# Appendix References

1 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville (MD): Agency for Healthcare Research and Quality (US); 2021.
2 Sterne JA, Hernan MA, Reeves BC, . ROBINS-I: a tool for assessing risk of bias in non-randomised studies of interventions. Bmj. 2016;355:i4919. PMID: 27733354. 10.1136/bmj.i4919 27733354
3 de Ferranti SD, Steinberger J, Ameduri R, . Cardiovascular Risk Reduction in High-Risk Pediatric Patients: A Scientific Statement From the American Heart Association. Circulation. 2019;139(13):e603–e34. PMID: 30798614. 10.1161/CIR.0000000000000618 30798614
4 Vos MB, Kaar JL, Welsh JA, . Added Sugars and Cardiovascular Disease Risk in Children: A Scientific Statement From the American Heart Association. Circulation. 2017;135(19):e1017–e34. Epub 2016 Aug 22. PMID: 27559074. 10.1161/CIR.0000000000000439 27550974
5 Grundy SM, Stone NJ, Bailey AL, . 2018 AHA/ACC/AACVPR/AAPA/ABC/ACPM/ADA/AGS/APhA/ASPC/NLA/PCNA Guideline on the Management of Blood Cholesterol: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Circulation. 2019;139(25):e1082–e143. PMID: 30586774. 10.1161/cir.0000000000000625 30586774
6 Jellinger PS, Handelsman Y, Rosenblit PD, . American Association of Clinical Endocrinologists and American College of Endocrinology Guidelines for Management of Dyslipidemia and Prevention of Cardiovascular Disease. Endocr Pract. 2017;23(Suppl 2):1–87. PMID: 28437620. 10.4158/ep171764.appgl 28437620
7 U.S. Department of Health and Human Services, National Institutes of Health, National Heart Lung and Blood Institute. Expert panel on integrated guidelines for cardiovascular health and risk reduction in children and adolescents: Full Report. NIH Publication No. 12-7486. Bethesda, MD: U.S. Department of Health and Human Services, National Institutes of Health, National Heart, Lung, and Blood Institute; 2012.
8 Goldberg AC, Hopkins PN, Toth PP, . Familial hypercholesterolemia: screening, diagnosis and management of pediatric and adult patients: clinical guidance from the National Lipid Association Expert Panel on Familial Hypercholesterolemia. J Clin Lipidol. 2011;5(3 Suppl):S1–8. PMID: 21600525. 10.1016/j.jacl.2011.04.003 21600525
9 Goodman DS, Hulley SB, Clark LT, . Report of the National Cholesterol Education Program Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults. Archives of Internal Medicine. 1988;148(1):36–69. 10.1001/archinte.1988.00380010040006 3422148
10 Browne B, Vasquez S. Pediatric dyslipidemias: Prescription medication efficacy and safety. J Clin Lipidol. 2008;2(3):189–201. PMID: 21291737. 10.1016/j.jacl.2008.04.008 21291737
11 Eiland LS, Luttrell PK. Use of statins for dyslipidemia in the pediatric population. J Pediatr Pharmacol Ther. 2010;15(3):160–72. PMID: 22477808.22477808
12 Miller ML, Wright CC, Rodriguez B. Use of Lipid Lowering Medications in Youth. In: Feingold KR, Anawalt B, Boyce A, Chrousos G, de Herder WW, Dhatariya K, ., editors. Endotext. South Dartmouth (MA) 2000.
13 AMGEN. FDA Approves Repatha® (evolocumab) In Pediatric Patients Age 10 And Older With Heterozygous Familial Hypercholesterolemia. Approval Based on HAUSER-RCT Study Demonstrating a Significant Reduction in LDL-C. Thousand Oaks, CA: Amgen; 2021.
14 de Ferranti SD, Rodday AM, Mendelson MM, . Prevalence of Familial Hypercholesterolemia in the 1999 to 2012 United States National Health and Nutrition Examination Surveys (NHANES). Circulation. 2016;133(11):1067–72. PMID: 26976914. 10.1161/CIRCULATIONAHA.115.018791 26976914
15 Jackson CL, Keeton JZ, Eason SJ, . Identifying Familial Hypercholesterolemia Using a Blood Donor Screening Program With More Than 1 Million Volunteer Donors. JAMA Cardiol. 2019;4(7):685–9. PMID: 31116347. 10.1001/jamacardio.2019.1518 31116347
16 Elliott E, Lilly C, Murphy E, . The Coronary Artery Risk Detection in Appalachian Communities (CARDIAC) Project: An 18 Year Review. Curr Pediatr Rev. 2017;13(4):265–76. PMID: 29345596. 10.2174/1573400514666180117093652 29345596
17 Perak AM, Ning H, Kit BK, . Trends in Levels of Lipids and Apolipoprotein B in US Youths Aged 6 to 19 Years, 1999-2016. JAMA. 2019;321(19):1895–905. PMID: 31112258. 10.1001/jama.2019.4984 31112258
18 Reina SA, Llabre MM, Vidot DC, . Metabolic Syndrome in Hispanic Youth: Results from the Hispanic Community Children’s Health Study/Study of Latino Youth. Metab. 2017;15(8):400–6. PMID: 28829223. 10.1089/met.2017.0054 28829223
19 Bauer KW, Marcus MD, El ghormli L, . Cardio-metabolic risk screening among adolescents: understanding the utility of body mass index, waist circumference and waist to height ratio. Pediatr Obes. 2015;10(5):329–37. PMID: 25515620. 10.1111/ijpo.267 25515620
20 Kinnear FJ, Lithander FE, Searle A, . Reducing cardiovascular disease risk among families with familial hypercholesterolaemia by improving diet and physical activity: a randomised controlled feasibility trial. BMJ Open. 2020;10(12):e044200. PMID: 33372081. 10.1136/bmjopen-2020-044200 33372081
21 The Writing Group for the DISC Collaborative Research Group. Efficacy and safety of lowering dietary intake of fat and cholesterol in children with elevated low-density lipoprotein cholesterol. The Dietary Intervention Study in Children (DISC). JAMA. 1995;273(18):1429–35. PMID: 7723156. 10.1001/jama.1995.03520420045036 7723156
22 Shannon BM, Tershakovec AM, Martel JK, . Reduction of elevated LDL-cholesterol levels of 4- to 10-year-old children through home-based dietary education. Pediatrics. 1994;94(6 Pt 1):923–7. PMID: 7971012.7971012
23 Wong H, Chahal N, Manlhiot C, . Flaxseed in pediatric hyperlipidemia: a placebo-controlled, blinded, randomized clinical trial of dietary flaxseed supplementation for children and adolescents with hypercholesterolemia. JAMA Pediatr. 2013;167(8):708–13. PMID: 23733031. 10.1001/jamapediatrics.2013.1442 23733031
24 Del Bo C, Deon V, Abello F, . Eight-week hempseed oil intervention improves the fatty acid composition of erythrocyte phospholipids and the omega-3 index, but does not affect the lipid profile in children and adolescents with primary hyperlipidemia. Food res. 2019;119:469–76. PMID: 30884679. 10.1016/j.foodres.2018.12.045 30884679
25 Avis HJ, Hutten BA, Gagné C, . Efficacy and safety of rosuvastatin therapy for children with familial hypercholesterolemia. J Am Coll Cardiol 2010. p. 1121–6. PMID: 20223367. 10.1016/j.jacc.2009.10.042 20223367
26 Clauss SB, Holmes KW, Hopkins P, . Efficacy and safety of lovastatin therapy in adolescent girls with heterozygous familial hypercholesterolemia. Pediatrics. 2005;116(3):682–8. PMID: 16140708. 10.1542/peds.2004-2090 16140708
27 de Jongh S, Lilien MR, op’t Roodt J, . Early statin therapy restores endothelial function in children with familial hypercholesterolemia. J Am Coll Cardiol. 2002;40(12):2117–21. PMID: 12505222. 10.1016/s0735-1097(02)02593-7 12505222
28 Knipscheer HC, Boelen CC, Kastelein JJ, . Short-term efficacy and safety of pravastatin in 72 children with familial hypercholesterolemia. Pediatr Res. 1996;39(5):867–71. PMID: 8726243. 10.1203/00006450-199605000-00021 8726243
29 McCrindle BW, Ose L, Marais AD. Efficacy and safety of atorvastatin in children and adolescents with familial hypercholesterolemia or severe hyperlipidemia: a multicenter, randomized, placebo-controlled trial. J Pediatr. 2003;143(1):74–80. PMID: 12915827. 10.1016/S0022-3476(03)00186-0 12915827
30 Stein EA, Illingworth DR, Kwiterovich PO, Jr., . Efficacy and safety of lovastatin in adolescent males with heterozygous familial hypercholesterolemia: a randomized controlled trial. JAMA. 1999;281(2):137–44. PMID: 9917116. 10.1001/jama.281.2.137 9917116
31 Wiegman A, Hutten BA, de Groot E, . Efficacy and safety of statin therapy in children with familial hypercholesterolemia: a randomized controlled trial. JAMA. 2004;292(3):331–7. PMID: 15265847. 10.1001/jama.292.3.331 15265847
32 Braamskamp MJ, Stefanutti C, Langslet G, . Efficacy and Safety of Pitavastatin in Children and Adolescents at High Future Cardiovascular Risk. J Pediatr. 2015;167(2):338–43 e5. PMID: 26059337. 10.1016/j.jpeds.2015.05.006 26059337
33 de Jongh S, Ose L, Szamosi T, . Efficacy and safety of statin therapy in children with familial hypercholesterolemia: a randomized, double-blind, placebo-controlled trial with simvastatin. Circulation. 2002;106(17):2231–7. PMID: 12390953. 10.1161/01.cir.0000035247.42888.82 12390953
34 Kusters DM, Avis HJ, de Groot E, . Ten-year follow-up after initiation of statin therapy in children with familial hypercholesterolemia. JAMA. 2014;312(10):1055–7. PMID: 25203086. 10.1001/jama.2014.8892 25203086
35 Desai NK, Mendelson MM, Baker A, . Hepatotoxicity of Statins as Determined by Serum Alanine Aminotransferase in a Pediatric Cohort With Dyslipidemia. Journal of Pediatric Gastroenterology & Nutrition. 2019;68(2):175–81. PMID: 30334928. 10.1097/MPG.0000000000002174 30334928
36 Joyce NR, Zachariah JP, Eaton CB, . Statin Use and the Risk of Type 2 Diabetes Mellitus in Children and Adolescents. Acad Pediatr. 2017;17(5):515–22. PMID: 28232259. 10.1016/j.acap.2017.02.006 28232259
37 Stein EA, Marais AD, Szamosi T, . Colesevelam hydrochloride: efficacy and safety in pediatric subjects with heterozygous familial hypercholesterolemia. J Pediatr. 2010;156(2):231–6. PMID: 19879596. 10.1016/j.jpeds.2009.08.037 19879596
38 Kusters DM, Caceres M, Coll M, . Efficacy and safety of ezetimibe monotherapy in children with heterozygous familial or nonfamilial hypercholesterolemia. J Pediatr. 2015;166(6):1377–84. PMID: 25841542. 10.1016/j.jpeds.2015.02.043 25841542
39 Santos RD, Ruzza A, Hovingh GK, . Evolocumab in Pediatric Heterozygous Familial Hypercholesterolemia. New England Journal of Medicine. 2020;383(14):1317–27. PMID: 32865373. 10.1056/NEJMoa2019910 32865373
40 Tonstad S, Knudtzon J, Sivertsen M, . Efficacy and safety of cholestyramine therapy in peripubertal and prepubertal children with familial hypercholesterolemia. J Pediatr. 1996;129(1):42–9. PMID: 8757561. 10.1016/s0022-3476(96)70188-9 8757561
41 Tonstad S, Sivertsen M, Aksnes L, . Low dose colestipol in adolescents with familial hypercholesterolaemia. Arch Dis Child. 1996;74(2):157–60. PMID: 8660081. 10.1136/adc.74.2.157 8660081
42 van der Graaf A, Cuffie-Jackson C, Vissers MN, . Efficacy and safety of coadministration of ezetimibe and simvastatin in adolescents with heterozygous familial hypercholesterolemia. J Am Coll Cardiol. 2008;52(17):1421–9. PMID: 18940534. 10.1016/j.jacc.2008.09.002 18940534
43 Wheeler KA, West RJ, Lloyd JK, . Double blind trial of bezafibrate in familial hypercholesterolaemia. Arch Dis Child. 1985;60(1):34–7. PMID: 3882058. 10.1136/adc.60.1.34 3882058
44 Gidding SS, Prospero C, Hossain J, . A double-blind randomized trial of fish oil to lower triglycerides and improve cardiometabolic risk in adolescents. J Pediatr. 2014;165(3):497–503.e2. PMID: 25008950. 10.1016/j.jpeds.2014.05.039 25008950
45 Guardamagna O, Amaretti A, Puddu PE, . Bifidobacteria supplementation: effects on plasma lipid profiles in dyslipidemic children. Nutrition. 2014;30(7–8):831–6. PMID: 24985000. 10.1016/j.nut.2014.01.014 24985000
46 Martino F, Martino E, Morrone F, . Effect of dietary supplementation with glucomannan on plasma total cholesterol and low density lipoprotein cholesterol in hypercholesterolemic children. Nutr Metab Cardiovasc Dis. 2005;15(3):174–80. PMID: 15955465. 10.1016/j.numecd.2004.04.004 15955465
47 Verduci E, Agostoni C, Radaelli G, . Blood lipids profile in hyperlipidemic children undergoing different dietary long chain polyunsaturated supplementations: a preliminary clinical trial. Int J Food Sci Nutr. 2014;65(3):375–9. PMID: 24228803. 10.3109/09637486.2013.858239 24228803
48 Dennison BA, Levine DM. Randomized, double-blind, placebo-controlled, two-period crossover clinical trial of psyllium fiber in children with hypercholesterolemia. J Pediatr. 1993;123(1):24–9. PMID: 8391569. 10.1016/s0022-3476(05)81532-x 8391569
49 Guardamagna O, Abello F, Cagliero P, . Could dyslipidemic children benefit from glucomannan intake? Nutrition. 2013;29(7–8):1060–5. PMID: 23759268. 10.1016/j.nut.2013.02.010 23759268