# Appendix F Ongoing Studies

Condition | Trial title | Trial number | Location | N | Duration (yrs) | Intervention | Relevant endpoints | Estimated completion date
FH Case Finding | Improved Diagnosis of Familial Hypercholesterolemia Across the Northland (ID-FH) | NCT05238519 | US (Minnesota, Wisconsin, North Dakota) | 200 | 6 months | Participants with suspected FH (2-75 yrs) are randomized to usual care or motivational interview designed to promote communication of risk to family members | Cascade screening of 1st degree family members; Proportion of participants with LDL-C <100; Absolute change in LDL-C; Proportion of participants w self-reported genetic testing | Feb 2025
FH Registry | CASCADE FH Registry (CAscade SCreening for Awareness and DEtection of Familial Hypercholesterolemia Registry) | NCT01960244 | US | 5000 | 3 | National, multi-center registry to track therapy, clinical outcomes, and patient-reported outcomes over time | Number of identified FH patients, reaching optimal level of disease management; target treatment levels for LDL-C | Dec 2025
FH Tx | A Randomized, Double-Blind, Placebo-Controlled Study Followed by an Open Label Treatment Period to Evaluate the Efficacy and Safety of Alirocumab in Children and Adolescents with Heterozygous Familial Hypercholesterolemia | NCT03510884 | France | 150 | NR | Alirocumab (one of 4 doses) | Percent change in TC, LDL-C, HDL-C, and TG; AEs | Aug 2022
FH Tx | Study to Evaluate Efficacy and Safety of Inclisiran in Adolescents With Heterozygous Familial Hypercholesterolemia (ORION-16) | NCT04652726 | Multinational (includes US) | 150 | | 1 year double-blind inclisiran (300mg) versus placebo / 1 year open-label inclisiran (300mg) | Percent change in LDL-C | Dec 2024 (recruiting)
MFD Tx | Omega-3 Fatty Acid Dietary Intervention for Dyslipidemia of Obesity in Children 10 to <18 Years of Age: O3DI Study | NCT05025943 | US | 40 | NR | Standard lifestyle intervention + omega-3 fatty acid enriched diet | Change in serum TG | Mar 2023

Abbreviations: AE = adverse events; FH = familial hypercholesterolemia; HDL-C = high-density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; MFD = multifactorial dyslipidemia; NR = not reported; TC = total cholesterol; TG = triglycerides; Tx = treatment; US = United States; yrs = years