# Appendix E Additional Evidence Tables

Appendix E Table 1 Familial Hypercholesterolemia: Additional Study Characteristics for US Cohorts Included for Key Question 2

Appendix E Table 2 Multifactorial Dyslipidemia: Additional Study Characteristics for US Cohorts Included for Key Question 2

Appendix E Table 3 Familial Hypercholesterolemia: Behavioral Intervention Trials—Results for Mean Difference in Change for Additional Outcomes

Appendix E Table 4 Multifactorial Dyslipidemia: Behavioral Intervention Trials—Detailed Intervention Descriptions

Appendix E Table 5 Multifactorial Dyslipidemia: Behavioral Intervention Trials—Results for Mean Difference in Change in Behavioral Outcomes

Appendix E Table 6 Multifactorial Dyslipidemia: Supplement Intervention Trials—Results for Mean Difference in Change in Non-Lipid Outcomes

Appendix E Table 7 Multifactorial Dyslipidemia/FH: Supplement Intervention Trials—Results for Mean Difference in Change in BMI

Appendix E Table 8 Familial Hypercholesterolemia: Statin Intervention Trials—Results for Total Adverse Events

Appendix E Table 9 Familial Hypercholesterolemia: Statin Intervention Trials—Results for Withdrawals Due to Adverse Events

Appendix E Table 10 Familial Hypercholesterolemia: Statin Intervention Trials—Liver-Related Adverse Events

Appendix E Table 11 Familial Hypercholesterolemia: Nonrandomized Studies of Statin Interventions—Additional Liver-Related Adverse Event Outcomes

Appendix E Table 12 Familial Hypercholesterolemia: Statin Intervention Trials—Results for Abnormal Creatine Kinase

Appendix E Table 13 Familial Hypercholesterolemia: Statin Intervention Trials—Musculoskeletal Adverse Events

Appendix E Table 14 Familial Hypercholesterolemia: Statin Intervention Trials—Results for Difference in Tanner Stage

Appendix E Table 15 Familial Hypercholesterolemia: Statin Intervention Trials—Hormonal Adverse Events

Appendix E Table 16 Familial Hypercholesterolemia: Statin Intervention Trials—Gastrointestinal Adverse Events

Appendix E Table 17 Familial Hypercholesterolemia: Statin Intervention Trials—Dermatologic Adverse Events

Appendix E Table 18 Familial Hypercholesterolemia: Statin Intervention Trials—Other Adverse Events

Appendix E Table 19 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Total Adverse Events

Appendix E Table 20 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Gastrointestinal Adverse Events

Appendix E Table 21 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Liver-Related Adverse Events

Appendix E Table 22 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Musculoskeletal Adverse Events

Appendix E Table 23 Familial Hypercholesterolemia: Non-Statin Drug Intervention Trials—Additional Dichotomous Harms Outcome

Appendix E Table 24 Multifactorial Dyslipidemia: Behavioral Intervention Trials—Additional Dichotomous Harms Outcomes

Appendix E Table 25 Multifactorial Dyslipidemia: Behavioral Intervention Trials—Additional Continuous Harms Outcomes

Appendix E Table 26 Multifactorial Dyslipidemia: Supplement Intervention Trials—Additional Dichotomous Harms Outcomes

Appendix E Table 27 Multifactorial Dyslipidemia/FH: Supplement Intervention Trials—Additional Dichotomous Harms Outcomes