# Appendix D Excluded Studies List

Reason for Exclusion^*^
E1. Aim/relevant
E2. Population
E3. Intervention
E4. Comparator
E5. Outcomes (no relevant outcomes)
E6. Setting
E6a. Not conducted in US (KQ2-specific)
E7. Design
E8. Non-Very High HDI Country
E9. Non-English
E10. Poor quality
E11. Ongoing study, no outcomes published
E12. Conference abstract only
E13. Yield study that is out for size or recency (KQ2-specific)
E13a. Yield study with sub-analyses that are not relevant for review
E13b. Yield study where data is captured in another overlapping cohort or publication

* Assigned at full-text phase.

Abbreviations: E = exclude; HDI = Human Development Index; KQ = key question, US = United States

1 Abello, F, Cagliero, P, . Lycopene supplementation in children affected by primary dyslipidaemia: Effects on lipid profile and oxidative stress. High Blood Press Cardiovasc Prev. 2(94). 2012. KQ4E12, KQ5E12
2 Abul-Husn, NS, Manickam, K, . Genetic identification of familial hypercholesterolemia within a single U.S. health care system. Science. 354(6319): aaf7000. doi: 10.1126/science.aaf7000. 2016. KQ2E528008010
3 Ademi, Z, Martin, AC. Universal screening of children for familial hypercholesterolaemia: Value for money? Atherosclerosis. 275: 384–386. 2018. 10.1016/j.atherosclerosis.2018.06.874. KQ1E7, KQ3E729961599
4 Akcan, N, Obaid, M, . Evidence in obese children: contribution of tri-ponderal mass index or body mass index to dyslipidemia, obesity-inflammation, and insulin sensitivity. Journal of Pediatric Endocrinology & Metabolism. 33(2): 223–231. 2020. 10.1515/jpem-2019-0106. KQ2E6a31809264
5 Albaum, JM, Carsley, S, . Persistent High Non-High-Density Lipoprotein Cholesterol in Early Childhood: A Latent Class Growth Model Analysis. J Pediatr. 191: 152–157. 2017. 10.1016/j.jpeds.2017.08.079. KQ2E6a29173300
6 Alemzadeh, R, Kichler, J. Comparison of Apolipoprotein (ApoB/ApoA-1) and Lipoprotein (Total Cholesterol/HDL) Ratios in Obese Adolescents. Metab Syndr Relat Disord. 16(1): 40–45. 2018. 10.1089/met.2017.0135. KQ2E529154726
7 Alias-Hernandez, I, Galera-Martinez, R, . Insulinaemia and insulin resistance in Caucasian general paediatric population aged 2 to 10 years: Associated risk factors. Pediatr Diabetes. 19(1): 45–52. 2018. 10.1111/pedi.12533. KQ2E6a28493411
8 Allen-Tice, C, Steinberger, J, . Pediatric cholesterol screening practices in 9- to 11-year-olds in a large midwestern primary care setting. J Clin Lipidol. 14(2): 224–230. 2020. 10.1016/j.jacl.2020.01.013. KQ2E1032111582
9 Anderson, LN, Maguire, JL, . Duration of Fasting, Serum Lipids, and Metabolic Profile in Early Childhood. J Pediatr. 180: 47–52.e1. 2017. 10.1016/j.jpeds.2016.09.005. KQ2E6a27742126
10 Antwi, J, Lavin, R, . Perception of and risk factors for type 2 diabetes among students attending an upstate New York college: a pilot study. Diabetol Metab Syndr. 12: 25. 2020. 10.1186/s13098-020-00535-1. KQ2E232256715
11 Araujo, MB, Pacce, MS. A 10-year experience using combined lipid-lowering pharmacotherapy in children and adolescents. Journal of Pediatric Endocrinology & Metabolism. 29(11): 1285–1291. 2016. 10.1515/jpem-2016-0117. KQ4E7, KQ5E427718491
12 Attilakos, A, Zerva, O, . Effect of phytosterols on serum lipids of children with hypercholesterolemia. J Inherit Metab Dis. 41 (Suppl 1): S43. 2018. KQ4E12, KQ5E12
13 Balder, JW, Lansberg, PJ, . Pediatric lipid reference values in the general population: The Dutch lifelines cohort study. J Clin Lipidol. 12(5): 1208–1216. 2018. 10.1016/j.jacl.2018.05.011. KQ2E6a, KQ3E430007775
14 Baran, J, Weres, A, . Blood lipid profile and body composition in a pediatric population with different levels of physical activity. Lipids Health Dis. 17(1): 171. 2018. 10.1186/s12944-018-0817-2. KQ2E6a30045723
15 Barreiro-Ribeiro, F, Vasques, AC, . Hypertriglyceridemic Waist Phenotype Indicates Insulin Resistance in Adolescents According to the Clamp Technique in the BRAMS Study. Childhood Obesity. 12(6): 446–454. 2016. KQ2E8, KQ3E827627113
16 Behiry, EG, El Nady, NM, . Evaluation of TG-HDL Ratio Instead of HOMA Ratio as Insulin Resistance Marker in Overweight and Children with Obesity. Endocr Metab Immune Disord Drug Targets. 19(5): 676–682. 2019. 10.2174/1871530319666190121123535. KQ2E6a30663576
17 Blakeley, Ce, Van, Rompay Mi, . Relationship between muscle strength and dyslipidemia, serum 25(OH)D, and weight status among diverse schoolchildren: a cross-sectional analysis. BMC Pediatr. 18(1) (no pagination). 2018. 10.1186/s12887-018-0998-x. KQ2E13
18 Blumenfeld, Olivares Ja, San, Mauro Martín I, . Low-fat, fermented milk enriched with plant sterols, a strategy to reduce hypertriglyceridema in children, a double-blind, randomized placebo-cotrolled trial. Nutr Hosp. 32(3): 1056–1060. 2015. 10.3305/nh.2015.32.3.9319. KQ4E9, KQ5E926319820
19 Borresen, EC, Jenkins-Puccetti, N, . A Pilot Randomized Controlled Clinical Trial to Assess Tolerance and Efficacy of Navy Bean and Rice Bran Supplementation for Lowering Cholesterol in Children. Lobal Pediatric Health. 4: 2333794X17694231. 2017. 10.1177/2333794X17694231. KQ4E10, KQ5E10
20 Braamskamp, MJ, Hutten, BA, . Early initiation of statin treatment in children with familial hypercholesterolaemia. Curr Opin Lipidol. 26(3): 236–9. 2015. 10.1097/MOL.0000000000000177. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E725943840
21 Braamskamp, Mjam, Langslet, G, . Effect of Rosuvastatin on Carotid Intima-Media Thickness in Children With Heterozygous Familial Hypercholesterolemia: The CHARON Study (Hypercholesterolemia in Children and Adolescents Taking Rosuvastatin Open Label). Circulation. 136(4): 359–366. 2017. PMID: 28592434. 10.1161/CIRCULATIONAHA.116.025158. KQ4E7, KQ5E528592434
22 Braamskamp, Mjam, Langslet, G, . Efficacy and safety of rosuvastatin therapy in children and adolescents with familial hypercholesterolemia: Results from the CHARON study. J Clin Lipidol. 9(6): 741–750. 2015. PMID: 26687694. 10.1016/j.jacl.2015.07.011. KQ4E4, KQ5E426687694
23 Bridges, KG, Jarrett, T, . Use of the triglyceride to HDL cholesterol ratio for assessing insulin sensitivity in overweight and obese children in rural Appalachia. Journal of Pediatric Endocrinology & Metabolism. 29(2): 153–6. 2016. 10.1515/jpem-2015-0158. KQ2E1326352085
24 Bucholz, EM, Gooding, HC, . Awareness of Cardiovascular Risk Factors in U.S. Young Adults Aged 18-39 Years. Am J Prev Med. 54(4): e67–e77. 2018. 10.1016/j.amepre.2018.01.022. KQ2E229433955
25 Bugge, A, Moller, S, . Associations between waist circumference, metabolic risk and executive function in adolescents: A cross-sectional mediation analysis. PLoS ONE [Electronic Resource]. 13(6): e0199281. 2018. 10.1371/journal.pone.0199281. KQ2E6a29912925
26 Buonuomo, PS, Macchiaiolo, M, . Statin-associated myopathy in pediatric settings: Myth or fact?. J Pediatr. 191: 279. 2017. 10.1016/j.jpeds.2017.08.056. KQ4E5, KQ5E728964429
27 Burns, RD, Brusseau, TA, . Waist-to-Height Ratio, Aerobic Fitness, and Cardiometabolic Risk in Hispanic Children From Low-Income U.S. Schools. Pediatr Exerc Sci. 28(3): 388–96. 2016. 10.1123/pes.2016-0016. KQ2E527174796
28 Cagliero, P, Abello, F, . Effects of bifidobacterium supplementation on plasma lipid profile in dyslipidemic children. High Blood Press Cardiovasc Prev. 20(2): 93–114. 2013. KQ4E12, KQ5E12
29 Cagliero, P, Marini, E, . The effects of probiotics supplementation on antioxidant activity in children affected by primary hyperlipidemia. High Blood Press Cardiovasc Prev. 21(2): 151–169. 2014. KQ4E12, KQ5E12
30 Carreau, V, Girardet, JP, . Long-term follow-up of statin treatment in a cohort of children with familial hypercholesterolemia: efficacy and tolerability. Paediatr Drugs. 13(4): 267–75. 2011. PMID: 21692550. 10.2165/11591650-000000000-00000. KQ4E4, KQ5E421692550
31 Carson, V, Tremblay, MS, . Compositional analyses of the associations between sedentary time, different intensities of physical activity, and cardiometabolic biomarkers among children and youth from the United States. PLoS ONE [Electronic Resource]. 14(7): e0220009. 2019. 10.1371/journal.pone.0220009. KQ2E531329609
32 Cayres, SU, de Lira, FS, . The mediating role of physical inactivity on the relationship between inflammation and artery thickness in prepubertal adolescents. J Pediatr. 166(4): 924–9. 2015. 10.1016/j.jpeds.2014.12.057. KQ2E6a25661410
33 Centers for Disease Control Prevention, . Prevalence of abnormal lipid levels among youths --- United States, 1999-2006. MMWR Morb Mortal Wkly Rep. 59(2): 29–33. 2010. PMID: 20094024. KQ2E1320094024
34 Cesa, CC, Barbiero, SM, . Effectiveness of physical exercise to reduce cardiovascular risk factors in youths: a randomized clinical trial. J Clin Med Res. 7(5): 348–55. 2015. 10.14740/jocmr1700w. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E825780484
35 Chahal, N, McCrindle, B, . A 4-week randomized clinical trial of flaxseed supplementation in children with hypercholesterolemia. Can J Cardiol. (5): S339. 2011. KQ4E12, KQ5E12
36 Chahal, N, Rush, J, . Dyslipidemia management in overweight or obese adolescents: A mixed-methods clinical trial of motivational interviewing. SAGE Open Medicine. 5: 2050312117707152. 2017. 10.1177/2050312117707152. KQ4E4, KQ5E428567283
37 Chen, E, Miller, Ge, . Unsupportive parenting moderates the effects of family psychosocial intervention on metabolic syndrome in African American youth. Int J Obes (Lond). 42(4): 634–640. 2018. 10.1038/ijo.2017.246. KQ2E5, KQ4E5, KQ5E528984843
38 Choi, YS, Klaric, JS, . Prediction of insulin resistance with anthropometric and clinical laboratory measures in nondiabetic teenagers. Metab Syndr Relat Disord. 17(1): 37–45. 2019. 10.1089/met.2018.0072. KQ2E530394863
39 Christensen, JJ, Ulven, SM, . Comprehensive lipid and metabolite profiling of children with and without familial hypercholesterolemia: A cross-sectional study. Atherosclerosis. 266(): 48–57. 2017. 10.1016/j.atherosclerosis.2017.09.021. KQ2E6a, KQ3E528963918
40 Clarke, JT, Cullen-Dean, G, . Increased incidence of epistaxis in adolescents with familial hypercholesterolemia treated with fish oil. J Pediatr. 116(1): 139–41. 1990. 10.1016/s0022-3476(05)81666-x. KQ4E7, KQ5E42295954
41 Corriveau, N, Eagle, T, . Sustained Benefit Over Four-Year Follow-Up of Michigan’s Project Healthy Schools. Am J Public Health. 105(12): e19–25. 2015. 10.2105/AJPH.2015.302835. KQ2E5
42 Cottrell, L, John, C, . Individual-, family-, community-, and policy-level impact of a school-based cardiovascular risk detection screening program for children in underserved, rural areas: the CARDIAC Project. J Obes. 2013:732579.(doi): 10.1155/2013/732579. Epub 2013 Jun 5.. 2013. PMID: 23840946. KQ2E13b23840946
43 Cottrell, L, Lilly, C, . Chronic disease risk screening: characteristics of parents who participate in screening with their children. West Virginia Medical Journal. 111(1): 26–31. 2015. KQ2E5
44 Croyle, RT, Sun, YC, . Psychological minimization of cholesterol test results: moderators of appraisal in college students and community residents. Health Psychol. 12(6): 503–7. 1993. PMID: 8293735. 10.1037//0278-6133.12.6.503. KQ3E48293735
45 Daniels, S, Caprio, S, . PCSK9 inhibition with alirocumab in pediatric patients with heterozygous familial hypercholesterolemia: The ODYSSEY KIDS study. J Clin Lipidol. 14(3): 322–330.e5. 2020. 10.1016/j.jacl.2020.03.001. KQ4E7, KQ5E432331936
46 Davidson, MH, Dugan, LD, . A psyllium-enriched cereal for the treatment of hypercholesterolemia in children: a controlled, double-blind, crossover study. Am J Clin Nutr. 63(1): 96–102. 1996. PMID: 8604676. 10.1093/ajcn/63.1.96. KQ4E10, KQ5E108604676
47 Davidson, MH, Dugan, LD, . A psyllium-enriched cereal for the treatment of hypercholesterolemia in children: a controlled, double-blind, crossover study. Am J Clin Nutr. 63(1): 96–102. 1996. PMID: 8604676. 10.1093/ajcn/63.1.96. KQ4E10, KQ5E108604676
48 de Ferranti, SD, Shrader, P, . Children with Heterozygous Familial Hypercholesterolemia in the United States: Data from the Cascade Screening for Awareness and Detection-FH Registry. J Pediatr. 229: 70–77. 2021. 10.1016/j.jpeds.2020.09.042. KQ2E5, KQ3E5, KQ4E7, KQ5E532976895
49 Deeb, A, Attia, S, . Dyslipidemia and Fatty Liver Disease in Overweight and Obese Children. J Obes. 2018: 8626818. 2018. 10.1155/2018/8626818. KQ2E6a30009050
50 Dhuper, S, Bayoumi, NS, . Ethnic Differences in Lipid Profiles of Overweight, Obese, and Severely Obese Children and Adolescents 6-19 Years of Age. Childhood Obesity. 13(3): 236–241. 2017. 10.1089/chi.2016.0208. KQ2E528398850
51 Dickey, W, Arday, DR, . Outpatient evaluation, recognition, and initial management of pediatric overweight and obesity in U.S. military medical treatment facilities. J Am Assoc Nurse Pract. 29(2): 85–93. 2017. 10.1002/2327-6924.12398. KQ2E527582288
52 Dong, B, Arnold, LW, . Ethnic differences in cardiometabolic risk among adolescents across the waist-height ratio spectrum: National Health and Nutrition Examination Surveys (NHANES). Int J Cardiol. 222: 622–628. 2016. 10.1016/j.ijcard.2016.07.169. KQ2E13b27517651
53 Doshi, N, Perrin, EM, . Short-term change in body mass index in overweight adolescents following cholesterol screening. Arch Pediatr Adolesc Med. 163(9): 812–7. 2009. PMID: 19736334. 10.1001/archpediatrics.2009.152. KQ1E7, KQ3E519736334
54 Douglas, MB, Birrer, RB, . Obese children should be screened for hypercholesterolemia. J Health Care Poor Underserved. 7(1): 24–35. 1996. 10.1353/hpu.2010.0012. KQ2E138645782
55 Draijer, LG, Bosch, AM, . Screening for lysosomal acid lipase deficiency: A retrospective data mining study and evaluation of screening criteria. Atherosclerosis. 278: 174–179. 2018. 10.1016/j.atherosclerosis.2018.09.023. KQ2E6a, KQ3E530286343
56 Ducobu, J, Brasseur, D, . Simvastatin use in children. Lancet. 339(8807): 1488. 1992. PMID: 1351171. 10.1016/0140-6736(92)92092-t. KQ4E7, KQ5E41351171
57 Elmaogullari, S, Demirel, F, . Risk factors that affect metabolic health status in obese children. Journal of Pediatric Endocrinology & Metabolism. 30(1): 49–55. 2017. 10.1515/jpem-2016-0128. KQ2E6a27992361
58 Faigel, HC. Screening college students for hypercholesterolemia. J Am Coll Health. 40(6): 272–5. 1992. 10.1080/07448481.1992.9936292. KQ2E131602094
59 Fich M, Krzysko-Pieczka, I, . FKBP5 polymorphism is associated with insulin resistance in children and adolescents with obesity. Obes Res Clin Pract. 12(Suppl 2): 62–70. 2018. 10.1016/j.orcp.2016.11.007. KQ2E6a28007534
60 Florentin, M, Elisaf, MS, . L-Carnitine/Simvastatin Reduces Lipoprotein (a) Levels Compared with Simvastatin Monotherapy: A Randomized Double-Blind Placebo-Controlled Study. Lipids. 52(1): 1–9. 2017. 10.1007/s11745-016-4216-z. KQ4E2, KQ5E227914033
61 Fonseca, MJ, Oliveira, A, . Association of Pubertal Development With Adiposity and Cardiometabolic Health in Girls and Boys-Findings From the Generation XXI Birth Cohort. J Adolesc Health. 65(4): 558–563. 2019. 10.1016/j.jadohealth.2019.05.014. KQ2E6a31377165
62 Ford, ES, Li, C, . Concentrations of low-density lipoprotein cholesterol and total cholesterol among children and adolescents in the United States. Circulation. 119(8): 1108–15. 2009. PMID: 19221218. 10.1161/CIRCULATIONAHA.108.816769. KQ2E1319221218
63 Fritz, J, Lopez-Ridaura, R, . The association of Native American genetic ancestry and high-density lipoprotein cholesterol: A representative study of a highly admixed population. Am J Hum Biol. 32(6): e23426. 2020. 10.1002/ajhb.23426. KQ2E6a32329554
64 Futema, M, Cooper, JA, . Screening for familial hypercholesterolaemia in childhood: Avon Longitudinal Study of Parents and Children (ALSPAC). Atherosclerosis. 260: 47–55. 2017. 10.1016/j.atherosclerosis.2017.03.007. KQ2E6a, KQ3E428349888
65 Gagliano, NJ, Emans, SJ, . Cholesterol screening in the adolescent. J Adolesc Health. 14(2): 104–8. 1993. 10.1016/1054-139x(93)90093-5. KQ2E138476872
66 Gagné, C, Kusters, M, . Efficacy and Safety of Ezetimibe Monotherapy in 6-10 Year Old Children with Heterozygous Familial or Nonfamilial Hypercholesterolemia. J Clin Lipidol. 7(3): 257–258. 2013. KQ4E12, KQ5E12
67 Gandelman, K, Glue, P, . An eight-week trial investigating the efficacy and tolerability of atorvastatin for children and adolescents with heterozygous familial hypercholesterolemia. Pediatr Cardiol. 32(4): 433–41. 2011. PMID: 21259004. 10.1007/s00246-011-9885-z. KQ4E4, KQ5E421259004
68 Garcia, RE, Moodie, DS. Routine cholesterol surveillance in childhood. Pediatrics. 84(5): 751–5. 1989. PMID: 2640549. KQ2E132640549
69 Garoufi, A, Drakatos, A, . Comparing calculated LDL-C with directly measured LDL-C in healthy and in dyslipidemic children. Clin Biochem. 50(1–2): 16–22. 2017. 10.1016/j.clinbiochem.2016.05.026. KQ2E6a, KQ3E527836622
70 Giardi EV, Paul, TK, . Cardiovascular Disease Risk Among Young Urban Women. Journal of Women’s Health. 25(11): 1139–1146. 2016. KQ2E2
71 Gidding, SS, Keith, SW, . Adolescent and adult African Americans have similar metabolic dyslipidemia. J Clin Lipidol. 9(3): 368–76. 2015. 10.1016/j.jacl.2014.11.010. KQ2E1326073396
72 Gillman, MW, Cupples, LA, . Impact of within-person variability on identifying children with hypercholesterolemia: Framingham Children’s Study. J Pediatr. 121(3): 342–7. 1992. PMID: 1517906. 10.1016/s0022-3476(05)81785-8. KQ2E5, KQ3E41517906
73 Giro J, Rodriguez-Borjabad, C, . Plasma inducible degrader of the LDLR, soluble low-density lipoprotein receptor, and proprotein convertase subtilisin/kexin type 9 levels as potential biomarkers of familial hypercholesterolemia in children. J Clin Lipidol. 12(1): 211–218. 2018. 10.1016/j.jacl.2017.10.003. KQ2E6a, KQ3E529102496
74 Glueck, CJ, Tsang, RC, . Plasma vitamin A and E levels in children with familial type II hyperlipoproteinemia during therapy with diet and cholestyramine resin. Pediatrics. 54(1): 51–5. 1974. KQ4E7, KQ5E44365953
75 Gomes, HA, Garcia, P, . Experience on statin therapy in paediatric age: retrospective study in a Portuguese referral centre. Cardiol Young. 30(6): 840–851. 2020. 10.1017/S1047951120001158. KQ3E4, KQ4E7, KQ5E432408915
76 Gomez-Arbelaez, D, Camacho, PA, . Neck circumference as a predictor of metabolic syndrome, insulin resistance and low-grade systemic inflammation in children: the ACFIES study. BMC Pediatr. 16: 31. 2016. 10.1186/s12887-016-0566-1. KQ2E6a26956385
77 Goncalves, R, Szmuchrowski, LA, . Selected anthropometric variables and aerobic fitness as predictors of cardiovascular disease risk in children. Biology of Sport. 32(3): 255–60. 2015. 10.5604/20831862.1163371. KQ2E6a26424930
78 Gore, MO, Eason, SJ, . High prevalence of elevated haemoglobin A1C among adolescent blood donors: Results from a voluntary screening programme including 31,546 adolescents. Diabetes & Vascular Disease Research. 12(4): 272–8. 2015. 10.1177/1479164115579799. KQ2E525972340
79 Gregory, EF, Miller, JM, . Routine Cholesterol Tests and Subsequent Change in BMI Among Overweight and Obese Children. Acad Pediatr. 19(7): 773–779. 2019. 10.1016/j.acap.2019.05.131. KQ1E7, KQ2E13, KQ3E731152795
80 Griffin, TC, Christoffel, KK, . Family history evaluation as a predictive screen for childhood hypercholesterolemia. Pediatric Practice Research Group. Pediatrics. 84(2): 365–73. 1989. KQ2E132748269
81 Groot, PH, Dijkhuis-Stoffelsma, R, . The effects of colestipol hydrochloride on serum lipoprotein lipid and apolipoprotein B and A-I concentrations in children heterozygous for familial hypercholesterolemia. Acta Paediatr Scand. 72(1): 81–5. 1983. PMID: 6407278. 10.1111/j.1651-2227.1983.tb09668.x. KQ4E10, KQ5E56407278
82 Grzymski, JJ, Elhanan, G, . Population genetic screening efficiently identifies carriers of autosomal dominant diseases. Nat Med. 26(8): 1235–1239. 2020. 10.1038/s41591-020-0982-5. KQ2E232719484
83 Habiba, NM, Fulda, KG, . Correlation of Lipid Profile and Risk of Developing Type 2 Diabetes Mellitus in 10-14 Year Old Children. Cell Physiol Biochem. 39(5): 1695–1704. 2016. KQ2E1327642750
84 Hansen, D, Michaelsen, KF, . Growth during treatment of familial hypercholesterolemia. Acta Paediatr. 81(12): 1023–5. 1992. PMID: 1290846. 10.1111/j.1651-2227.1992.tb12167.x. KQ4E7, KQ5E41290846
85 Harada-Shiba M, Kastelein JJP, Hovingh GK, . Efficacy and Safety of Pitavastatin in Children and Adolescents with Familial Hypercholesterolemia in Japan and Europe. J Atheroscler Thromb. 2018;25(5):422–9. KQ4E5, KQ5E5 10.5551/jat.42242 29187694
86 Harada-Shiba, M, Arisaka, O, . Efficacy and Safety of Pitavastatin in Japanese Male Children with Familial Hypercholesterolemia. J Atheroscler Thromb. 23(1): 48–55. 2016. 10.5551/jat.28753. KQ4E4, KQ5E425891210
87 Hartz, JC, Yellen, E, . The relationship between payer type and lipid outcomes in response to clinical lifestyle interventions in youth with dyslipidemia. BMC Pediatr. 19(1): 217. 2019. 10.1186/s12887-019-1593-5. KQ2E231266458
88 Hedman, M, Neuvonen, PJ, . Pharmacokinetics and pharmacodynamics of pravastatin in children with familial hypercholesterolemia. Clin Pharmacol Ther. 74(2): 178–85. 2003. PMID: 12891228. 10.1016/S0009-9236(03)00153-X. KQ4E4, KQ5E412891228
89 Helk, O, Widhalm, K. Effects of a low-fat dietary regimen enriched with soy in children affected with heterozygous familial hypercholesterolemia. Clinical Nutrition ESPEN. 36: 150–156. 2020. 10.1016/j.clnesp.2019.09.009. KQ4E10, KQ5E1032220359
90 Hendriksen, R. B., & van der Gaag, E. J. (2022). Effect of a dietary intervention including minimal and unprocessed foods, high in natural saturated fats, on the lipid profile of children, pooled evidence from randomized controlled trials and a cohort study. PLoS ONE [Electronic Resource], 17(1), e0261446. PMID: 34986194. 10.1371/journal.pone.0261446. KQ4E2, KQ5E234986194
91 Hennig, M, Brandt-Varma, A, . Monitoring the Effects of Hypolipidemic Treatment in Children with Familial Hypercholesterolemia in Poland. Life. 10(11): 04. 2020. 10.3390/life10110270. KQ4E7, KQ5E4
92 Herrington, L, Susi, A, . Factors Affecting Pediatric Dyslipidemia Screening and Treatment. Clin Pediatr (Phila). 58(5): 502–510. 2019. 10.1177/0009922819832068. KQ2E1030793626
93 Hetherington-Rauth, M, Bea, Jw, . Comparison of direct measures of adiposity with indirect measures for assessing cardiometabolic risk factors in preadolescent girls. Nutr J. 16(1) (no pagination). 2017. 10.1186/s12937-017-0236-7. KQ2E5
94 Higgins, V, Asgari, S, . Pediatric reference intervals for calculated LDL cholesterol, non-HDL cholesterol, and remnant cholesterol in the healthy CALIPER cohort. Clin Chim Acta. 486: 129–134. 2018. 10.1016/j.cca.2018.07.028. KQ1E7, KQ2E6a, KQ3E530025755
95 Huang, F, Del-Rio-Navarro, BE, . Effect of omega-3 fatty acids supplementation combined with lifestyle intervention on adipokines and biomarkers of endothelial dysfunction in obese adolescents with hypertriglyceridemia. J Nutr Biochem. 64: 162–169. 2019. 10.1016/j.jnutbio.2018.10.012. KQ4E8, KQ5E830513433
96 Hudson, SE, Feigenbaum, MS, . Screening and socioeconomic associations of dyslipidemia in young adults. BMC Public Health. 20(1): 104. 2020. 10.1186/s12889-019-8099-9. KQ2E531992243
97 Humphries, SE, Cooper, J, . The UK Paediatric Familial Hypercholesterolaemia Register: Statin-related safety and 1-year growth data. J Clin Lipidol. 12(1): 25–32. 2018. 10.1016/j.jacl.2017.11.005. KQ4E7, KQ5E1029208363
98 Ice, CL, Murphy, E, . Morbidly obese diagnosis as an indicator of cardiovascular disease risk in children: results from the CARDIAC Project. Int J Pediatr Obes. 6(2): 113–9. 2011. PMID: 20545480. 10.3109/17477161003792556. KQ2E13b20545480
99 Ip, EH, Leng, X, . Risk profiles of lipids, blood pressure, and anthropometric measures in childhood and adolescence: project heartBeat! BMC Obesity. 3: 9. 2016. 10.1186/s40608-016-0090-8. KQ2E526929822
100 Iskandar, I, Harahap, Y, . Efficacy and tolerability of a nutraceutical combination of red yeast rice, guggulipid, and chromium picolinate evaluated in a randomized, placebo-controlled, double-blind study. Complement Ther Med. 48: 102282. 2020. 10.1016/j.ctim.2019.102282. KQ4E8, KQ5E831987238
101 Jayawardene, WP, Lohrmann, D, . Clinical measures of obesity and cumulative cardiometabolic risk in adolescents. Clin Obes. 7(1): 11–21. 2017. 10.1111/cob.12171. KQ2E13b28028931
102 John, CC, Regier, MD, . Long-term pharmacotherapy for elevated low density lipoprotein levels in children: A retrospective analysis. J Clin Lipidol. 10(2): 265–72. 2016. PMID: 27055956. 10.1016/j.jacl.2015.11.012. KQ4E7, KQ5E427055956
103 Jung, L, Courts, E, . Effectiveness of early identification and electronic interventions for teens with risk factors for the development of heart disease and diabetes: Phase II findings. J Am Assoc Nurse Pract. 31(1): 17–23. 2019. 10.1097/JXX.0000000000000087. KQ2E530095669
104 Khalifah, R., Girard, M., & Legault, L. (2014). Regression of Carotid Intima Media Thickness after One Year of Atorvastatin Intervention in Dyslipidemic Obese Teenagers, a Randomized Controlled Pilot Study. J Metabolic Synd, 3(3). 10.4172/2167-0943.1000149. KQ4E10, KQ5E10
105 Karapostolakis, G, Vakaki, M, . The Effect of Long-Term Atorvastatin Therapy on Carotid Intima-Media Thickness of Children With Dyslipidemia. Angiology. 72(4): 322–331. 2021. 10.1177/0003319720975635. KQ4E7, KQ5E1033242982
106 Kasliwal, RR, Bansal, M, . ESSENS dyslipidemia: A placebo-controlled, randomized study of a nutritional supplement containing red yeast rice in subjects with newly diagnosed dyslipidemia. Nutrition. 32(7–8): 767–76. 2016. 10.1016/j.nut.2016.01.012. KQ1E8, KQ2E8, KQ3E8, KQ4E8, KQ5E827143594
107 Kastelein, JJP, Kusters, M, . Efficacy and Safety of Ezetimibe Monotherapy in Children Six to Ten Years of Age with Heterozygous Familial or Non-Familial Hypercholesterolemia. J Am Coll Cardiol. 61: E1466. 2013. KQ4E12, KQ5E12
108 Kelly, AS, Kaizer, AM, . Reaching the Tipping Point: Identification of Thresholds at which Visceral Adipose Tissue May Steeply Increase in Youth. Obesity. 28(1): 139–145. 2020. 10.1002/oby.22679. KQ2E531773904
109 Khoury, M, Manlhiot, C, . Universal screening for cardiovascular disease risk factors in adolescents to identify high-risk families: a population-based cross-sectional study. BMC Pediatr. 16: 11. 2016. 10.1186/s12887-016-0548-3. KQ2E6a26795037
110 Kilpelainen, TO, Bentley, AR, . Multi-ancestry study of blood lipid levels identifies four loci interacting with physical activity. Nat Commun. 10(1): 376. 2019. 10.1038/s41467-018-08008-w. KQ2E2, KQ3E530670697
111 Kim, JS, Chen, Z, . Associations of air pollution, obesity and cardiometabolic health in young adults: The Meta-AIR study. Environ Int. 133(Pt A): 105180. 2019. 10.1016/j.envint.2019.105180. KQ2E531622905
112 Kit, BK, Carroll, MD, . Trends in serum lipids among US youths aged 6 to 19 years, 1988-2010. JAMA. 308(6): 591–600. 2012. PMID: 22871871. 10.1001/jama.2012.9136. KQ2E1322871871
113 Kit, BK, Kukli E, . Prevalence of and trends in dyslipidemia and blood pressure among US children and adolescents, 1999-2012. JAMA Pediatr. 169(3): 272–9. 2015. PMID: 25599372. 10.1001/jamapediatrics.2014.3216. KQ2E1325599372
114 Knickelbine, T, Lui, M, . Familial hypercholesterolemia in a large ambulatory population: Statin use, optimal treatment, and identification for advanced medical therapies. J Clin Lipidol.. 10(5): 1182–7. doi: 10.1016/j.jacl.2016.05.007. Epub 2016 May 14. 2016. KQ2E527678435
115 Koskinen, J, Juonala, M, . Impact of Lipid Measurements in Youth in Addition to Conventional Clinic-Based Risk Factors on Predicting Preclinical Atherosclerosis in Adulthood: International Childhood Cardiovascular Cohort Consortium. Circulation. 137(12): 1246–1255. 2018. 10.1161/CIRCULATIONAHA.117.029726. KQ2E529170152
116 Krause, BJ, Carrasco-Wong, I, . Micro-RNAs Let7e and 126 in Plasma as Markers of Metabolic Dysfunction in 10 to 12 Years Old Children. PLoS ONE [Electronic Resource]. 10(6): e0128140. 2015. 10.1371/journal.pone.0128140. KQ2E6a26046362
117 Kubo, T, Takahashi, K, . Usefulness of non-fasting lipid parameters in children. Journal of Pediatric Endocrinology & Metabolism. 30(1): 77–83. 2017. 10.1515/jpem-2016-0271. KQ2E6a, KQ3E427977407
118 Kuehl, KS, Cockerham, JT, . Effective control of hypercholesterolemia in children with dietary interventions based in pediatric practice. Prev Med. 22(2): 154–66. 1993. PMID: 8483855. 10.1006/pmed.1993.1013. KQ4E4, KQ5E48483855
119 Kuula, L, Pesonen, AK, . Sleep and Lipid Profile During Transition from Childhood to Adolescence. J Pediatr. 177: 173–178.e1. 2016. 10.1016/j.jpeds.2016.06.026. KQ2E6a27453369
120 Kwon, Y, Kim, JH, . Serum YKL-40 Levels Are Associated with the Atherogenic Index of Plasma in Children. Mediators Inflamm. 2020: 8713908. 2020. 10.1155/2020/8713908. KQ2E6a33061832
121 Lai, HL, Ward, R, . Cardiovascular Health of North Carolina Undergraduates. N C Med J. 76(5): 286–92. 2015. KQ2E1326946856
122 Lambert, M, Lupien, PJ, . Treatment of familial hypercholesterolemia in children and adolescents: effect of lovastatin. Canadian Lovastatin in Children Study Group. Pediatrics. 97(5): 619–28. 1996. PMID: 8628597. KQ4E4, KQ5E48628597
123 Langslet, G, Bogsrud, MP, . Long-term follow-up of young adults with familial hypercholesterolemia after participation in clinical trials during childhood. J Clin Lipidol. 9(6): 778–785. 2015. PMID: 26687698. 10.1016/j.jacl.2015.08.008. KQ4E7, KQ5E426687698
124 Langslet, G, Breaz A, . A 3-year study of atorvastatin in children and adolescents with heterozygous familial hypercholesterolemia. J Clin Lipidol. 10(5): 1153–1162 e3. 2016. PMID: 27678432. 10.1016/j.jacl.2016.05.010. KQ4E7, KQ5E427678432
125 Lannon, CM, Earp, J. Parents’ behavior and attitudes toward screening children for high serum cholesterol levels. Pediatrics. 89(6 Pt 2): 1159–63. 1992. PMID: 1594369. KQ1E5, KQ2E13, KQ3E41594369
126 Lauritzen, L, Damsgaard, Ct. Unclear effect of fish oil supplementation on adolescent hypertriglyceridemia. J Pediatr. 166(3): 779–780. 2015. 10.1016/j.jpeds.2014.12.049. KQ4E7, KQ5E7
127 Ledo, DL, Suano-Souza, FI, . Body Mass Index and Cardiovascular Risk Factors in Children and Adolescents with High Birth Weight. Ann Nutr Metab. 72(4): 272–278. 2018. 10.1159/000488595. KQ2E6a29649809
128 Lee, AM, Gurka, MJ, . Trends in Metabolic Syndrome Severity and Lifestyle Factors Among Adolescents. Pediatrics. 137(3): e20153177. 2016. 10.1542/peds.2015-3177. KQ2E13b26908664
129 Lehtovirta, M, Matthews, LA, . Achievement of the Targets of the 20-Year Infancy-Onset Dietary Intervention-Association with Metabolic Profile from Childhood to Adulthood. Nutrients. 13(2): 06. 2021. 10.3390/nu13020533. KQ4E2, KQ5E2
130 Li, KJ, Borresen, EC, . Navy Bean and Rice Bran Intake Alters the Plasma Metabolome of Children at Risk for Cardiovascular Disease. Frontiers in Nutrition. 4: 71. 2017. 10.3389/fnut.2017.00071. KQ4E5, KQ5E529404331
131 Loprinzi, PD, Branscum, A, . Healthy Lifestyle Characteristics and Their Joint Association With Cardiovascular Disease Biomarkers in US Adults. Mayo Clin Proc. 91(4): 432–42. 2016. 10.1016/j.mayocp.2016.01.009. KQ2E6a26906650
132 Macknin, M, Kong, T, . Plant-based, no-added-fat or American Heart Association diets: impact on cardiovascular risk in obese children with hypercholesterolemia and their parents. J Pediatr. 166(4): 953–9.e1-3. 2015. 10.1016/j.jpeds.2014.12.058. KQ4E4, KQ5E425684089
133 Malloy, MJ, Kane, JP, . Familial hypercholesterolemia in children: treatment with p-aminosalicylic acid. Pediatrics. 61(3): 365–72. 1978. PMID: 205828. 10.1542/peds.61.3.365. KQ4E3, KQ5E3205828
134 Manchester, RA, McDuffie, C, . Screening for hypercholesterolemia in college students. J Am Coll Health. 37(4): 149–53. 1989. 10.1080/07448481.1989.9938407. KQ2E132926025
135 Mantyselka, A, Lindi, V, . Associations of Dehydroepiandrosterone Sulfate With Cardiometabolic Risk Factors in Prepubertal Children. J Clin Endocrinol Metab. 103(7): 2592–2600. 2018. 10.1210/jc.2018-00184. KQ2E6a29757399
136 Margolis, KL, Greenspan, LC, . Lipid screening in children and adolescents in community practice: 2007 to 2010. Circ Cardiovasc Qual Outcomes. 7(5): 718–26. 2014. PMID: 25160839. 10.1161/CIRCOUTCOMES.114.000842. KQ2E1025160839
137 Martin, SS, Blaha, MJ, . Very large database of lipids: rationale and design. Clin Cardiol. 36(11): 641–8. 2013. PMID: 24122913. 10.1002/clc.22214. KQ2E224122913
138 Martinez, EE, Forbes, PW, . Census tract based income level and lipid levels in urban pediatric primary care: a retrospective study. BMC Pediatr. 16: 86. 2016. 10.1186/s12887-016-0622-x. KQ2E527391043
139 Martino, F, Puddu, PE, . Low dose chromium-polynicotinate or policosanol is effective in hypercholesterolemic children only in combination with glucomannan. Atherosclerosis. 228(1): 198–202. 2013. PMID: 23453352. 10.1016/j.atherosclerosis.2013.02.005. KQ4E10, KQ5E1023453352
140 Mayor, S. Screening children at immunisation visits can identify familial hypercholesterolaemia. BMJ. 355: i5794. 2016. 10.1136/bmj.i5794. KQ2E6a27789464
141 McCrindle, BW, Helden, E, . A randomized crossover trial of combination pharmacologic therapy in children with familial hyperlipidemia. Pediatr Res. 51(6): 715–21. 2002. PMID: 12032266. 10.1203/00006450-200206000-00009. KQ4E4, KQ5E412032266
142 McCrindle, BW, Helden, E, . A randomized crossover trial of combination pharmacologic therapy in children with familial hyperlipidemia. Pediatr Res. 51(6): 715–21. 2002. PMID: 12032266. 10.1203/00006450-200206000-00009. KQ4E4, KQ5E412032266
143 Merianos, AL, Jandarov, RA, . Tobacco Smoke Exposure Association With Lipid Profiles and Adiposity Among U.S. Adolescents. J Adolesc Health. 62(4): 463–470. 2018. 10.1016/j.jadohealth.2017.10.001. KQ2E529224987
144 Messiah, SE, Vidot, DC, . Obesity and cardiometabolic disease risk factors among US adolescents with disabilities. World J Diabetes. 6(1): 200–7. 2015. 10.4239/wjd.v6.i1.200. KQ2E13a25685291
145 Mihalopoulos, NL, Stipelman, C, . Universal Lipid Screening in 9- to 11-Year-Olds Before and After 2011 Guidelines. Acad Pediatr.. 18(2): 196–199. doi: 10.1016/j.acap.2017.11.006. Epub 2017 Nov 24. 2018. KQ2E1029180296
146 Miller, PE, Martin, SS, . Screening and advanced lipid phenotyping in familial hypercholesterolemia: The Very Large Database of Lipids Study-17 (VLDL-17). J Clin Lipidol. 9(5): 676–83. 2015. PMID: 26350814. 10.1016/j.jacl.2015.06.015. KQ2E226350814
147 Moon, S, Park, JS, . The Cut-off Values of Triglycerides and Glucose Index for Metabolic Syndrome in American and Korean Adolescents. J Korean Med Sci. 32(3): 427–433. 2017. 10.3346/jkms.2017.32.3.427. KQ2E528145645
148 Mosimah, CI, Lilly, C, . Early testing of insulin resistance: a tale of two lipid ratios in a group of 5th graders screened by the Coronary Artery Risk Detection in Appalachian Communities Project (CARDIAC Project). World Journal of Pediatrics. 15(4): 398–404. 2019. 10.1007/s12519-018-00225-z. KQ2E531055781
149 Motkowski, R, Maciejczyk, M, . Effect of Statin Therapy on the Plasma Concentrations of Retinol, Alpha-Tocopherol and Coenzyme Q10 in Children with Familial Hypercholesterolemia. Cardiovascular Drugs & Therapy. 14(): 14. 2020. 10.1007/s10557-020-07091-w. KQ4E7, KQ5E10
150 Nielsen, TRH, Lausten-Thomsen, U, . Dyslipidemia and reference values for fasting plasma lipid concentrations in Danish/North-European White children and adolescents. BMC Pediatr. 17(1): 116. 2017. 10.1186/s12887-017-0868-y. KQ2E6a, KQ3E528454530
151 Nur Zati Iwani, AK, Jalaludin, MY, . TG : HDL-C Ratio Is a Good Marker to Identify Children Affected by Obesity with Increased Cardiometabolic Risk and Insulin Resistance. International Journal of Endocrinology Print. 2019: 8586167. 2019. 10.1155/2019/8586167. KQ2E6a
152 Oliosa, PR, Zaniqueli, D, . Body fat percentage is better than indicators of weight status to identify children and adolescents with unfavorable lipid profile. J Pediatr (Rio J). 95(1): 112–118. 2019. PMID: 29306717. 10.1016/j.jped.2017.11.003. KQ2E6a29306717
153 Patni, N, Li, X, . The prevalence and etiology of extreme hypertriglyceridemia in children: Data from a tertiary children’s hospital. J Clin Lipidol. 12(2): 305–310. 2018. 10.1016/j.jacl.2018.01.003. KQ2E229454679
154 Perdue, AD, Cottrell, LA, . Pediatric metabolic outcome comparisons based on a spectrum of obesity and asthmatic symptoms. J Asthma. 56(4): 388–394. 2019. 10.1080/02770903.2018.1463377. KQ2E6a29676936
155 Pla N, Rodriguez-Borjabad, C, . Lipid and lipoprotein parameters for detection of familial hypercholesterolemia in childhood. The DECOPIN Project. Clinica e Investigacion en Arteriosclerosis. 30(4): 170–178. 2018. 10.1016/j.arteri.2017.12.003. KQ1E9, KQ2E6a, KQ3E929602595
156 Pyles, LA, Lilly, CL, . Cardiometabolic risk factors in siblings from a statewide screening program. J Clin Lipidol. 14(6): 762–771. 2020. 10.1016/j.jacl.2020.09.003. KQ2E533067145
157 Pyles, LA, Lilly, CL, . LDL cholesterol level in fifth-grade schoolchildren associates with stature. J Lipid Res. 58(11): 2197–2201. 2017. 10.1194/jlr.P078816. KQ2E13a28870972
158 Ramaswami U, Cooper J, Humphries SE, . The UK Paediatric Familial Hypercholesterolaemia Register: preliminary data. Arch Dis Child. 2017;102(3):255–60. PMID: 26948823. 10.1136/archdischild-2015-308570. KQ4E7, KQ5E726948823
159 Risk Factor Collaboration NCD. Repositioning of the global epicentre of non-optimal cholesterol. Nature. 582(7810): 73–77. 2020. 10.1038/s41586-020-2338-1. KQ2E6a32494083
160 Rizos, CV, Florentin, M, . Achieving low-density lipoprotein cholesterol targets as assessed by different methods in patients with familial hypercholesterolemia: an analysis from the HELLAS-FH registry. Lipids Health Dis. 19(1): 114. 2020. 10.1186/s12944-020-01289-5. KQ3E4, KQ4E7, KQ5E532466791
161 Rocha, VZ, Santos, RD. Safety of statin treatment in children with familial hypercholesterolemia: Filling the gaps. J Clin Lipidol. 12(1): 12–15. 2018. 10.1016/j.jacl.2017.11.007. KQ4E7, KQ5E729287917
162 Rodriguez-Borjabad, C, Malo, AI, . Efficacy of therapeutic lifestyle changes on lipid profiles assessed by NMR in children with familial and non-familial hypercholesterolemia. Clinica e Investigacion en Arteriosclerosis. 32(2): 49–58. 2020. 10.1016/j.arteri.2019.10.001. KQ4E7, KQ5E532005605
163 Rosenberg, E, Lamping, DL, . Cholesterol screening of children at high risk: behavioural and psychological effects. CMAJ. 156(4): 489–96. 1997. PMID: 9054818. KQ3E49054818
164 Rosenthal, SL, Knauer-Black, S, . The psychological functioning of children with hypercholesterolemia and their families. A preliminary investigation. Clin Pediatr (Phila). 32(3): 135–41. 1993. PMID: 8453828. 10.1177/000992289303200302. KQ3E48453828
165 Ross, SM. Red Yeast Rice: The Efficacy of Monascus Purpureus Yeast for Treatment of Hyperlipidemia a Modifiable Risk Factor of Cardiovascular Disease. Holist Nurs Pract. 31(1): 52–58. 2017. KQ4E2, KQ5E227902524
166 Ruperez, AI, Olza, J, . Cardiovascular risk biomarkers and metabolically unhealthy status in prepubertal children: Comparison of definitions. Nutrition Metabolism & Cardiovascular Diseases. 28(5): 524–530. 2018. 10.1016/j.numecd.2018.02.006. KQ2E6a
167 Safarova, MS, Liu, H, . Rapid identification of familial hypercholesterolemia from electronic health records: The SEARCH study. J Clin Lipidol. 10(5): 1230–9. doi: 10.1016/j.jacl.2016.08.001. Epub 2016 Aug 6.. 2016. KQ2E227678441
168 Salas-Fernandez, A, Maldonado-Hernandez, J, . The 13C-glucose breath test is a valid non-invasive screening tool to identify metabolic syndrome in adolescents. Clin Chem Lab Med. 53(1): 133–8. 2015. 10.1515/cclm-2014-0412. KQ2E6a25153397
169 Sardinha, LB, Santos, DA, . A Comparison between BMI, Waist Circumference, and Waist-To-Height Ratio for Identifying Cardio-Metabolic Risk in Children and Adolescents. PLoS ONE [Electronic Resource]. 11(2): e0149351. 2016. 10.1371/journal.pone.0149351. KQ2E526901828
170 Seremet Kurklu, N, Karatas Torun, N, . Is there a relationship between the dietary inflammatory index and metabolic syndrome among adolescents?. Journal of Pediatric Endocrinology & Metabolism. 33(4): 495–502. 2020. 10.1515/jpem-2019-0409. KQ2E6a32084004
171 Shakya, HB, Domingue, B, . Adolescent gender norms and adult health outcomes in the USA: a prospective cohort study. The Lancet Child & Adolescent Health. 3(8): 529–538. 2019. 10.1016/S2352-4642(19)30160-9. KQ2E231155319
172 Sheng-Fu, Liu, Yin-Ruei, Wang, . A randomized, double-blind clinical study of the effects of Ankascin 568 plus on blood lipid regulation. Journal of food & drug analysis. 26(1): 393–400. 2018. 10.1016/j.jfda.2017.04.006. KQ4E2, KQ5E229389579
173 Shimodaira, M, Hara, M, . The utility of body mass index as an indicator for lipid abnormalities in non-fasting children. Journal of Pediatric Endocrinology & Metabolism. 31(3): 283–288. 2018. 10.1515/jpem-2017-0522. KQ2E6a29373322
174 Shin, SM, Cho, YM, . Supplementation with Cynanchum wilfordii radix extract for 8 weeks lowers serum total cholesterol: A controlled, randomized, double-blind clinical trial. Phytotherapy Research. 34(9): 2313–2322. 2020. 10.1002/ptr.6682. KQ4E2, KQ5E232243009
175 Sinzinger, H, O’Grady, J. Professional athletes suffering from familial hypercholesterolaemia rarely tolerate statin treatment because of muscular problems. Br J Clin Pharmacol. 57(4): 525–8. 2004. PMID: 15025753. 10.1111/j.1365-2125.2003.02044.x. KQ4E4, KQ5E415025753
176 Skovby, F, Micic, S, . Screening for familial hypercholesterolaemia by measurement of apolipoproteins in capillary blood. Arch Dis Child. 66(7): 844–7. 1991. PMID: 1863097. 10.1136/adc.66.7.844. KQ2E6a1863097
177 Smith, AJ, Turner, EL, . A Cost Analysis of Universal versus Targeted Cholesterol Screening in Pediatrics. J Pediatr. 196: 201–207.e2. 2018. 10.1016/j.jpeds.2018.01.027. KQ1E7, KQ2E7, KQ3E729703359
178 Sriram, S, St Sauver, JL, . Temporal trends in lipid testing among children and adolescents: A population based study. Preventive Medicine Reports. 8: 267–272. 2017. 10.1016/j.pmedr.2017.11.001. KQ2E1029204335
179 Stackpole, KMW, Ollberding, NJ, . Omega-3 Use for the Treatment of Hypertriglyceridemia, Low High-Density Lipoprotein Cholesterol Levels, and Nonalcoholic Fatty Liver Disease in Children with Obesity. Childhood Obesity. 17(5): 357–364. 2021. 10.1089/chi.2021.0047. KQ4E2, KQ5E233844928
180 Stavnsbo, M, Resaland, GK, . Reference values for cardiometabolic risk scores in children and adolescents: Suggesting a common standard. Atherosclerosis. 278: 299–306. 2018. 10.1016/j.atherosclerosis.2018.10.003. KQ2E5, KQ3E530477756
181 Stefanutti, C, Lucani, G, . Diet only and diet plus simvastatin in the treatment of heterozygous familial hypercholesterolemia in childhood. Drugs Exp Clin Res. 25(1): 23–8. 1999. PMID: 10337501. KQ4E7, KQ5E1010337501
182 Steiner, MJ, Skinner, AC, . Fasting might not be necessary before lipid screening: a nationally representative cross-sectional study. Pediatrics. 128(3): 463–70. 2011. PMID: 21807697. 10.1542/peds.2011-0844. KQ2E5, KQ3E421807697
183 Strand, MF, Fredriksen, PM, . Reference intervals for serum lipids and prevalence of dyslipidaemia in 6-12-year-old children: The Health Oriented Pedagogical Project (HOPP). Scand J Public Health. 46(21_suppl): 21–27. 2018. 10.1177/1403494818767824. KQ2E6a, KQ3E529754571
184 Sturm, A. C., Truty, R., Callis, T. E., ., (2021). Limited-Variant Screening vs Comprehensive Genetic Testing for Familial Hypercholesterolemia Diagnosis. JAMA Cardiology, 6(8), 902–909. PMID: 34037665. 10.1001/jamacardio.2021.1301. KQ2E234037665
185 Szternel, L, Krintus, M, . Non-fasting lipid profile determination in presumably healthy children: Impact on the assessment of lipid abnormalities. PLoS ONE [Electronic Resource]. 13(6): e0198433. 2018. 10.1371/journal.pone.0198433. KQ2E6a, KQ3E429927973
186 Tavares, Akmm, Ribas, SA, . Effect of phytosterol capsule supplementation associated with the National Cholesterol Education Program Step 2 diet on low-density lipoprotein in children and adolescents with dyslipidemia: A double-blind crossover trial. Nutrition. 82: 111051. 2021. 10.1016/j.nut.2020.111051. KQ4E8, KQ5E833290971
187 Tonstad, S. Familial hypercholesterolaemia: a pilot study of parents’ and children’s concerns. Acta Paediatr. 85(11): 1307–13. 1996. PMID: 8955457. 10.1111/j.1651-2227.1996.tb13916.x. KQ3E48955457
188 Tran, DT, Kupzyk, KA, . Using Cluster Analysis to Identify Subgroups of College Students at Increased Risk for Cardiovascular Disease. J Nurs Meas. 26(3): 470–482. 2018. 10.1891/1061-3749.26.3.470. KQ2E230593573
189 Trico, Dtali, A, . Triglyceride-rich very low-density lipoproteins (VLDL) are independently associated with insulin secretion in a multiethnic cohort of adolescents. Diabetes Obes Metab. 20(12): 2905–2910. 2018. 10.1111/dom.13467. KQ2E1330003666
190 Tsao-Wu, M, Williams, RJ, . Associations between obesity severity and medical comorbidities for children with obesity in low intensity hospital intervention. Obes Res Clin Pract. 13(6): 555–560. 2019. 10.1016/j.orcp.2019.11.001. KQ2E231791923
191 Umer, A, Hamilton, C, . Association between birth weight and childhood cardiovascular disease risk factors in West Virginia. J Dev Orig Health Dis. 11(1): 86–95. 2020. 10.1017/S204017441900045X. KQ2E531412965
192 Urbi EM, de Ferranti, SD. Lipid Screening in Children and Adolescents. JAMA. 316(6): 589–91. 2016. 10.1001/jama.2016.9671. KQ1E7, KQ2E7, KQ3E7, KQ4E7, KQ5E727532913
193 Vickery, AW, Ryan, J, . Increasing the Detection of Familial Hypercholesterolaemia Using General Practice Electronic Databases. Heart Lung Circ. 26(5): 450–454. 2017. 10.1016/j.hlc.2016.09.012. KQ2E6a27889294
194 Voortman, T, van den Hooven, EH, . Protein intake in early childhood and cardiometabolic health at school age: the Generation R Study. Eur J Nutr. 55(6): 2117–27. 2016. 10.1007/s00394-015-1026-7. KQ2E6a26329684
195 Vuorio, A, Strandberg, TE, . Statins and new-onset diabetes mellitus - a risk lacking in familial hypercholesterolaemia. J Intern Med. 279(4): 358–61. 2016. 10.1111/joim.12405. KQ4E7, KQ5E726260225
196 Wald, DS, Bestwick, JP, . Child-Parent Familial Hypercholesterolemia Screening in Primary Care. N Engl J Med. 375(17): 1628–1637. 2016. PMID: 27783906. KQ2E6a, KQ3E427783906
197 Wald, DS, Bestwick, JP. Ethnic access to child-parent screening for familial hypercholesterolaemia. Eur J Prev Cardiol. 26(12): 1341–1342. 2019. 10.1177/2047487319843668. KQ2E6a, KQ3E530971125
198 Wang, X, Xian, T, . Associations between urinary iodine concentration, lipid profile and other cardiometabolic risk factors in adolescents: a cross-sectional, population-based analysis. Br J Nutr. 121(9): 1039–1048. 2019. 10.1017/S0007114518003860. KQ2E13a30739611
199 Webber, P, Marsh, W, . Effectiveness of early identification and electronic interventions for teens with risk factors for the development of heart disease and diabetes. J Am Assoc Nurse Pract. 28(1): 47–53. 2016. 10.1002/2327-6924.12315. KQ2E526465963
200 Williams, CL, Bollella, M, . Soluble fiber enhances the hypocholesterolemic effect of the step I diet in childhood. J Am Coll Nutr. 14(3): 251–7. 1995. 10.1080/07315724.1995.10718504. KQ4E4, KQ5E48586774
201 Wright, CJ, Abbey, EL, . Cardiovascular disease risk profile of NCAA Division III intercollegiate football athletes: a pilot study. Physician & Sportsmedicine. 45(3): 280–285. 2017. 10.1080/00913847.2017.1345288. KQ2E228632483
202 Zachariah, JP, Shittu, T, . Lipid temporal trends in normal-weight youth. Am Heart J. 231: 68–72. 2021. 10.1016/j.ahj.2020.10.050. KQ2E13b33096104
203 Zakhar, J, Amrock, SM, . Passive and Active Tobacco Exposure and Children’s Lipid Profiles. Nicotine Tob Res. 18(5): 982–7. 2016. 10.1093/ntr/ntv158. KQ2E526187391
204 Zavoral, JH, Hannan, P, . The hypolipidemic effect of locust bean gum food products in familial hypercholesterolemic adults and children. Am J Clin Nutr. 38(2): 285–94. 1983. PMID: 6308996. 10.1093/ajcn/38.2.285. KQ4E5, KQ5E56308996
205 Zawacki, A, Dodge, A, . Novel Lipid Thresholds for Screening Predict the Need for Pharmacotherapy. J Pediatr. 202: 220–225.e2. 2018. 10.1016/j.jpeds.2018.07.008. KQ2E5, KQ3E430172432
206 Zhang, Z, Gillespie, C, . Usual intake of added sugars and lipid profiles among the U.S. adolescents: National Health and Nutrition Examination Survey, 2005-2010. J Adolesc Health. 56(3): 352–9. 2015. 10.1016/j.jadohealth.2014.12.001. KQ2E13a25703323
207 Zhao, M, Bovet, P, . Performance of different adiposity measures for predicting cardiovascular risk in adolescents. Sci Rep. 7: 43686. 2017. 10.1038/srep43686. KQ2E13a28262726