# Appendix C Included Studies List

## Included studies List, by Key Question (KQ)

Ancillary publication(s) indented under primary article

### KQs 1 and 3: Included studies for screening benefits and harms

No included studies

### KQ 2: Included studies for screening yield, by condition

#### Familial Hypercholesterolemia

- de Ferranti SD, Rodday AM, Mendelson MM, . Prevalence of Familial Hypercholesterolemia in the 1999 to 2012 United States National Health and Nutrition Examination Surveys (NHANES). Circulation. 2016;133(11):1067–72. 10.1161/CIRCULATIONAHA.115.018791.26976914
- Elliott E, Lilly C, Murphy E, . The Coronary Artery Risk Detection in Appalachian Communities (CARDIAC) Project: An 18 Year Review. Curr Pediatr Rev. 2017;13(4):265–76. PMID: 29345596. 10.2174/1573400514666180117093652 29345596
  - Ritchie SK, Murphy EC, Ice C, . Universal versus targeted blood cholesterol screening among youth: The CARDIAC project. Pediatrics. 2010;126(2):260–5. PMID: 20624798. 10.1542/peds.2009-2546 20624798
- Jackson CL, Keeton JZ, Eason SJ, . Identifying Familial Hypercholesterolemia Using a Blood Donor Screening Program With More Than 1 Million Volunteer Donors. JAMA Cardiol. 2019;4(7):685–9. PMID: 31116347. 10.1001/jamacardio.2019.1518 31116347

#### Multifactorial dyslipidemia

- Bauer KW, Marcus MD, El ghormli L, . Cardio-metabolic risk screening among adolescents: understanding the utility of body mass index, waist circumference and waist to height ratio. Pediatr Obes. 2015;10(5):329–37. PMID: 25515620. 10.1111/ijpo.267 25515620
  - Healthy Study Group, Hirst K, Baranowski T, . HEALTHY study rationale, design and methods: moderating risk of type 2 diabetes in multi-ethnic middle school students. Int J Obes (Lond). 2009;33 Suppl 4:S4–20. PMID: 19623188. 10.1038/ijo.2009.112 19623188
- Elliott E, Lilly C, Murphy E, . The Coronary Artery Risk Detection in Appalachian Communities (CARDIAC) Project: An 18 Year Review. Curr Pediatr Rev. 2017;13(4):265–76. PMID: 29345596. 10.2174/1573400514666180117093652 29345596
  - CARDIAC project. Summary of Results from 1998 to Present: Coronary Artery Risk Detection in Appalachian Communities 21 Year Summary - Fifth Grade 1998-2020. 2020. Accessed 6/20/2022 from https://www.cardiacwv.org/?pid=10
  - Ritchie SK, Murphy EC, Ice C, . Universal versus targeted blood cholesterol screening among youth: The CARDIAC project. Pediatrics. 2010;126(2):260–5. 10.1542/peds.2009-2546. Epub 10 Jul 12.20624798
- Nelson TL, Puccetti N, Luckasen GJ. Healthy hearts: a cross-sectional study of clinical cardiovascular disease risk factors in Northern Colorado school children (1992-2013). BMC Obes. 2015;2:48. PMID: 26664730. 10.1186/s40608-015-0078-9 26664730
- Perak AM, Ning H, Kit BK, . Trends in Levels of Lipids and Apolipoprotein B in US Youths Aged 6 to 19 Years, 1999-2016. JAMA. 2019;321(19):1895–905. PMID: 31112258. 10.1001/jama.2019.4984 31112258
  - Nguyen D, Kit B, Carroll M. Abnormal Cholesterol Among Children and Adolescents in the United States, 2011-2014. NCHS data brief. 2015(228):1–8. PMID: 26727279.26727279
- Reina SA, Llabre MM, Vidot DC, . Metabolic Syndrome in Hispanic Youth: Results from the Hispanic Community Children’s Health Study/Study of Latino Youth. Metab. 2017;15(8):400–6. PMID: 28829223. 10.1089/met.2017.0054 28829223

### KQs 4–5: Included studies for treatment benefit and harms, by condition

#### Familial Hypercholesterolemia

- Amundsen AL, Ose L, Nenseter MS, . Plant sterol ester-enriched spread lowers plasma total and LDL cholesterol in children with familial hypercholesterolemia. Am J Clin Nutr. 2002;76(2):338–44. PMID: 12145004. 10.1093/ajcn/76.2.338 12145004
  - Amundsen AL, Ntanios F, Put N, . Long-term compliance and changes in plasma lipids, plant sterols and carotenoids in children and parents with FH consuming plant sterol ester-enriched spread. Eur J Clin Nutr. 2004;58(12):1612–20. PMID: 15199384. 10.1038/sj.ejcn.1602015 15199384
- Avis HJ, Hutten BA, Gagné C, . Efficacy and safety of rosuvastatin therapy for children with familial hypercholesterolemia. J Am Coll Cardiol 2010. p. 1121–6. PMID: 20223367. 10.1016/j.jacc.2009.10.042 20223367
  - Avis HJ, Hargreaves IP, Ruiter JP, . Rosuvastatin lowers coenzyme Q10 levels, but not mitochondrial adenosine triphosphate synthesis, in children with familial hypercholesterolemia. J Pediatr. 2011;158(3):458–62. PMID: 20884007. 10.1016/j.jpeds.2010.08.015 20884007
- Braamskamp MJ, Stefanutti C, Langslet G, . Efficacy and Safety of Pitavastatin in Children and Adolescents at High Future Cardiovascular Risk. J Pediatr. 2015;167(2):338–43 e5. PMID: 26059337. 10.1016/j.jpeds.2015.05.006 26059337
- Clauss SB, Holmes KW, Hopkins P, . Efficacy and safety of lovastatin therapy in adolescent girls with heterozygous familial hypercholesterolemia. Pediatrics. 2005;116(3):682–8. PMID: 16140708. 10.1542/peds.2004-2090 16140708
- Couture P, Brun LD, Szots F, . Association of specific LDL receptor gene mutations with differential plasma lipoprotein response to simvastatin in young French Canadians with heterozygous familial hypercholesterolemia. Arterioscler Thromb Vasc Biol. 1998;18(6):1007–12. PMID: 9633944. 10.1161/01.atv.18.6.1007 9633944
- de Jongh S, Lilien MR, op’t Roodt J, . Early statin therapy restores endothelial function in children with familial hypercholesterolemia. J Am Coll Cardiol. 2002;40(12):2117–21. PMID: 12505222. 10.1016/s0735-1097(02)02593-7 12505222
- de Jongh S, Ose L, Szamosi T, . Efficacy and safety of statin therapy in children with familial hypercholesterolemia: a randomized, double-blind, placebo-controlled trial with simvastatin. Circulation. 2002;106(17):2231–7. PMID: 12390953. 10.1161/01.cir.0000035247.42888.82 12390953
- de Jongh S, Vissers MN, Rol P, . Plant sterols lower LDL cholesterol without improving endothelial function in prepubertal children with familial hypercholesterolaemia. J Inherit Metab Dis. 2003;26(4):343–51. 10.1023/a:1025155002348 12971422
- Desai NK, Mendelson MM, Baker A, . Hepatotoxicity of Statins as Determined by Serum Alanine Aminotransferase in a Pediatric Cohort With Dyslipidemia. Journal of Pediatric Gastroenterology & Nutrition. 2019;68(2):175–81. PMID: 30334928. 10.1097/MPG.0000000000002174 30334928
- Engler MM, Engler MB, Malloy MJ, . Effect of docosahexaenoic acid on lipoprotein subclasses in hyperlipidemic children (the EARLY study). Am J Cardiol. 2005;95(7):869–71. PMID: 15781019. 10.1016/j.amjcard.2004.12.014 15781019
  - Engler MM, Engler MB, Arterburn LM, . Docosahexaenoic acid supplementation alters plasma phospholipid fatty acid composition in hyperlipidemic children: Results from the Endothelial Assessment of Risk from Lipids in Youth (EARLY) study. Nutr Res. 2004;24(9):721–29. PMID: None. 10.1016/j.nutres.2004.06.004
- Gylling H, Siimes MA, Miettinen TA. Sitostanol ester margarine in dietary treatment of children with familial hypercholesterolemia. J Lipid Res. 1995;36(8):1807–12. PMID: 7595101. 10.1016/S0022-2275(20)41499-3 7595101
- Joyce NR, Zachariah JP, Eaton CB, . Statin Use and the Risk of Type 2 Diabetes Mellitus in Children and Adolescents. Acad Pediatr. 2017;17(5):515–22. PMID: 28232259. 10.1016/j.acap.2017.02.006 28232259
- Kinnear FJ, Lithander FE, Searle A, . Reducing cardiovascular disease risk among families with familial hypercholesterolaemia by improving diet and physical activity: a randomised controlled feasibility trial. BMJ Open. 2020;10(12):e044200. 10.1136/bmjopen-2020-044200
- Knipscheer HC, Boelen CC, Kastelein JJ, . Short-term efficacy and safety of pravastatin in 72 children with familial hypercholesterolemia. Pediatr Res. 1996;39(5):867–71. PMID: 8726243. 10.1203/00006450-199605000-00021 8726243
- Kusters DM, Avis HJ, de Groot E, . Ten-year follow-up after initiation of statin therapy in children with familial hypercholesterolemia. JAMA. 2014;312(10):1055–7. PMID: 25203086. 10.1001/jama.2014.8892 25203086
  - Braamskamp MJ, Kusters DM, Wiegman A, . Gonadal steroids, gonadotropins and DHEAS in young adults with familial hypercholesterolemia who had initiated statin therapy in childhood. Atherosclerosis. 2015;241(2):427–32. PMID: 26079405. 10.1016/j.atherosclerosis.2015.05.034 26079405
- Kusters DM, Caceres M, Coll M, . Efficacy and safety of ezetimibe monotherapy in children with heterozygous familial or nonfamilial hypercholesterolemia. J Pediatr. 2015;166(6):1377–84. PMID: 25841542. 10.1016/j.jpeds.2015.02.043 25841542
- McCrindle BW, Ose L, Marais AD. Efficacy and safety of atorvastatin in children and adolescents with familial hypercholesterolemia or severe hyperlipidemia: a multicenter, randomized, placebo-controlled trial. J Pediatr. 2003;143(1):74–80. PMID: 12915827. 10.1016/S0022-3476(03)00186-0 12915827
- Santos RD, Ruzza A, Hovingh GK, . Evolocumab in Pediatric Heterozygous Familial Hypercholesterolemia. New England Journal of Medicine. 2020;383(14):1317–27. 10.1056/NEJMoa2019910 32865373
- Stein EA, Illingworth DR, Kwiterovich PO, Jr., . Efficacy and safety of lovastatin in adolescent males with heterozygous familial hypercholesterolemia: a randomized controlled trial. JAMA. 1999;281(2):137–44. PMID: 9917116. 10.1001/jama.281.2.137 9917116
- Stein EA, Marais AD, Szamosi T, . Colesevelam hydrochloride: efficacy and safety in pediatric subjects with heterozygous familial hypercholesterolemia. J Pediatr. 2010;156(2):231–6. PMID: 19879596. 10.1016/j.jpeds.2009.08.037 19879596
- Tonstad S, Knudtzon J, Sivertsen M, . Efficacy and safety of cholestyramine therapy in peripubertal and prepubertal children with familial hypercholesterolemia. J Pediatr. 1996;129(1):42–9. PMID: 8757561. 10.1016/s0022-3476(96)70188-9 8757561
- Tonstad S, Sivertsen M, Aksnes L, . Low dose colestipol in adolescents with familial hypercholesterolaemia. Arch Dis Child. 1996;74(2):157–60. PMID: 8660081. 10.1136/adc.74.2.157 8660081
- van der Graaf A, Cuffie-Jackson C, Vissers MN, . Efficacy and safety of coadministration of ezetimibe and simvastatin in adolescents with heterozygous familial hypercholesterolemia. J Am Coll Cardiol. 2008;52(17):1421–9. PMID: 18940534. 10.1016/j.jacc.2008.09.002 18940534
- Wheeler KA, West RJ, Lloyd JK, . Double blind trial of bezafibrate in familial hypercholesterolaemia. Arch Dis Child. 1985;60(1):34–7. PMID: 3882058. 10.1136/adc.60.1.34 3882058
- Wiegman A, Hutten BA, de Groot E, . Efficacy and safety of statin therapy in children with familial hypercholesterolemia: a randomized controlled trial. JAMA. 2004;292(3):331–7. PMID: 15265847. 10.1001/jama.292.3.331 15265847
  - Braamskamp M, Kastelein JJP, Kusters DM, . Statin Initiation During Childhood in Patients With Familial Hypercholesterolemia: Consequences for Cardiovascular Risk. J Am Coll Cardiol. 2016;67(4):455–6. PMID: 26821635. 10.1016/j.jacc.2015.11.021 26821635
  - Braamskamp MJ, Kusters DM, Avis HJ, . Long-term statin treatment in children with familial hypercholesterolemia: more insight into tolerability and adherence. Paediatr Drugs. 2015;17(2):159–66. PMID: 25644328. 10.1007/s40272-014-0116-y 25644328
  - Kusters DM, Avis HJ, de Groot E, . Ten-year follow-up after initiation of statin therapy in children with familial hypercholesterolemia. JAMA. 2014;312(10):1055–7. PMID: 25203086. 10.1001/jama.2014.8892 25203086
  - Luirink IK, Wiegman A, Kusters DM, . 20-Year Follow-up of Statins in Children with Familial Hypercholesterolemia. N Engl J Med. 2019;381(16):1547–56. PMID: 31618540. 10.1056/NEJMoa1816454 31618540
  - Rodenburg J, Vissers MN, Wiegman A, . Statin treatment in children with familial hypercholesterolemia: the younger, the better. Circulation. 2007;116(6):664–8. PMID: 17664376. 10.1161/CIRCULATIONAHA.106.671016 17664376

#### Multifactorial dyslipidemia

- Gidding SS, Prospero C, Hossain J, . A double-blind randomized trial of fish oil to lower triglycerides and improve cardiometabolic risk in adolescents. J Pediatr. 2014;165(3):497–503.e2. PMID: 25008950. 10.1016/j.jpeds.2014.05.039 25008950
- Shannon BM, Tershakovec AM, Martel JK, . Reduction of elevated LDL-cholesterol levels of 4- to 10-year-old children through home-based dietary education. Pediatrics. 1994;94(6 Pt 1):923–7. PMID: 7971012.7971012
  - McHale SM, Tershakovec AM, Corneal DA, . Psychosocial factors in nutrition education for hypercholesterolemic children. Ann Behav Med. 1998;20(3):233–40. PMID: 9989332. 10.1007/bf02884966 9989332
  - Tershakovec AM, Jawad AF, Stallings VA, . Growth of hypercholesterolemic children completing physician-initiated low-fat dietary intervention. J Pediatr. 1998;133(1):28–34. PMID: 9672506. 10.1016/s0022-3476(98)70173-8 9672506
  - Tershakovec AM, Shannon BM, Achterberg CL, . One-year follow-up of nutrition education for hypercholesterolemic children. Am J Public Health. 1998;88(2):258–61. PMID: 9491017. 10.2105/ajph.88.2.258 9491017
- The Writing Group for the DISC Collaborative Research Group. Efficacy and safety of lowering dietary intake of fat and cholesterol in children with elevated low-density lipoprotein cholesterol. The Dietary Intervention Study in Children (DISC). JAMA. 1995;273(18):1429–35. PMID: 7723156. 10.1001/jama.1995.03520420045036 7723156
  - Dorgan JF, Liu L, Barton BA, . Adolescent diet and metabolic syndrome in young women: results of the Dietary Intervention Study in Children (DISC) follow-up study. J Clin Endocrinol Metab. 2011;96(12):E1999–2008. PMID: 21994964. 10.1210/jc.2010-2726 21994964
  - Kwiterovich PO, Jr., Barton BA, McMahon RP, . Effects of diet and sexual maturation on low-density lipoprotein cholesterol during puberty: the Dietary Intervention Study in Children (DISC). Circulation. 1997;96(8):2526–33. PMID: 9355889. 10.1161/01.cir.96.8.2526 9355889
  - Lavigne JV, Brown KM, Gidding S, . A cholesterol-lowering diet does not produce adverse psychological effects in children: three-year results from the dietary intervention study in children. Health Psychol. 1999;18(6):604–13. PMID: 10619534. 10.1037/0278-6133.18.6.604 10619534
  - Obarzanek E, Kimm SY, Barton BA, . Long-term safety and efficacy of a cholesterol-lowering diet in children with elevated low-density lipoprotein cholesterol: seven-year results of the Dietary Intervention Study in Children (DISC). Pediatrics. 2001;107(2):256–64. PMID: 11158455. 10.1542/peds.107.2.256 11158455
  - Obarzanek E, Hunsberger SA, Van Horn L, . Safety of a fat-reduced diet: the Dietary Intervention Study in Children (DISC). Pediatrics. 1997;100(1):51–9. PMID: 9200359. 10.1542/peds.100.1.51 9200359
- Wong H, Chahal N, Manlhiot C, . Flaxseed in pediatric hyperlipidemia: a placebo-controlled, blinded, randomized clinical trial of dietary flaxseed supplementation for children and adolescents with hypercholesterolemia. JAMA Pediatr. 2013;167(8):708–13. PMID: 23733031. 10.1001/jamapediatrics.2013.1442 23733031

#### Multifactorial dyslipidemia/FH

- Del Bo C, Deon V, Abello F, . Eight-week hempseed oil intervention improves the fatty acid composition of erythrocyte phospholipids and the omega-3 index, but does not affect the lipid profile in children and adolescents with primary hyperlipidemia. Food res. 2019;119:469–76. PMID: 30884679. 10.1016/j.foodres.2018.12.045 30884679
- Dennison BA, Levine DM. Randomized, double-blind, placebo-controlled, two-period crossover clinical trial of psyllium fiber in children with hypercholesterolemia. J Pediatr. 1993;123(1):24–9. PMID: 8391569. 10.1016/s0022-3476(05)81532-x 8391569
- Deon V, Del Bo C, Guaraldi F, . Effect of hazelnut on serum lipid profile and fatty acid composition of erythrocyte phospholipids in children and adolescents with primary hyperlipidemia: A randomized controlled trial. Clin Nutr. 2018;37(4):1193–201. 10.1016/j.clnu.2017.05.022 28606702
  - Guaraldi F, Deon V, Del Bo C, . Effect of short-term hazelnut consumption on DNA damage and oxidized LDL in children and adolescents with primary hyperlipidemia: a randomized controlled trial. J nutr biochem. 2018;57:206–11. 10.1016/j.jnutbio.2018.03.012 29753234
- Guardamagna O, Abello F, Cagliero P, . Could dyslipidemic children benefit from glucomannan intake? Nutrition. 2013;29(7–8):1060–5. 10.1016/j.nut.2013.02.010 23759268
- Guardamagna O, Amaretti A, Puddu PE, . Bifidobacteria supplementation: effects on plasma lipid profiles in dyslipidemic children. Nutrition. 2014;30(7–8):831–6. PMID: 24985000. 10.1016/j.nut.2014.01.014 24985000
- Martino F, Martino E, Morrone F, . Effect of dietary supplementation with glucomannan on plasma total cholesterol and low density lipoprotein cholesterol in hypercholesterolemic children. Nutr Metab Cardiovasc Dis. 2005;15(3):174–80. PMID: 15955465. 10.1016/j.numecd.2004.04.004 15955465
- Verduci E, Agostoni C, Radaelli G, . Blood lipids profile in hyperlipidemic children undergoing different dietary long chain polyunsaturated supplementations: a preliminary clinical trial. Int J Food Sci Nutr. 2014;65(3):375–9. 10.3109/09637486.2013.858239 24228803