# Appendix B Literature Flow

Appendix B Figure 1 Literature Flow Diagram