# Appendix A Detailed Methods and Background

## Search Strategies

Original Search 7/13/21

Bridge Search 5/16/22

Sources Searched: database and platform
MEDLINE via Ovid
Cochrane Central Register of Controlled Clinical Trials via Wiley

### Search filters used

RCT filter used is a modified version incorporating:

- Chris Cooper, Jo Varley-Campbell and Patrice Carter, Established search filters may miss studies when identifying randomized controlled trials, Journal of Clinical Epidemiology, 2019-08-01, Volume 112, Pages 12–19 30986533
- Glanville JM, Lefebvre C, Miles JN, Camosso-Stefinovic J. How to identify randomized controlled trials in MEDLINE: ten years on. Journal of the Medical Library Association 2006; 94: 130–136. https://www.ncbi.nlm.nih.gov/pmc/articles/PMC1435857/ 16636704
- Box 6.4.b: Cochrane Highly Sensitive Search Strategy for identifying randomized trials in MEDLINE: sensitivity- and precision-maximizing version (2008 revision); PubMed format, Cochrane Handbook for Systematic Reviews of Interventions, Version 5.1.0, [updated March 2011]

### MEDLINE via Ovid

Ovid MEDLINE(R) ALL <1946 to July 12, 2021>

1. Hyperlipidemias/ 27553
2. Dyslipidemias/ 12641
3. Hypercholesterolemia/ 26292
4. Lipid Metabolism Disorders/ 632
5. Hyperlipoproteinemias/ 2580
6. Hypertriglyceridemia/ 6187
7. Hyperlipoproteinemia Type II/ 7011
8. Hyperlipidemia, Familial Combined/ 756
9. Hypobetalipoproteinemias/ 335
10. Abetalipoproteinemia/ 588
11. hyperlipid?emi$.ti,ab. 32411
12. dyslipid?emi$.ti,ab. 37499
13. hypercholesterol?emi$.ti,ab. 35886
14. hyperlipoprotein?emi$.ti,ab. 4527
15. hypertriglycerid?emia$.ti,ab. 13505
16. dysbetalipoprotein?emi$.ti,ab. 227
17. hypobetalipoproteinemi$.ti,ab. 350
18. abetalipoproteinemi$.ti,ab. 392
19. (familial adj3 apolipoprotein).ti,ab. 258
20. heterozygous fh.ti,ab. 486
21. homozygous fh.ti,ab. 295
22. (lipid$ adj2 disorder$).ti,ab. 5134
23. or/1-22 144578
24. Cholesterol/bl 65354
25. Triglycerides/bl 50807
26. Lipoproteins/bl 20785
27. Cholesterol, HDL/ 29233
28. Cholesterol, LDL/ 28735
29. Apolipoprotein B-100/ 2219
30. Apolipoprotein B 100.ti,ab. 1240
31. apob 100.ti,ab. 1136
32. apo b 100.ti,ab. 615
33. ((high$2 or elevated or abnormal$2 or aberr$) adj3 (cholesterol or lipid$ or LDL$ or lipoprotein$)).ti,ab. 100165
34. ((low or lower$3 or decreas$ or deficien$ or abnormal$2 or aberr$) adj3 HDL$).ti,ab. 18662
35. or/24-34 196986
36. 23 or 35 288584
37. Mass screening/ 108551
38. screen$.ti,ab. 815937
39. ((cholesterol or lipid$ or lipoprotein$ or LDL$ or HDL$) adj3 (detect$ or measur$ or check$ or assess$ or analyz$ or analys$ or test$ or panel$ or profile$)).ti,ab. 84891
40. ((fasting or nonfasting or non-fasting or preprandial or pre-prandial or postprandial or post-prandial) adj (lipid$ or lipoprotein$ or cholesterol)).ti,ab. 2973
41. or/37-40 928086
42. 36 and 41 51528
43. adolescent/ or young adult/ or child/ or child, preschool/ or infant/ or infant, newborn/ 4107555
44. (pediatric$ or paediatric$ or preterm$ or newborn$ or child$ or infant$ or infancy or neonat$ or preschool$ or young$ or early years or adolescen$ or teenage$ or teens or preteen$ or youth or young people or girl$ or boy$ or student$ or juvenile$ or minor or minors or baby or babies or school$ or toddler*).ti,ab. 3584227
45. limit 44 to (“in data review” or in process or publisher or “pubmed not medline”) 427278
46. 43 or 45 4534833
47. 42 and 46 9834
48. limit 47 to (english language and yr=“2015 -Current”) 3205
49. remove duplicates from 48 3195
50. 36 or 39 or 40 333425
51. “Sensitivity and Specificity”/ 356654
52. “Predictive Value of Tests”/ 212465
53. ROC Curve/ 63662
54. Receiver operat$.ti,ab. 96033
55. ROC curve$.ti,ab. 40013
56. sensitivit$.ti,ab. 874685
57. specificit$.ti,ab. 518244
58. predictive value.ti,ab. 99037
59. accuracy.ti,ab. 444776
60. False Negative Reactions/ 18125
61. False Positive Reactions/ 28261
62. Diagnostic Errors/ 38618
63. “Reproducibility of Results”/ 420811
64. Reference Values/ 161821
65. Reference Standards/ 44064
66. Observer Variation/ 43705
67. Psychometrics/ 79809
68. Psychometric$.ti,ab. 50874
69. false positive$.ti,ab. 62169
70. false negative$.ti,ab. 35163
71. miss rate$.ti,ab. 554
72. error rate$.ti,ab. 15558
73. or/51-72 2432428
74. 50 and 73 32787
75. 46 and 74 4949
76. limit 75 to (english language and yr=“2015 -Current”) 1671
77. hydroxymethylglutaryl-coa reductase inhibitors/ or lovastatin/ or pravastatin/ or simvastatin/ 39187
78. Rosuvastatin Calcium/ or Atorvastatin/ 8969
79. hypolipidemic agents/ 15509
80. bezafibrate/ or fenofibrate/ or gemfibrozil/ or niacin/ 15755
81. anticholesteremic agents/ or cholestyramine resin/ or clofenapate/ or clofibrate/ or clofibric acid/ or colestipol/ or Colesevelam Hydrochloride/ 23331
82. probucol/ 1392
83. Ezetimibe/ or Ezetimibe, Simvastatin Drug Combination/ 2275
84. 3-hydroxy-3-methylglutaryl coenzyme A reductase inhibitor$.ti,ab. 1124
85. hydroxymethylglutaryl coa reductase inhibitor$.ti,ab. 95
86. hydroxymethylglutaryl coa inhibitor$.ti,ab. 2
87. hydroxymethylglutaryl coenzyme a reductase.ti,ab. 452
88. hydroxymethylglutaryl coenzyme a inhibitor$.ti,ab. 8
89. hmg coa reductase inhibitor$.ti,ab. 4117
90. hmg coa inhibitor$.ti,ab. 80
91. atorvastatin.ti,ab. 9052
92. fluvastatin.ti,ab. 1916
93. lovastatin.ti,ab. 3891
94. pitavastatin.ti,ab. 965
95. pravastatin.ti,ab. 4130
96. rosuvastatin.ti,ab. 3720
97. simvastatin.ti,ab. 9844
98. hypolipidemic$.ti,ab. 4975
99. anticholesteremic$.ti,ab. 37
100. colestipol.ti,ab. 388
101. colesevelam.ti,ab. 267
102. cholestyramine.ti,ab. 2421
103. Lomitapide.ti,ab. 182
104. antilipidemic.ti,ab. 261
105. statin$.ti,ab. 45838
106. lipid lower$.ti,ab. 15952
107. (treat$ or therap$ or medicat$).ti. 2279609
108. Ezetimibe.ti,ab. 3315
109. (Pcsk9 or alirocumab or evolocumab or kexin type 9).ti,ab. 4190
110. diet, carbohydrate-restricted/ 1743
111. diet, fat-restricted/ 3800
112. diet, mediterranean/ 3987
113. diet, protein-restricted/ 3021
114. diet, reducing/ 11270
115. diet, vegetarian/ 3353
116. caloric restriction/ 6509
117. portion size/ 558
118. Food habits/ 86673
119. Diet Therapy/ 10758
120. Soybean Proteins/ 5023
121. exp Fatty Acids, Omega-3/ 26264
122. Phytosterols/ 3590
123. Dietary Fiber/ 18003
124. Dietary Protein/ 38273
125. Dietary Carbohydrates/ 26325
126. Dietary Fats/ 48594
127. Flax/ or Linseed Oil/ 3159
128. diet$.ti,ab. 597673
129. ((reduce$ or reduction$ or manipulat$ or restrict$) adj3 (fat$ or carbohydrate$ or cholesterol)).ti,ab. 37176
130. low fat.ti,ab. 11788
131. lowfat.ti,ab. 53
132. fiber.ti,ab. 163435
133. omega 3.ti,ab. 16378
134. n 3 polyunsaturated fatty acid$.ti,ab. 4075
135. n 3 fatty acid$.ti,ab. 4925
136. n 3 pufa.ti,ab. 3738
137. (oily fish or fish oil).ti,ab. 9983
138. soy$ protein$.ti,ab. 5079
139. plant stanol$.ti,ab. 244
140. plant sterol$.ti,ab. 1642
141. phytosterol$.ti,ab. 3023
142. esters.ti,ab. 55517
143. (flaxseed or flax seed or linseed).ti,ab. 3865
144. Exercise/ 120559
145. Exercise therapy/ 43645
146. Motor activity/ 98253
147. Physical fitness/ 28251
148. Plyometric Exercise/ 699
149. Physical Conditioning, Human/ 2675
150. Running/ 21021
151. Jogging/ 826
152. Swimming/ 18576
153. Walking/ 35572
154. Resistance training/ 10008
155. (exercise or exercising or exercises).ti,ab. 303724
156. physical fitness.ti,ab. 10175
157. physical conditioning.ti,ab. 840
158. physical activity.ti,ab. 118971
159. (running or jog$ or swim$ or walk$).ti,ab. 228166
160. (lifestyle$ or life style$).ti,ab. 121203
161. Hyperlipidemias/dh, dt, pc, th [Diet Therapy, Drug Therapy, Prevention and Control, Therapy] 10829
162. Dyslipidemias/dh, dt, pc, th 5481
163. Hypercholesterolemia/dh, dt, pc, th 13039
164. Lipid Metabolism Disorders/dh, dt, pc, th 116
165. Hyperlipoproteinemias/dh, dt, pc, th 850
166. Hypertriglyceridemia/dh, dt, pc, th 2038
167. Hyperlipoproteinemia Type II/dh, dt, pc, th 3087
168. Hyperlipidemia, Familial Combined/dh, dt, pc, th 214
169. Hypobetalipoproteinemias/dh, dt, pc, th 19
170. Abetalipoproteinemia/dh, dt, pc, th 76
171. or/77-170 3929484
172. (randomized controlled trial or controlled clinical trial).pt. or clinical trials as topic.sh. or exp Randomized Controlled Trials as Topic/ or (randomized or randomised or placebo or randomly or phase iii or phase 3).ti,ab. or trial.ti. 1503222
173. (RCT or placebo or sham or dummy or single blind$ or double blind$ or allocated or allocation or triple blind$ or treble blind$ or random$).ti,ab. not medline.st. 219633
174. 172 or 173 1579915
175. 36 and 46 and 171 and 174 3049
176. limit 175 to (english language and yr=“2015 -Current”) 949
177. ae.fs. 1817933
178. “Drug-Related Side Effects and Adverse Reactions”/ 33927
179. Mortality/ 47028
180. Morbidity/ 31543
181. Death/ 18279
182. mo.fs. 607424
183. (harm or harms or harmful or harmed).ti,ab. 130556
184. (adverse adj (effect$ or event$ or outcome$)).ti,ab. 367548
185. safety.ti,ab. 559414
186. overtreat$.ti,ab. 5495
187. (death or deaths).ti,ab. 878026
188. drug-induced liver injury/ 30304
189. drug-induced liver injury, chronic/ 408
190. Liver Neoplasms/ci 5534
191. Liver/de 88609
192. Liver failure/ci 649
193. Liver failure, acute/ci 1231
194. (liver adj3 (injur$ or dysfunction$ or failure$)).ti,ab. 64935
195. (Hepatic adj3 (injur$ or dysfunction$ or failure$)).ti,ab. 25836
196. (transaminase adj3 (elevat$ or abnormal$ or dysfunction$)).ti,ab. 2650
197. Liver enzyme$.ti,ab. 17388
198. alanine transaminase.ti,ab. 5576
199. alanine aminotransferase.ti,ab. 28631
200. aspartate transaminase.ti,ab. 4589
201. aspartate aminotransferase.ti,ab. 22827
202. (AST or ALT).ti,ab. 42513
203. Muscular Diseases/ci 2914
204. Myositis/ 8629
205. Myositis.ti,ab. 10130
206. Dermatomyositis/ 8251
207. Dermatomyositis.ti,ab. 9326
208. myositis ossificans.ti,ab. 1437
209. Rhabdomyolysis/ 5735
210. rhabdomyolysis.ti,ab. 8314
211. myotoxicity.ti,ab. 833
212. myopathy.ti,ab. 21049
213. muscle enzyme$.ti,ab. 1853
214. (creatine adj3 (high or elevat$ or abnormal$)).ti,ab. 3591
215. Myalgia/ 2095
216. myalgia.ti,ab. 7666
217. (Pain$3 or rash$2 or (skin adj (disease$1 or disorder$1 or reaction$1)) or pruritus or cellulitis or prurigo or paraesthesia or nose bleeding or headache$1 or migraine$1 or (stomach adj (ache$1 or complain$)) or ((GI or gastrointestinal or gastro-intestinal) adj symptom$1) or nausea or vomit$3 or constipat$ or bloat$ or gas or flatulen$ or gastroenteritis or loose stool$ or diarrh?ea or dyspep$ or (sleep adj (disturbance$ or disorder$)) or (muscle$ adj (ache$ or tender$ or complain$ or spasm$)) or proteinuria or weight gain or decreased appetite or intestinal obstruction or fatigue or pharyngitis or nasopharyngitis or accidental injur$3 or fever or flu syndrome or infection$ or influenza or toothache$1).ti,ab. 3098492
218. or/177-217 6390168
219. 36 and 46 and 171 and 218 4166
220. limit 219 to (english language and yr=“2015 -Current”) 1363
221. 49 or 76 or 176 or 220 5621

### Cochrane Central Register of Controlled Clinical Trials (CENTRAL) via Wiley

Date Run: 14/07/2021 05:08:44

- ID Search Hits
#1 (hyperlipid*emi*:ti,ab,kw or dyslipid*emi*:ti,ab,kw or hypercholesterol*emi*:ti,ab,kw or hyperlipoprotein*emi*:ti,ab,kw or hypertriglycerid*emi*:ti,ab,kw or dysbetalipoprotein*emi*:ti,ab,kw or hypobetalipoproteinemi*:ti,ab,kw or abetalipoproteinemi*:ti,ab,kw) 20646
#2 (familial near/3 apolipoprotein):ti,ab,kw 4
#3 “heterozygous fh”:ti,ab,kw or “homozygous fh”:ti,ab,kw 58
#4 (lipid next disorder*):ti,ab,kw or (lipid near/3 dysfunction*):ti,ab,kw 196
#5 (high* or elevated or abnormal* or aberr*):ti,ab,kw near/3 (cholesterol or lipid* or LDL* or lipoprotein*):ti,ab,kw 16503
#6 (low* or decrease* or deficien* or abnormal* or aberr*):ti,ab,kw near/3 HDL*:ti,ab,kw 3036
#7 (cholesterol or lipid* or lipoprotein* or LDL* or HDL*):ti,ab,kw near/3 (detect* or measure* or check* or assess* or analyz* or analys* or test* or panel* or profile*):ti,ab,kw 18069
#8 (fasting or nonfasting or non-fasting or preprandial or pre-prandial or postprandial or post-prandial):ti,ab,kw next (lipid* or lipoprotein* or cholesterol):ti,ab,kw 1311
#9 #1 or #2 or #3 or #4 or #5 or #6 or #7 or #8 42855
#10 (p*ediatric* or newborn* or child* or infant* or infancy or neonat* or preschool* or “early years” or adolescen* or teenage* or teens or preteen* or youth or “young people” or girl* or boy* or juvenile* or minors or baby or babies or school* or toddler*):ti,ab,kw 316698
#11 #9 and #10 with Publication Year from 2015 to present, in Trials 1631
#12 #11 NOT conference:pt 1392
#13 #12 NOT (clinicaltrials or trialsearch):so 953

Appendix A Table 1 Inclusion and Exclusion Criteria

| Inclusion criteria | Exclusion criteria
Condition | FH or multifactorial dyslipidemia^*^ as defined by the studies
Population | All KQs: Asymptomatic children and adolescents ≤20 years of age at time of screening or treatment initiation; KQs 4,5 (Treatment Benefits and Harms): Treatment studies can have populations identified in any manner (including cascade screening) | KQs 1,2,3: Children and adolescents with any of the following:; - Known dyslipidemia; - Diagnosis associated with secondary dyslipidemia^†^; - Established family history of FH; KQs 4,5:; - Diagnosis associated with secondary dyslipidemia^*^; - Homozygous FH
Interventions | KQs 1,2,3 (Screening Benefits, Yield, and Harms):; - Universal or selective screening using serum lipid panel (fasting or nonfasting lipid measurement, including one or more of the following: TC, LDL-C, HDL-C, non-HDL-C, TG); KQs 4,5 (Treatment Benefits and Harms):; - Lipid-lowering medications; - Behavioral interventions to promote healthy diet and physical activity; - Dietary supplements | KQs 1,2,3:; - Genetic screening alone; - Cascade screening; KQs 4,5 in FH population:; - Apheresis; - Revascularization
Comparators | KQs 1,3 (Screening Benefits and Harms):; - No screening or usual care; KQ 2: No comparator or any confirmatory test; KQs 4,5 (Treatment Benefits and Harms):; - No treatment or usual care
Outcomes | KQs 1,4 (Screening and Treatment Benefits):; - Health outcomes:; ○ MI; ○ Ischemic stroke; ○ CVD mortality; ○ All-cause mortality; - Intermediate outcomes:; ○ Serum lipid concentrations (TC, LDL-C, HDL-C, and non–HDL- C, TG); ○ Atherosclerosis markers (carotid intima-media thickness, calcium score, pathological findings); ○ BMI; - Behavioral Intermediate outcomes:; ○ Physical activity, sedentary behavior, dietary intake (for behavioral counseling interventions only); KQ 2 (Yield):; - Screen positivity; - PPV; KQ3 (Screening Harms):; - Psychosocial effects; - Overdiagnosis; - False positives/negatives; KQ 5 (Treatment Harms): All harms from:; - Lipid-lowering medications (e.g., AEs, long-term safety, overtreatment); - Lifestyle modifications (e.g., nutritional, psychosocial) | KQs 1,4:; - Other serum markers (e.g., apolipoprotein A1, C-reactive protein)
Setting | KQs 1, 3–5: Primary care or referrable from primary care; KQ 2 (Yield): Primary care or referrable from primary care, population-based or community settings | All KQs: Settings not generalizable to primary care
Study design | KQ 1 (Screening Benefits): RCTs, CCTs; KQs 3,5 (Yield, Screening and Treatment Harms): RCTs, CCTs, cohort studies, observational studies; KQ 2 (Yield): Recent large cohorts; KQ 4 (Treatment Benefits): RCTs | KQ4: Comparative effectiveness studies
Country | Studies that take place in countries categorized as “Very High” on the 2019 Human Development Index (as defined by the United Nations Development Programme) (published 2020).; KQ2 (Yield): U.S. only | Primary studies that are conducted in countries that are not categorized as “Very High” on the Human Development Index.
Publication language | English | Any language other than English
Quality rating | Fair – or good-quality studies | Poor quality studies, according to design- specific USPSTF criteria

* Multifactorial dyslipidemia defined as dyslipidemia not due to familial hypercholesterolemia.

† Secondary causes of dyslipidemia include: renal (chronic renal disease, hemolytic uremic syndrome, nephrotic syndrome); infectious (acute viral or bacterial infections, HIV, hepatitis); hepatic (obstructive liver disease, cholestasis, biliary cirrhosis, Alagille syndrome); inflammatory (systemic lupus erythematosus, juvenile rheumatoid arthritis); storage (glycogen storage disease, Gaucher disease, cystine storage disease, Tay-Sachs disease, Niemann-Pick disease); and other (Kawasaki disease, anorexia nervosa, cancer, previous solid organ transplant, progeria, idiopathic hypercalcemia, Klinefelter syndrome, Werner syndrome, polycystic ovary syndrome, type 1 or 2 diabetes).

Abbreviations: AE = adverse event; BMI = body mass index; CCT = controlled clinical trials; CVD = cardiovascular disease; FH = familial hypercholesterolemia; HDL-C = high-density lipoprotein cholesterol; KQs = Key Questions; LDL-C = low-density lipoprotein cholesterol; MI = myocardial infarction; PPV = positive predictive value; RCT = randomized controlled trial; TC = total cholesterol; TG = triglycerides; U.S. = United States; USPSTF = United States Preventive Services Task Force

Appendix A Table 2 Study-Design Quality Rating Criteria

Study Design | Adapted Quality Criteria
Randomized clinical trials,^*^ adapted from U.S. Preventive Services Task Force Manual^1^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; No evidence that the measures, analyses, or subgroup analyses are selectively reported
Nonrandomized studies of interventions,^*^ adapted from ROBINS-I^2^ | Bias arising in the randomization process or due to confounding; - Balance in baseline characteristics; - No baseline confounding; - No time-varying confounding; - No evidence of biased selection of sample; - Start of followup and start of intervention coincide; Bias in classifying interventions; - Participant intervention status is clearly and explicitly defined and measured; - Classification of intervention status is unaffected by knowledge of the outcome or risk of the outcome.; Bias due to departures from intended interventions; - Participants were analyzed as originally allocated/assigned; Bias from missing data; - Outcome data are reasonably complete and comparable between groups; - Confounding variables that are controlled for in analysis are reasonably complete; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; Bias in reporting results selectively; No evidence that the measures, analyses, or subgroup analyses are selectively reported
Cross-sectional studies assessed for Yield (KQ2),^*^ adapted from U.S. Preventive Services Task Force Manual^1^ | Bias arising due to confounding; - Evidence of biased sample selection or does the cohort represent a screening-eligible population; - Differences between those participating in the study and not; Bias from missing data; - Extent of missing data; - Outcomes measured using consistent and appropriate procedures across groups; Bias in reporting results selectively; - Evidence of selective reporting

* Good-quality studies generally meet all quality criteria. Fair-quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor-quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer.

Abbreviations: KQ = Key Question; ROBINS-I = Risk of Bias in Nonrandomised Studies - of Interventions; U.S. = United States

Appendix A Table 3 Treatment Recommendations of Other Organizations in Pediatric Populations

Organization, Year | Year published | Diet and Lifestyle | Medication
American Heart Association Scientific Statement on cardiovascular risk reduction in high-risk pediatric patients^3^ | 2019 | With elevated LDL-C; - If high-risk, consider simultaneous lifestyle modification and treatment with statin; - If moderate risk, consider lifestyle modification for 3 mo (with addition of statin if LDL-C remains elevated); - If at risk, consider lifestyle modification for 6 mo (with addition of statin if LDL-C remains elevated); With elevated triglycerides; - Provide lifestyle change counseling and repeat measures in 1-2 weeks; - If still abnormal, obtain diagnostic evaluation and initiate management; - Base treatment on TG level:; ○ If TG 130-400 mg/dL and non-HDL-C < 145 mg/dL, treat with lifestyle modifications and repeat measures in 3 months and then periodically; ■ If TG 400-999 mg/dL, or triglycerides 130-400 mg/dL and non-HDL-C ≥ 145 mg/dL, treat based on risk category with goal of triglycerides < 150 mg/dL and non-HDL-C < 145 mg/dL If high-risk, consider simultaneous lifestyle modification and pharmacotherapy; ■ If moderate-risk, consider lifestyle modification for 3 months (with addition of pharmacotherapy if goal not reached); ■ If at-risk, consider lifestyle modification for 6 months (with addition of pharmacotherapy if goal not reached); If TG >1,000 mg/dL confirmed with repeat testing, treat simultaneously with lifestyle modifications and omega-3 fatty acids or medications | Recommended for high-risk, moderate-risk, and at-risk children^*^; With elevated LDL-C; - If high risk, LDL-C goal <100 mg/dL; - If mod-risk or at-risk, LDL-C goal <130 mg/dL; - Statins first-line; if goals not met then add cholesterol absorption inhibitors; - For homozygous familial hypercholesterolemia: additional treatments (LDL apheresis and proprotein convertase subtilisin kexin 9 [PCSK9] inhibitors); With elevated triglycerides; - Goal TG < 150 mg/dL and non-HDL < 145 mg/dL; - options include:; ○ fenofibrate with consideration of potential hepatic and muscle effects and drug interactions; ○ omega-3 fatty acids (eicosapentaenoic acid [EPA] and docosahexaenoic acid [DHA]) 4 g/day); ○ statin if elevated non-HDL or apolipoprotein B
American Heart Association Scientific Statement^4^ on Added Sugars and Cardiovascular Disease Risk in Children | 2019 | On added sugars and CVD risk in children:; For all children, limit intake of sugar-sweetened beverages to ≤one 8-ounce beverage/week; For children aged 2-18 years, consume ≤25 g (100 cal or approximately 6 teaspoons) of added sugar per day; For children <2 years old, avoid added sugars | -
AHA/ACC/AACVPR/AAPA/ABC/ACPM/ADA/AGS/APhA/ASPC/NLA/PCNA Guideline on the Management of Blood Cholesterol^5^ | 2018 | In children and adolescents with lipid disorders related to obesity:; - Intensify lifestyle therapy, including moderate caloric restriction and regular aerobic physical activity; In children and adolescent with lipid abnormalities:; lifestyle counseling is beneficial for lowering LDL-C | Children and adolescents >10 years of age with an LDL-C persistently above 190 mg/dL or above 160 mg/dL with a clinical presentation consistent with FH and who do not adequately respond to lifestyle change after 3-6mo: Initiate statin therapy
American Associate of Clinical Endocrinologists^6^ | 2017 | - | Offer pharmacotherapy for children > 10 years old who do not sufficiently respond to lifestyle modifications, especially if:; - LDL-C ≥ 190 mg/dL; - LDL-C ≥ 160 mg/dL and ≥ 2 CV risk factors after vigorous lifestyle intervention; - Family history of premature (before age 55 years) atherosclerotic CVD; - Overweight, obesity, or other elements of insulin resistance syndrome; Further details on followup and monitoring are provided
National Heart, Lung, and Blood Institute Expert Panel on Integrated Guidelines for Cardiovascular Health and Risk Reduction in Children and Adolescents^7^ | 2012 | Recommended first step: Cardiovascular Health Integrated Lifestyle Diet (CHILD 1 Diet);^†^ but if triglyceride levels ≥ 500 mg/dL or low-density lipoprotein cholesterol (LDL-C) ≥ 250 mg/dL child should also be referred immediately to lipid specialist.; If CHILD 1 diet^†^ and lifestyle mgmt. do not achieve therapeutic goals after 3 months, lipid parameter-specific dietary changes recommended; Consider CHILD 2-LDL diet^†^ for elevated LDL cholesterol in pts aged 2-21 years; Age 11-21 years with elevated LDL-C levels (using average of 2 measures 2 weeks to 3 months apart):; - Detailed family history and risk factor assessment required before starting drug therapy; - If LDL-C ≥ 250 mg/dL consult lipid specialist; - If LDL-C 130mg/dL to <250 mg/dL, or HDL-C ≥ 145mf/dL; ○ Refer to dietitian for medical nutrition therapy with CHILD 1 diet, then CHILD 2-LDL diet for 6 months, then repeat fasting lipid profile; ○ If LDL-C <130mg/dL, continue CHILD 2-LDL diet and reevaluate in 12 months; ○ If LDL-C 130-189mg/dL, negative family history, and no other risk factors or risk conditions; ■ Continue CHILD 2-LDL diet and reevaluate every 6 months; ■ Drug therapy not generally indicated, but treatment with bile acid sequestrants might be considered in consultation with lipid specialist; Consider CHILD 2-triglyceride (TG) diet^†^ for elevated TGs (or non-high-density lipoprotein cholesterol) for pts aged 2-21 years; Age 11-21 years with elevated TG levels (using average of 2 measure 2 weeks to 3 months apart):; - Detailed family history and risk factor assessment required before starting drug therapy; - In child with obesity, nutrition therapy should include calorie restriction and increased activity beyond that recommended for all children; - If TG ≥100 mg/dL in child <10 years old or ≥ 130 md/dL in child aged 10-19 years but <500 mg/dL; ○ Refer to dietitian for medical nutrition therapy with CHILD 1 diet, then CHILD 2-TG diet for 6 months, then repeat fasting lipid profile; ■ If TG < 100 mg/dL in child < 10 years old or < 130 mg/dL in child aged 10-19 years, continue CHILD 2-TG diet and reevaluate every 6-12 months; ■ If TG > 100 mg/dL in child < 10 years old or > 130 mg/dL in child aged 10-19 years, reconsult dietitian for intensified CHILD 2-TG counseling; ■ If TG 200-499 mg/dL and non-HDL-C ≥ 145 mg/dL, consider fish oil and/or consultation with lipid specialist; ■ If TG ≥500 mg/dL, consult lipid specialist; ○ If average fasting TG levels ≥500 mg/dL OR any single TG level ≥1000 mg/dL related to primary hypertriglyceridemia, start CHILD 2-TG diet (and consider fish oil, fibrate, or niacin to prevent pancreatitis); Physical activity recommendations: 1 hour/day of moderate-to-vigorous physical activity with vigorous physical activity 3 days/week and limiting leisure screen time to < 2 hours/day | Age 0-10 years:; - Pharmacologic treatment (under care of lipid specialist) limited to children with:; ○ Homozygous FH with LDL-C ≥ 400 mg/dL; ○ Primary hypertriglyceridemia with TGs ≥ 500 mg/dL; ○ High-risk condition; ○ Evidence CVD; ○ Postcardiac transplantation; - Statins may be considered in children aged 8-9 years with average LCL-C ≥ 190 mg/dL after CHILD 2-LDL diet if positive family history, ≥ 1 high-level risk factor, or ≥ 2 moderate-level risk factors; Age 11-21 years with elevated LDL-C levels (using average of 2 measures 2 weeks to 3 months apart): Consider starting statin therapy if; ■ LDL-C 130-159 mg/dL and either ≥ 2 high-level risk factors or 1 high-level and ≥ 2; ■ LDL-C 160-189 mg/dL and any of positive family history, ≥ 1 high-level risk factors, or ≥ 2 moderate-level risk factors; ■ LDL-C ≥ 190 mg/dL; Children > 10 years old with non-HDL-C ≥145 mg/dL after LDL-C goal achieved may be considered (with lipid specialist) for additional treatment with statins, fibrates, or niacin; Children on statin therapy should be counseled and carefully monitored
National Lipid Association^8^ | 2011 | - | Both children and adults with LDL cholesterol ≥190 mg/dL [or non-HDL-C ≥220 mg/dL] after lifestyle changes will require drug therapy; Statins are preferred for initial pharmacologic treatment in children after initiation of diet and physical activity management.; Consideration should be given to starting treatment at ≥8. In special cases, such as those with homozygous FH, treatment might need to initiated at earlier ages.; Further details on management issues in pediatrics are provided

* High risk = homozygous FH, type-2 diabetes, end-stage renal disease, type-1 diabetes, Kawasaki disease with persistent aneurysms, solid-organ transplant vasculopathy, or childhood cancer survivor (stem cell recipient).

Moderate risk = severe obesity (BMI >95th percentile), heterozygous FH, confirmed hypertension, coarctation, Lp(a), predialysis chronic kidney disease, AS, or childhood cancer survivor (chest radiation)

At risk = obesity, insulin resistance with comorbidities (dyslipidemia, nonalcoholic fatty liver disease, polycystic ovary syndrome), white-coat hypertension, hypertrophic cardiomyopathy and other cardiomyopathies, pulmonary hypertension, chronic inflammatory conditions (juvenile idiopathic arthritis, systemic lupus erythematosus, inflammatory bowel disease, HIV), s/p coronary (cardiotoxic chemotherapy only), Kawasaki disease with regressed aneurysms (zMax ≥5).

† Full details of CHILD 1 and CHILD-2 diets can be found in the full recommendation report.

Abbreviations: AACVPR = American Association of Cardiovascular and Pulmonary Rehabilitation; AAPA = American Academy of Physician Assistants; ABC = Association of Black Cardiologists; ACC = American College of Cardiology; ACPM = American College of Preventive Medicine; ADA = American Diabetes Association; AGS = American Geriatrics Society; AHA = American Heart Association; APhA = American Pharmacists Association; ASPC = American Society for Preventive Cardiology; ASCVD = atherosclerotic cardiovascular disease; BMI = body mass index; CHD = coronary heart disease; ; CV = cardiovascular; CVD = cardiovascular disease; DNA = deoxyribonucleic acid; FH = familial hypercholesterolemia; g/day = grams per day; HDL-C = high=density lipoprotein cholesterol; LDL-C = low-density lipoprotein cholesterol; mg/dL = milligrams per deciliter; NLA = National Lipid Association; PCNA = Preventive Cardiovascular Nurses Association; PCSK9 = proprotein convertase subtilisin/kexin type 9; TG = triglycerides

Appendix A Table 4 NCEP Step I and II Dietary Therapy of High Cholesterol^9^

Nutrient | Step I Diet, recommended intake | Step II Diet, recommended intake
Total Fat | <30% of total calories | <30% of total calories
- Saturated fatty acids | <10% of total calories | <7% of total calories
- Polyunsaturated fatty acids | Up to 10% of total calories | Up to 10% of total calories
- Monounsaturated fatty acids | 10-15% of total calories | 10-15% of total calories
Carbohydrates | 50-60% of total calories | 50-60% of total calories
Protein | 10-20% of total calories | 10-20% of total calories
Cholesterol | <300 mg/d | <200 mg/d
Total calories | To achieve and maintain desirable weight | To achieve and maintain desirable weight

Abbreviations: mg/d = milligrams per day; NCEP = National Cholesterol Education Program

Appendix A Table 5 FDA-Approved Drugs in Pediatric Populations^10–13^

Drug Class | Drug (No of included studies) | Ages, years | Indication | Dose (mg/day)
Statins | Atorvastatin (1) | 10-17 | Heterozygous FH | 10-20
Statins | Fluvastatin (0) | 10-16 | Heterozygous FH | 20-80
Statins | Lovastatin (2) | 10-17 | Heterozygous FH | 10-40
Statins | Pitavastatin (1) | ≥8 | Heterozygous FH | 2-4
Statins | Pravastatin (2) | 8-18 | Heterozygous FH | 20-40
Statins | Rosuvastatin (1) | 8-17 | Heterozygous FH | 5-20
Statins | Simvastatin (3) | 10-17 | Heterozygous FH | 10-40
Bile acid sequestrants | Colesevelam (1) | 10-17 | Heterozygous FH | 1.875-3.75 g/day
Ezetimibe | Ezetimibe (1) | ≥10 | Heterozygous FH | 10
PCSK9 Inhibitor | Evolocumab (1) | ≥10 | Heterozygous FH | 420 mg in monthly injections

Abbreviations: FDA = U.S. Food & Drug Administration; FH= familial hypercholesterolemia; g = gram; mg/dL = milligram per deciliter; PCSK9 = proprotein convertase subtilisin/kexin type 9