# References

1 Owens DK, Davidson KW, Krist AH, Preexposure prophylaxis for the prevention of HIV infection: U.S. Preventive Services Task Force recommendation statement. JAMA. 2019 Jun 11;321(22):2203–13. doi: 10.1001/jama.2019.6390. PMID: 31184747.31184747
2 Chou R, Evans C, Hoverman A, Preexposure prophylaxis for the prevention of HIV infection: Evidence report and systematic review for the U.S. Preventive Services Task Force. JAMA. 2019 06 11;321(22):2214–30. doi: 10.1001/jama.2019.2591. PMID: 31184746.31184746
3 Centers for Disease Control and Prevention. 1993 Revised classification system for HIV infection and expanded surveillance case definition for AIDS among adolescents and adults. MMWR Recomm Rep. 1992 December 18;41(RR-17) PMID: 1361652.1361652
4 Centers for Disease Control and Prevention. HIV-2 Infection Surveillance- United States, 1987-2009. 2011. https://www.cdc.gov/mmwr/preview/mmwrhtml/mm6029a3.htm. Accessed December 8, 2017.
5 Centers for Disease Control and Prevention NCfHA, Viral Hepatitis, STD, and TB Prevention, Division of HIV/AIDS Prevention. HIV Infection, Stage 3 (AIDS). 2019. https://www.cdc.gov/hiv/pdf/library/slidesets/cdc-hiv-infection-stage-3-2019.pdf. Accessed September 14, 2021.
6 Centers for Disease Control and Prevention. HIV Surveillance Report: Diagnoses of HIV Infection in the United States and Dependent Areas; 2019; vol 32; published May 2021. 2019. https://www.cdc.gov/hiv/library/reports/hiv-surveillance/vol-32/index.html Accessed June 8, 2023.
7 Centers for Disease Control and Prevention. HIV in the United States. 2011. http://www.cdc.gov/hiv/resources/factsheets/us.htm. Accessed December 8, 2017.
8 Centers for Disease Control and Prevention. HIV surveillance - United States, 1981-2008. MMWR. 2011;60(21):689–93. PMID: 21637182.21637182
9 Campsmith ML, Rhodes PH, Hall I, Undiagnosed HIV prevalence among adults and adolescents in the United States at the end of 2006. J Acquir Immune Defic Syndr. 2010;53:619–24. PMID: 19838124.19838124
10 Centers for Disease Control and Prevention. HIV Surveillance Report, 2020. Published 2022. https://www.cdc.gov/hiv/library/reports/hiv-surveillance.html. Accessed June 2, 2022.
11 Prejean J, Song R, Hernandez A, Estimated HIV incidence in the United States, 2006-2009. PLoS One. 2011 Aug 3;6(8):e17502. doi:10.1371/journal.pone.0017502. PMID: 21826193.21826193
12 Centers for Disease Control and Prevention. Special Report: HIV Infection, Risk, Prevention, and Testing Behaviors Among Transgender Women. National HIV Behavioral Surveillance 7 U.S. Cities, 2019-2020. HIV Surveillance Report No. 27.. 2021. https://www.cdc.gov/hiv/pdf/library/reports/surveillance/cdc-hiv-surveillance-special-report-number-27.pdf. Accessed October 25, 2021.
13 Centers for Disease Control and Prevention. HIV Treatment as Prevention. 2021. https://www.cdc.gov/hiv/risk/art/index.html. Accessed September 15, 2021.
14 Quinn TC, Wawer MJ, Sewankambo NK, Viral load and heterosexual transmission of human immunodeficiency virus type 1. N Engl J Med. 2000;342(13):921–9. PMID: 10738050.10738050
15 Gray RH, Wawer MJ, Brookmeyer R, Probability of HIV-1 transmission per coital act in monogamous, heterosexual, HIV-1-discordant couples in Rakai, Uganda. Lancet. 2001;357(9263):1149–53. doi: 10.1016/s0140-6736(00)04331-2. PMID: 11323041.11323041
16 Doherty MC, Garfein RS, Monterroso E, Correlates of HIV infection among young adult short-term injection drug users. AIDS. 2000 Apr 14;14(6):717–26. PMID: 10807195.10807195
17 Kahn JO, Walker BD. Acute human immunodeficiency virus type 1 infection. N Engl J Med. 1998;339(1):33–9. doi: 10.1056/NEJM199807023390107. PMID: 9647878.9647878
18 Schacker T, Collier AC, Hughes J, Clinical and epidemiologic features of primary HIV infection. Ann Intern Med. 1996 Aug 15;125(4):257–64. PMID: 8678387.8678387
19 Vanhems P, Allard R, Cooper DA, Acute human immunodeficiency virus type 1 disease as a mononucleosis-like illness: is the diagnosis too restrictive? Clin Infect Dis. 1997 May 1, 1997;24(5):965–70. doi: 10.1093/clinids/24.5.965. PMID: 9142802.9142802
20 Daar ES, Moudgil T, Meyer RD, Transient high levels of viremia in patients with primary human immunodeficiency virus type 1 infection. N Engl J Med. 1991;324(14):961–4. doi: 10.1056/NEJM199104043241405. PMID: 1823118.1823118
21 Henrard DR, Phillips JF, Muenz LR, Natural history of HIV-1 cell-free viremia. JAMA. 1995 Aug 16;274(7):554–8. PMID: 7629984.7629984
22 Ho DD, Neumann AU, Perelson AS, Rapid turnover of plasma virions and CD4 lymphocytes in HIV-1 infection. Nature. 1995 Jan 12;373(6510):123–6. doi: 10.1038/373123a0. PMID: 7816094.7816094
23 Schacker TW, Hughes JP, Shea T, Biological and virologic characteristics of primary HIV infection. Ann Intern Med. 1998 Apr 15;128(8):613–20. PMID: 9537934.9537934
24 Touloumi G, Pantazis N, Babiker AG, Differences in HIV RNA levels before the initiation of antiretroviral therapy among 1864 individuals with known HIV-1 seroconversion dates. AIDS. 2004 Aug 20;18(12):1697–705. PMID: 15280781.15280781
25 Wei X, Ghosh SK, Taylor ME, Viral dynamics in human immunodeficiency virus type 1 infection. Nature. 1995 Jan 12;373(6510):117–22. doi: 10.1038/373117a0. PMID: 7529365.7529365
26 Collaborative Group on AIDS Incubation and HIV Survival including the CASCADE EU Concerted Action. Time from HIV-1 seroconversion to AIDS and death before widespread use of highly-active antiretroviral therapy: a collaborative re-analysis. Lancet. 2000 Apr 1;355(9210):1131–7. PMID: 10791375.10791375
27 Koblin B, van Benthem B, Buchbinder S, Long-term survival after infection with human immunodeficiency virus type 1 (HIV-1) among homosexual men in hepatitis B vaccine trial cohorts in Amsterdam, New York City, and San Francisco, 1978-1995. Am J Epidemiol. 1999 November 15, 1999;150(10):1026–30. PMID: 10568617.10568617
28 Stein DS, Korvick JA, Vermund SH. CD4+ lymphocyte cell enumeration for prediction of clinical course of human immunodeficiency virus disease: a review. J Infect Dis. 1992 Feb;165(2):352–63. PMID: 1346152.1346152
29 Kaslow RA, Phair JP, Friedman HB, Infection with the human immunodeficiency virus: clinical manifestations and their relationship to immune deficiency. A report from the Multicenter AIDS Cohort Study. Ann Intern Med. 1987 Oct;107(4):474–80. PMID: 2957944.2957944
30 Phillips A, Gazzard B, Gilson R, Rate of AIDS diseases or death in HIV-infected antiretroviral therapy-naive individuals with high CD4 cell count. AIDS. 2007;21(13):1717 – 21. PMID: 17690569.17690569
31 Egger M, May M, Chene G, Prognosis of HIV-1-infected patients starting highly active antiretroviral therapy: a collaborative analysis of prospective studies. Lancet. 2002 Jul 13;360(9327):119–29. PMID: 12126821.12126821
32 Phillips A, Pezzotti P. Short-term risk of AIDS according to current CD4 cell count and viral load in antiretroviral drug-naive individuals and those treated in the monotherapy era. AIDS. 2004 Jan 2;18(1):51–8. PMID: 15090829.15090829
33 Phillips AN, Lee CA, Elford J, Serial CD4 lymphocyte counts and development of AIDS. Lancet. 1991 Feb 16;337(8738):389–92. PMID: 1671424.1671424
34 Mellors JW, Kingsley LA, Rinaldo CR Jr., Quantitation of HIV-1 RNA in plasma predicts outcome after seroconversion. Ann Intern Med. 1995 Apr 15;122(8):573–9. PMID: 7887550.7887550
35 Mellors JW, Munoz A, Giorgi JV, Plasma viral load and CD4+ lymphocytes as prognostic markers of HIV-1 infection. Ann Intern Med. 1997 Jun 15;126(12):946–54. PMID: 9182471.9182471
36 Phair JP, Mellors JW, Detels R, Virologic and immunologic values allowing safe deferral of antiretroviral therapy. AIDS. 2002 Dec 6;16(18):2455–9. PMID: 12461420.12461420
37 Babiker AG, Peto T, Porter K, Age as a determinant of survival in HIV infection. J Clin Epidemiol. 2001 Dec;54 Suppl 1:S16–21. PMID: 11750205.11750205
38 Vella S, Giuliano M, Floridia M, Effect of sex, age and transmission category on the progression to AIDS and survival of zidovudine-treated symptomatic patients. AIDS. 1995 Jan;9(1):51–6. PMID: 7893441.7893441
39 Pedersen C, Lindhardt BO, Jensen BL, Clinical course of primary HIV infection: consequences for subsequent course of infection. BMJ. 1989;299(6692):154–7. PMID: 2569901.2569901
40 de Roda Husman A-M, Koot M, Cornelissen M, Association between CCR5 genotype and the clinical course of HIV-1 Infection. Ann Intern Med. 1997 November 15, 1997;127(10):882–90. PMID: 9382366.9382366
41 Ioannidis JP, Rosenberg PS, Goedert JJ, Effects of CCR5-Delta32, CCR2-64I, and SDF-1 3'A alleles on HIV-1 disease progression: an international meta-analysis of individual-patient data. Ann Intern Med. 2001 Nov 6;135(9):782–95. PMID: 11694103.11694103
42 Lathey JL, Tierney C, Chang SY, Associations of CCR5, CCR2, and stromal cell-derived factor 1 genotypes with human immunodeficiency virus disease progression in patients receiving nucleoside therapy. J Infect Dis. 2001 Dec 1;184(11):1402–11. doi: 10.1086/324427. PMID: 11709782.11709782
43 Marmor M, Sheppard HW, Donnell D, Homozygous and heterozygous CCR5-Delta32 genotypes are associated with resistance to HIV infection. J Acquir Immune Defic Syndr. 2001 Aug 15;27(5):472–81. PMID: 11511825.11511825
44 Nolan D, Gaudieri S, John M, Impact of host genetics on HIV disease progression and treatment: new conflicts on an ancient battleground. AIDS. 2004 Jun 18;18(9):1231–40. PMID: 15362655.15362655
45 Baggaley RF, Boily MC, White RG, Risk of HIV-1 transmission for parenteral exposure and blood transfusion: a systematic review and meta-analysis. AIDS. 2006 Apr 4;20(6):805–12. doi: 10.1097/01.aids.0000218543.46963.6d. PMID: 16549963.16549963
46 Moore R. Epidemiology of HIV infection in the United States: implications for linkage to care. Clin Infect Dis. 2011;52(Suppl 2):S208–S13. doi: 10.1093/cid/ciq044. PMID: 21342909.21342909
47 Baral SD, Poteat T, Stromdahl S, Worldwide burden of HIV in transgender women: a systematic review and meta-analysis. Lancet Infect Dis. 2013 Mar;13(3):214–22. doi: 10.1016/s1473-3099(12)70315-8. PMID: 23260128.23260128
48 Chou R, Huffman LH, Fu R, Screening for HIV: A review of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2005 Jul 5;143(1):55–73. PMID: 15998755.15998755
49 Owens DK, Davidson KW, Krist AH, Screening for HIV infection: U.S. Preventive Services Task Force recommendation statement. JAMA. 2019 Jun 18;321(23):2326–36. doi: 10.1001/jama.2019.6587. PMID: 31184701.31184701
50 Cohen MS, Chen YQ, McCauley M, Prevention of HIV-1 infection with early antiretroviral therapy. N Engl J Med. 2011 Aug 11;365(6):493–505. doi: 10.1056/NEJMoa1105243. PMID: 21767103.21767103
51 Baeten JM, Donnell D, Ndase P, Antiretroviral prophylaxis for HIV-1 prevention in heterosexual men and women. N Engl J Med. 2012 Aug 2;367(5):399–410. doi: 10.1056/NEJMoa1108524. PMID: 22784037.22784037
52 Grohskopf LA, Chillag KL, Gvetadze R, Randomized trial of clinical safety of daily oral tenofovir disoproxil fumarate among HIV-uninfected men who have sex with men in the United States. J Acquir Immune Defic Syndr. 2013 Sep 1;64(1):79–86. doi: 10.1097/QAI.0b013e31828ece33. PMID: 23466649.23466649
53 Choopanya K, Martin M, Suntharasamai P, Antiretroviral prophylaxis for HIV infection in injecting drug users in Bangkok, Thailand (the Bangkok tenofovir study): a randomised, double-blind, placebo-controlled phase 3 trial. Lancet. 2013 Jun 15;381(9883):2083–90. doi: 10.1016/S0140-6736(13)61127-7. PMID: 23769234.23769234
54 Marrazzo JM, Ramjee G, Richardson BA, Tenofovir-based preexposure prophylaxis for HIV infection among African women. N Engl J Med. 2015 Feb 5;372(6):509–18. doi: 10.1056/NEJMoa1402269. PMID: 25651245.25651245
55 Peterson L, Taylor D, Roddy R, Tenofovir disoproxil fumarate for prevention of HIV infection in women: a phase 2, double-blind, randomized, placebo-controlled trial. PLoS Clin Trials. 2007;2(5):e27. doi: 10.1371/journal.pctr.0020027. PMID: 17525796.17525796
56 Wilton J, Senn H, Sharma M, Pre-exposure prophylaxis for sexually-acquired HIV risk management: a review. HIV AIDS (Auckl). 2015;7:125–36. doi: 10.2147/HIV.S50025. PMID: 25987851.25987851
57 Centers for Disease Control and Prevention. Updated Guidelines for Antiretroviral Postexposure Prophylaxis After Sexual, Injection Drug Use, or Other Nonoccupational Exposure to HIV- United States, 2016 U.S. Department of Health and Human Services. 2016. https://www.cdc.gov/hiv/pdf/programresources/cdc-hiv-npep-guidelines.pdf Accessed November 28, 2017.
58 Fauci AS, Redfield RR, Sigounas G, Ending the HIV epidemic: a plan for the United States. JAMA. 2019 Mar 5;321(9):844–5. doi: 10.1001/jama.2019.1343. PMID: 30730529.30730529
59 Krakower DS, Mayer KH. Pre-exposure prophylaxis to prevent HIV infection: current status, future opportunities and challenges. Drugs. 2015 Feb;75(3):243–51. doi: 10.1007/s40265-015-0355-4. PMID: 25673022.25673022
60 FDA Approves First Drug For Reducing the Risk of Sexually Acquired HIV Infection. FDA News Release. Silver Spring, MD: U.S. Food and Drug Administration; 2012. https://wayback.archive-it.org/7993/20170112032741/http://www.fda.gov/NewsEvents/Newsroom/PressAnnouncements/ucm312210.htm. Accessed December 8, 2017.
61 Department of Health and Human Services. Supplement Approval. 2018. https://www.accessdata.fda.gov/drugsatfda_docs/appletter/2018/021752Orig1s055ltr.pdf Accessed August 3, 2018.
62 U.S. Food & Drug Administration. DESCOVY(R) (emtricitabine and tenofovir alafenamide) tablets, for oral use Initial U.S. Approval: 2015. 2019. https://www.accessdata.fda.gov/drugsatfda_docs/label/2019/208215s011lbl.pdf Accessed September 14, 2021.
63 Gibson AK, Shah BM, Nambiar PH, Tenofovir alafenamide: A review of its use in the treatment of HIV-1 infection. Ann Pharmacother. 2016 Nov;50(11):942–52. doi: 10.1177/1060028016660812. PMID: 27465879.27465879
64 Amico KR, Stirratt MJ. Adherence to preexposure prophylaxis: current, emerging, and anticipated bases of evidence. Clin Infect Dis. 2014 Jul;59 Suppl 1:S55–60. doi: 10.1093/cid/ciu266. PMID: 24926036.24926036
65 Bavinton BR, Grulich AE. HIV pre-exposure prophylaxis: scaling up for impact now and in the future. Lancet Public Health. 2021 Jul;6(7):e528–e33. doi: 10.1016/s2468-2667(21)00112-2. PMID: 34087117.34087117
66 Molina JM, Capitant C, Spire B, On-demand preexposure prophylaxis in men at high risk for HIV-1 Infection. N Engl J Med. 2015 Dec 3;373(23):2237–46. doi: 10.1056/NEJMoa1506273. PMID: 26624850.26624850
67 Mutua G, Sanders E, Mugo P, Safety and adherence to intermittent pre-exposure prophylaxis (PrEP) for HIV-1 in African men who have sex with men and female sex workers. PLoS One. 2012;7(4):e33103. doi: 10.1371/journal.pone.0033103. PMID: 22511916.22511916
68 Kibengo FM, Ruzagira E, Katende D, Safety, adherence and acceptability of intermittent tenofovir/emtricitabine as HIV pre-exposure prophylaxis (PrEP) among HIV-uninfected Ugandan volunteers living in HIV-serodiscordant relationships: a randomized, clinical trial. PLoS One. 2013;8(9):e74314. doi: 10.1371/journal.pone.0074314. PMID: 24086333.24086333
69 Jackson A, McGowan I. Long-acting rilpivirine for HIV prevention. Curr Opin HIV AIDS. 2015 Jul;10(4):253–7. doi: 10.1097/COH.0000000000000160. PMID: 26049950.26049950
70 Landovitz RJ, Donnell D, Clement ME, Cabotegravir for HIV prevention in cisgender men and transgender women. N Engl J Med. 2021 08 12;385(7):595–608. doi: 10.1056/NEJMoa2101016. PMID: 34379922.34379922
71 National Institute of Allergy and Infectious Diseases. Evaluating the Safety and Efficacy of Long-Acting Injectable Cabotegravir Compared to Daily Oral TDF/FTC for Pre-Exposure Prophylaxis in HIV-Uninfected Women. clinicaltrials.gov; 2017. https://clinicaltrials.gov/ct2/show/NCT03164564. Accessed February 2, 2018.
72 Baum MM, Butkyavichene I, Churchman SA, An intravaginal ring for the sustained delivery of tenofovir disoproxil fumarate. Int J Pharm. 2015 Nov 10;495(1):579–87. doi: 10.1016/j.ijpharm.2015.09.028. PMID: 26386138.26386138
73 Baeten JM, Palanee-Phillips T, Brown ER, Use of a vaginal ring containing dapivirine for HIV-1 prevention in women. N Engl J Med. 2016 Dec;375(22):2121–32. doi: 10.1056/NEJMoa1506110. PMID: 26900902.26900902
74 Nel A, van Niekerk N, Kapiga S, Safety and efficacy of a dapivirine vaginal ring for HIV prevention in women. N Engl J Med. 2016;375(22):2133–43. doi: 10.1056/NEJMoa1602046. PMID: 27959766.27959766
75 U.S. Food & Drug Administration. FDA Approves First Injectable Treatment for HIV Pre-Exposure Prevention. December 20, 2021.; 2021. https://www.fda.gov/news-events/press-announcements/fda-approves-first-injectable-treatment-hiv-pre-exposure-prevention. Accessed December 20, 2021.
76 Scarsi KK. Chasing the cabotegravir tail: implications for prevention. Lancet HIV. 2020 Jul;7(7):e451–e3. doi: 10.1016/s2352-3018(20)30165-x. PMID: 32497490.32497490
77 Hankins C, Macklin R, Warren M. Translating PrEP effectiveness into public health impact: key considerations for decision-makers on cost-effectiveness, price, regulatory issues, distributive justice and advocacy for access. J Int AIDS Soc. 2015;18(4 Suppl 3):19973. doi: 10.7448/IAS.18.4.19973. PMID: 26198343.26198343
78 Caceres CF, Koechlin F, Goicochea P, The promises and challenges of pre-exposure prophylaxis as part of the emerging paradigm of combination HIV prevention. J Int AIDS Soc. 2015;18(4 Suppl 3):19949. doi: 10.7448/IAS.18.4.19949. PMID: 26198341.26198341
79 Falutz J. Editorial commentary: unmasking the bare bones of HIV preexposure prophylaxis. Clin Infect Dis. 2015 Aug 15;61(4):581–3. doi: 10.1093/cid/civ329. PMID: 25908681.25908681
80 World Health Organization. Updated recommendations on HIV prevention, infant diagnosis, antiretroviral initiation and monitoring. Geneva; 2021. https://www.who.int/publications/i/item/9789240022232. Accessed September 24, 2021.
81 Krakower DS. Human Immunodeficiency Virus Preexposure Prophylaxis: Meeting the Needs of Transgender Populations. Clinical Infectious Diseases. 2020;73(7):e2124–e6. doi: 10.1093/cid/ciaa1158.
82 U. S. Public Health Service, Centers for Disease Control and Prevention. Preexposure Prophylaxis for the Prevention of HIV infection in the United States—2014: a Clinical Practice Guideline. 2014. https://www.sfdph.org/dph/files/newsMediadocs/2014PR/PrEPguidelines2014.pdf Accessed June 8, 2023.
83 Centers for Disease Control and Prevention, US Public Health Service. Preexposure prophylaxis for the prevention of HIV infection in the United States—2017 Update: a clinical practice guideline. https://www.cdc.gov/hiv/pdf/risk/prep/cdc-hiv-prep-guidelines-2017.pdf. 2017. Published March 2018. Accessed June 8, 2023.
84 Centers for Disease Control and Prevention, US Public Health Service. Preexposure prophylaxis for the prevention of HIV infection in the United States—2021 Update: a clinical practice guideline. https://www.cdc.gov/hiv/pdf/risk/prep/cdc-hiv-prep-guidelines-2021.pdf. Published December 2021. Accessed June 8, 2023.
85 Apretude (cabotegravir extended-release injectable suspension). Highlights of Prescribing Information. 2021. https://gskpro.com/content/dam/global/hcpportal/en_US/Prescribing_Information/Apretude/pdf/APRETUDE-PI-PIL-IFU.PDF. Accessed June 8, 2023.
86 Abrams E. Lessons from dolutegravir and neural tube defects. Lancet. 2021;8(1):E1–E4.
87 Saag MS, Gandhi RT, Hoy JF, Antiretroviral drugs for treatment and prevention of HIV infection in adults: 2020 recommendations of the International Antiviral Society-USA Panel. JAMA. 2020 Oct 27;324(16):1651–69. doi: 10.1001/jama.2020.17025. PMID: 33052386.33052386
88 Delany-Moretlwe S, Hughes JP, Bock P, Cabotegravir for the prevention of HIV-1 in women: results from HPTN 084, a phase 3, randomised clinical trial. Lancet. 2022 Apr 1doi: 10.1016/s0140-6736(22)00538-4. PMID: 35378077.35378077
89 World Health Organization. Consolidated guidelines on the use of antiretroviral drugs for treating and preventing HIV infection (2016). 2016. https://www.who.int/publications/i/item/9789241549684. September 14, 2021.
90 IPM Statement on US Food and Drug Administration Review of Dapivirine Vaginal Ring. Silver Spring, Md.: International Partnership for Microbicides; 2021. https://www.ipmglobal.org/content/ipm-statement-us-food-and-drug-administration-review-dapivirine-vaginal-ring. Accessed May 9 2022.
91 World Health Organization. PrEP Implementation Tool. 2021. https://www.who.int/tools/prep-implementation-tool. Accessed September 14, 2021.
92 Song HJ, Squires P, Wilson D, Trends in HIV preexposure prophylaxis prescribing in the United States, 2012-2018. JAMA. 2020 Jul 28;324(4):395–7. doi: 10.1001/jama.2020.7312. PMID: 32720996.32720996
93 Kamitani E, Johnson WD, Wichser ME, Growth in proportion and disparities of HIV PrEP use among key populations identified in the United States National Goals: systematic review and meta-analysis of published surveys. J Acquir Immune Defic Syndr. 2020 08 01;84(4):379–86. doi: 10.1097/QAI.0000000000002345. PMID: 32205721.32205721
94 Centers for Disease Control and Prevention. Monitoring Selected National HIV Prevention and Care Objectives By Using HIV Surveillance Data United States and 6 Dependent Areas, 2019. 2021. https://www.cdc.gov/hiv/library/reports/hiv-surveillance/vol-26-no-2/index.html. Accessed September 14, 2021.
95 Krakower DS, Mayer KH. The role of healthcare providers in the roll out of preexposure prophylaxis. Curr Opin HIV AIDS. 2016 Jan;11(1):41–8. doi: 10.1097/COH.0000000000000206. PMID: 26417953.26417953
96 Petroll AE, Walsh JL, Owczarzak JL, PrEP awareness, familiarity, comfort, and prescribing experience among U.S. primary care providers and HIV specialists. AIDS Behav. 2017 May 01;21(5):1256–67. doi: 10.1007/s10461-016-1625-1. PMID: 27885552.27885552
97 Walsh JL, Petroll AE. Factors related to pre-exposure prophylaxis prescription by U.S. primary care physicians. Am J Prev Med. 2017 2017/06/01/;52(6):e165–e72. doi: 10.1016/j.amepre.2017.01.025. PMID: 28363410.28363410
98 Zhang C, McMahon J, Fiscella K, HIV pre-exposure prophylaxis implementation cascade among health care professionals in the United States: implications from a systematic review and meta-analysis. AIDS Patient Care STDS. 2019 12;33(12):507–27. doi: 10.1089/apc.2019.0119. PMID: 31821044.31821044
99 Mayer KH, Agwu A, Malebranche D. Barriers to the wider use of pre-exposure prophylaxis in the United States: a narrative review. Adv Ther. 2020 May;37(5):1778–811. doi: 10.1007/s12325-020-01295-0. PMID: 32232664.32232664
100 Russ S, Zhang C, Liu Y. Pre-exposure prophylaxis care continuum, barriers, and facilitators among black men who have sex with men in the United States: a systematic review and meta-analysis. AIDS Behav. 2021 Jul;25(7):2278–88. doi: 10.1007/s10461-020-03156-x. PMID: 33438151.33438151
101 Blackstock OJ, Moore BA, Berkenblit GV, A cross-sectional online survey of HIV pre-exposure prophylaxis adoption among primary care physicians. J Gen Intern Med. 2017 Jan;32(1):62–70. doi: 10.1007/s11606-016-3903-z. PMID: 27778215.27778215
102 Departments of Labor, Health and Human Services (HHS), Treasury. FAQS ABOUT AFFORDABLE CARE ACT IMPLEMENTATION PART 47. 2021. https://www.dol.gov/sites/dolgov/files/EBSA/about-ebsa/our-activities/resource-center/faqs/aca-part-47.pdf. Accessed September 14, 2021
103 Centers for Disease Control and Prevention. Core indicators for monitoring the Ending the HIV Epidemic initiative (preliminary data): National HIV Surveillance System data reported through September 2021; and preexposure prophylaxis (PrEP) data reported through June 2021. HIV Surveillance Data Tables 2021;2(No. 5). 2021. https://www.cdc.gov/hiv/pdf/library/reports/surveillance-data-tables/vol-2-no-5/cdc-hiv-surveillance-tables-vol-2-no-5.pdf. Accessed June 20, 2022.
104 Patel RR, Mena L, Nunn A, Impact of insurance coverage on utilization of pre-exposure prophylaxis for HIV prevention. PLoS One. 2017;12(5):e0178737. doi: 10.1371/journal.pone.0178737. PMID: 2855806728558067.
105 Macapagal K, Kraus A, Korpak AK, PrEP awareness, uptake, barriers, and correlates among adolescents assigned male at birth who have sex with males in the U.S. Arch Sex Behav. 2020 Jan;49(1):113–24. doi: 10.1007/s10508-019-1429-2. PMID: 31602584.31602584
106 Sevelius JM, Poteat T, Luhur WE, HIV testing and PrEP use in a national probability sample of sexually active transgender people in the United States. J Acquir Immune Defic Syndr. 2020 Aug 15;84(5):437–42. doi: 10.1097/qai.0000000000002403. PMID: 32692101.32692101
107 Hojilla JC, Hurley LB, Marcus JL, Characterization of HIV preexposure prophylaxis use behaviors and HIV incidence among US adults in an integrated health care system. JAMA Netw Open. 2021 Aug 2;4(8):e2122692. doi: 10.1001/jamanetworkopen.2021.22692. PMID: 34436609.34436609
108 U.S. Preventive Services Task Force. Procedure Manual. Rockville, MD. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual. Accessed May 11 2022.
109 Centers for Disease Control and Prevention, Prevention National Center for HIV/AIDS, Viral Hepatitis, STD, and TB Prevention. 2021 Draft Clinical Practice PrEP Guideline Public Comment Webinar. 2021. https://www.cdc.gov/hiv/pdf/programresources/cdc-hiv-PrEP-GL-Webinar-2021-Presentation.pdf. Accessed September 14, 2021.
110 Kiser PF, Johnson TJ, Clark JT. State of the art in intravaginal ring technology for topical prophylaxis of HIV infection. AIDS Rev. 2012 Jan-Mar;14(1):62–77. PMID: 22297505.22297505
111 Nel A, van Niekerk N, Van Baelen B, Safety, adherence, and HIV-1 seroconversion among women using the dapivirine vaginal ring (DREAM): an open-label, extension study. Lancet HIV. 2021 Feb;8(2):e77–e86. doi: 10.1016/s2352-3018(20)30300-3. PMID: 33539761.33539761
112 Baeten JM, Palanee-Phillips T, Mgodi NM, Safety, uptake, and use of a dapivirine vaginal ring for HIV-1 prevention in African women (HOPE): an open-label, extension study. Lancet HIV. 2021 Feb;8(2):e87–e95. doi: 10.1016/s2352-3018(20)30304-0. PMID: 33539762.33539762
113 Gulick R, Wilkin TJ, Chen Y, HPTN 069/ACTG 5305: Phase II study of maraviroc-based regimens for HIV PrEP in MSM [Abstract]. Conference on Retroviruses and Opportunistic Infections (CROI); February 22-25, 2016; Boston, MA.
114 Gulick RM, Wilkin TJ, Chen YQ, Phase 2 study of the safety and tolerability of maraviroc-containing regimens to prevent HIV Infection in men who have sex with men (HPTN 069/ACTG A5305). J Infect Dis. 2017 Jan 15;215(2):238–46. doi: 10.1093/infdis/jiw525. PMID: 27811319.27811319
115 Gulick RM, Wilkin TJ, Chen YQ, Safety and tolerability of maraviroc-containing regimens to prevent HIV infection in women: A phase 2 randomized trial. Ann Intern Med. 2017;167(6):384–93. doi: 10.7326/M17-0520. PMID: 28828489.28828489
116 Abdool Karim Q, Abdool Karim SS, Frohlich JA, Effectiveness and safety of tenofovir gel, an antiretroviral microbicide, for the prevention of HIV infection in women. Science. 2010 Sep 03;329(5996):1168–74. doi: 10.1126/science.1193748. PMID: 20643915.20643915
117 Rees H, Delany-Moretlwe S, Lombard C, FACTS 001 phase III trial of pericoital tenofovir 1% gel for HIV prevention in women. Presented at the Conference on Retroviruses and Opportunistic Infections (CROI), Seattle, February 23-26, 2015.
118 McCormack S, Dunn DT, Desai M, Pre-exposure prophylaxis to prevent the acquisition of HIV-1 infection (PROUD): effectiveness results from the pilot phase of a pragmatic open-label randomised trial. Lancet. 2016 Jan 2;387(10013):53–60. doi: 10.1016/S0140-6736(15)00056-2. PMID: 26364263.26364263
119 Abdool Karim SS, Abdool Karim Q, Kharsany AB, Tenofovir gel for the prevention of herpes simplex virus type 2 infection. N Engl J Med. 2015 Aug 6;373(6):530–9. doi: 10.1056/NEJMoa1410649. PMID: 26244306.26244306
120 Celum C, Morrow RA, Donnell D, Daily oral tenofovir and emtricitabine-tenofovir preexposure prophylaxis reduces herpes simplex virus type 2 acquisition among heterosexual HIV-1-uninfected men and women: a subgroup analysis of a randomized trial. Ann Intern Med. 2014 Jul 1;161(1):11–9. doi: 10.7326/M13-2471. PMID: 24979446.24979446
121 Mayer KH, Molina JM, Thompson MA, Emtricitabine and tenofovir alafenamide vs emtricitabine and tenofovir disoproxil fumarate for HIV pre-exposure prophylaxis (DISCOVER): primary results from a randomised, double-blind, multicentre, active-controlled, phase 3, non-inferiority trial. Lancet. 2020 07 25;396(10246):239–54. doi: 10.1016/S0140-6736(20)31065-5. PMID: 32711800.32711800
122 Hurt CB, Eron JJ Jr., Cohen MS. Pre-exposure prophylaxis and antiretroviral resistance: HIV prevention at a cost? Clin Infect Dis. 2011 Dec;53(12):1265–70. doi: 10.1093/cid/cir684. PMID: 21976467.21976467
123 Sun X, Briel M, Walter SD, Is a subgroup effect believable? Updating criteria to evaluate the credibility of subgroup analyses. BMJ. 2010;340doi: 10.1136/bmj.c117. PMID: 20354011.20354011
124 Higgins JP, Thompson SG, Deeks JJ, Measuring inconsistency in meta-analyses. BMJ. 2003 Sep 6;327(7414):557–60. doi: 10.1136/bmj.327.7414.557. PMID: 12958120.12958120
125 Cornell JE, Mulrow CD, Localio R, Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med. 2014 Feb 18;160(4):267–70. doi: 10.7326/M13-28861829794. PMID: 24727843.24727843
126 Center for Drug Evaluation and Research. Clinical Review. 2011. https://www.accessdata.fda.gov/drugsatfda_docs/nda/2012/021752Orig1s030MedR.pdf. Accessed February 2, 2018.
127 Sterne JA, Sutton AJ, Ioannidis JP, Recommendations for examining and interpreting funnel plot asymmetry in meta-analyses of randomised controlled trials. BMJ. 2011 Jul 22;343:d4002. doi: 10.1136/bmj.d4002. PMID: 21784880.21784880
128 Agot K, Taylor D, Corneli AL, Accuracy of self-report and pill-count measures of adherence in the FEM-PrEP clinical trial: implications for future HIV-prevention trials. AIDS Behav. 2015 May;19(5):743–51. doi: 10.1007/s10461-014-0859-z. PMID: 25100053.25100053
129 Antoni G, Tremblay C, Delaugerre C, On-demand pre-exposure prophylaxis with tenofovir disoproxil fumarate plus emtricitabine among men who have sex with men with less frequent sexual intercourse: a post-hoc analysis of the ANRS IPERGAY trial. The Lancet. HIV. 2020 02;7(2):e113–e20. doi: 10.1016/S2352-3018(19)30341-8. PMID: 31784343.31784343
130 Bekker LG, Roux S, Sebastien E, Daily and non-daily pre-exposure prophylaxis in African women (HPTN 067/ADAPT Cape Town trial): a randomised, open-label, phase 2 trial. Lancet HIV. 2018 02;5(2):e68–e78. doi: 10.1016/S2352-3018(17)30156-X. PMID: 28986029.28986029
131 Beymer MR, Weiss RE, Sugar CA, Are Centers for Disease Control and Prevention guidelines for preexposure prophylaxis specific enough? Formulation of a personalized HIV risk score for pre-exposure prophylaxis initiation. Sex Transm Dis. 2017 Jan;44(1):48–56. doi: 10.1097/olq.0000000000000535. PMID: 27898570.27898570
132 Chaix ML, Charreau I, Pintado C, Effect of on-demand oral preexposure prophylaxis with tenofovir/emtricitabine on herpes simplex virus-1/2 incidence among men who have sex with men: A substudy of the ANRS IPERGAY trial. Open Forum Infectious Diseases. 2018;5(11)doi: 10.1093/ofid/ofy295. PMID: 30539039.30539039
133 Chirwa LI, Johnson JA, Niska RW, CD4(+) cell count, viral load, and drug resistance patterns among heterosexual breakthrough HIV infections in a study of oral preexposure prophylaxis. AIDS. 2014 Jan 14;28(2):223–6. doi: 10.1097/QAD.0000000000000102. PMID: 24361682.24361682
134 Deutsch MB, Glidden DV, Sevelius J, HIV pre-exposure prophylaxis in transgender women: a subgroup analysis of the iPrEx trial. Lancet HIV. 2015 Dec;2(12):e512–9. doi: 10.1016/S2352-3018(15)00206-4. PMID: 26614965.26614965
135 Donnell D, Baeten JM, Bumpus NN, HIV protective efficacy and correlates of tenofovir blood concentrations in a clinical trial of PrEP for HIV prevention. J Acquir Immune Defic Syndr. 2014 Jul 1;66(3):340–8. doi: 10.1097/QAI.0000000000000172. PMID: 24784763.24784763
136 Grant RM, Mannheimer S, Hughes JP, Daily and nondaily oral preexposure prophylaxis in men and transgender women who have sex with men: The Human Immunodeficiency Virus Prevention Trials Network 067/ADAPT study. Clin Infect Dis. 2018 May 17;66(11):1712–21. doi: 10.1093/cid/cix1086. PMID: 29420695.29420695
137 Grant RM, Lama JR, Anderson PL, Preexposure chemoprophylaxis for HIV prevention in men who have sex with men. N Engl J Med. 2010 Dec 30;363(27):2587–99. doi: 10.1056/NEJMoa1011205. PMID: 21091279.21091279
138 Haberer JE, Baeten JM, Campbell J, Adherence to antiretroviral prophylaxis for HIV prevention: a substudy cohort within a clinical trial of serodiscordant couples in East Africa. PLoS Med. 2013;10(9):e1001511. doi: 10.1371/journal.pmed.1001511. PMID: 24058300.24058300
139 Heffron R, Mugo N, Were E, Preexposure prophylaxis is efficacious for HIV-1 prevention among women using depot medroxyprogesterone acetate for contraception. AIDS. 2014 Nov 28;28(18):2771–6. doi: 10.1097/QAD.0000000000000493. PMID: 25493602.25493602
140 Hoenigl M, Weibel N, Mehta SR, Development and validation of the San Diego early test score to predict acute and early HIV infection risk in men who have sex with men. Clin Infect Dis. 2015 Aug 1;61(3):468–75. doi: 10.1093/cid/civ335. PMID: 25904374.25904374
141 Hosek SG, Siberry G, Bell M, The acceptability and feasibility of an HIV preexposure prophylaxis (PrEP) trial with young men who have sex with men. J Acquir Immune Defic Syndr. 2013 Apr 01;62(4):447–56. doi: 10.1097/QAI.0b013e3182801081. PMID: 24135734.24135734
142 Jones J, Hoenigl M, Siegler AJ, Assessing the performance of 3 human immunodeficiency virus incidence risk scores in a cohort of black and white men who have sex with men in the South. Sex Transm Dis. 2017 May;44(5):297–302. doi: 10.1097/OLQ.0000000000000596. PMID: 28407646.28407646
143 Krakower DS, Gruber S, Hsu K, Development and validation of an automated HIV prediction algorithm to identify candidates for pre-exposure prophylaxis: a modelling study. The Lancet. HIV. 2019 10;6(10):e696–e704. doi: 10.1016/S2352-3018(19)30139-0. PMID: 31285182.31285182
144 Kwan TH, Lui GC Y, Lam TT N, Comparison between daily and on-demand PrEP (pre-exposure prophylaxis) regimen in covering condomless anal intercourse for men who have sex with men in Hong Kong: A randomized, controlled, open-label, crossover trial. Journal of the International AIDS Society. 2021 09;24(9):e25795. doi: 10.1002/jia2.25795. PMID: 34473402.34473402
145 Lancki N, Almirol E, Alon L, Preexposure prophylaxis guidelines have low sensitivity for identifying seroconverters in a sample of young Black MSM in Chicago. AIDS. 2018 Jan 28;32(3):383–92. doi: 10.1097/qad.0000000000001710. PMID: 29194116.29194116
146 Lehman DA, Baeten JM, McCoy CO, Risk of drug resistance among persons acquiring HIV within a randomized clinical trial of single- or dual-agent preexposure prophylaxis. J Infect Dis. 2015 Apr 15;211(8):1211–8. doi: 10.1093/infdis/jiu677. PMID: 25587020.25587020
147 Liu A, Glidden DV, Anderson PL, Patterns and correlates of PrEP drug detection among MSM and transgender women in the Global iPrEx Study. J Acquir Immune Defic Syndr. 2014 Dec 15;67(5):528–37. doi: 10.1097/QAI.0000000000000351. PMID: 25230290.25230290
148 Liu AY, Vittinghoff E, Sellmeyer DE, Bone mineral density in HIV-negative men participating in a tenofovir pre-exposure prophylaxis randomized clinical trial in San Francisco. PLoS One. 2011;6(8):e23688. doi: 10.1371/journal.pone.0023688. PMID: 2189785221897852.
149 Mandala J, Nanda K, Wang M, Liver and renal safety of tenofovir disoproxil fumarate in combination with emtricitabine among African women in a pre-exposure prophylaxis trial. BMC Pharmacol Toxicol. 2014;15:77. doi: 10.1186/2050-6511-15-77. PMID: 25539648.25539648
150 Marcus JL, Glidden DV, McMahan V, Daily oral emtricitabine/tenofovir preexposure prophylaxis and herpes simplex virus type 2 among men who have sex with men. PLoS One. 2014;9(3):e91513. doi: 10.1371/journal.pone.0091513. PMID: 24637511.24637511
151 Marcus JL, Hurley LB, Krakower DS, Use of electronic health record data and machine learning to identify candidates for HIV pre-exposure prophylaxis: a modelling study. The Lancet. HIV. 2019 10;6(10):e688–e95. doi: 10.1016/S2352-3018(19)30137-7. PMID: 31285183.31285183
152 Martin M, Vanichseni S, Suntharasamai P, Renal function of participants in the Bangkok tenofovir study--Thailand, 2005-2012. Clin Infect Dis. 2014 Sep 1;59(5):716–24. doi: 10.1093/cid/ciu355. PMID: 24829212.24829212
153 Martin M, Vanichseni S, Suntharasamai P, The impact of adherence to preexposure prophylaxis on the risk of HIV infection among people who inject drugs. AIDS. 2015 Apr 24;29(7):819–24. doi: 10.1097/QAD.0000000000000613. PMID: 25985403.25985403
154 Matthews LT, Heffron R, Mugo NR, High medication adherence during periconception periods among HIV-1-uninfected women participating in a clinical trial of antiretroviral pre-exposure prophylaxis. J Acquir Immune Defic Syndr. 2014 Sep 1;67(1):91–7. doi: 10.1097/QAI.0000000000000246. PMID: 25118795.25118795
155 Menza TW, Hughes JP, Celum CL, Prediction of HIV acquisition among men who have sex with men. Sex Transm Dis. 2009 Sep;36(9):547–55. doi: 10.1097/OLQ.0b013e3181a9cc41. PMID: 19707108.19707108
156 Mirembe BG, Kelly CW, Mgodi N, Bone mineral density changes among young, healthy African women receiving oral tenofovir for HIV preexposure prophylaxis. J Acquir Immune Defic Syndr. 2016 Mar 1;71(3):287–94. doi: 10.1097/QAI.0000000000000858. PMID: 26866954.26866954
157 Mugo NR, Hong T, Celum C, Pregnancy incidence and outcomes among women receiving preexposure prophylaxis for HIV prevention: a randomized clinical trial. JAMA. 2014 Jul 23-30;312(4):362–71. doi: 10.1001/jama.2014.8735. PMID: 25038355.25038355
158 Mugwanya KK, Wyatt C, Celum C, Changes in glomerular kidney function among HIV-1-uninfected men and women receiving emtricitabine-tenofovir disoproxil fumarate preexposure prophylaxis: a randomized clinical trial. JAMA Intern Med. 2015 Feb;175(2):246–54. doi: 10.1001/jamainternmed.2014.6786. PMID: 25531343.25531343
159 Mulligan K, Glidden DV, Anderson PL, Effects of emtricitabine/tenofovir on bone mineral density in HIV-negative persons in a randomized, double-blind, placebo-controlled trial. Clin Infect Dis. 2015 Aug 15;61(4):572–80. doi: 10.1093/cid/civ324. PMID: 25908682.25908682
160 Murnane PM, Brown ER, Donnell D, Estimating efficacy in a randomized trial with product nonadherence: application of multiple methods to a trial of preexposure prophylaxis for HIV prevention. Am J Epidemiol. 2015 Nov 15;182(10):848–56. doi: 10.1093/aje/kwv202. PMID: 26487343.26487343
161 Murnane PM, Celum C, Mugo N, Efficacy of preexposure prophylaxis for HIV-1 prevention among high-risk heterosexuals: subgroup analyses from a randomized trial. AIDS. 2013 Aug 24;27(13):2155–60. doi: 10.1097/QAD.0b013e3283629037. PMID: 24384592.24384592
162 Ogbuagu O, Ruane PJ, Podzamczer D, Long-term safety and efficacy of emtricitabine and tenofovir alafenamide vs emtricitabine and tenofovir disoproxil fumarate for HIV-1 pre-exposure prophylaxis: week 96 results from a randomised, double-blind, placebo-controlled, phase 3 trial. The Lancet. HIV. 2021 07;8(7):e397–e407. doi: 10.1016/S2352-3018(21)00071-0. PMID: 34197772.34197772
163 Peebles K, van der Straten A, Palanee-Phillips T, Brief Report: Anal Intercourse, HIV-1 Risk, and Efficacy in a Trial of a Dapivirine Vaginal Ring for HIV-1 Prevention. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2020 03 01;83(3):197–201. doi: 10.1097/QAI.0000000000002253. PMID: 31809308.31809308
164 Ridgway JP, Friedman EE, Bender A, Evaluation of an Electronic Algorithm for Identifying Cisgender Female Pre-Exposure Prophylaxis Candidates. AIDS Patient Care & STDS. 2021 01;35(1):5–8. doi: 10.1089/apc.2020.0231. PMID: 33400588.33400588
165 Scott H, Vittinghoff E, Irvin R, Development and Validation of the Personalized Sexual Health Promotion (SexPro) HIV Risk Prediction Model for Men Who Have Sex with Men in the United States. AIDS Behav. 2020 Jan;24(1):274–83. doi: 10.1007/s10461-019-02616-3. PMID: 31352633.31352633
166 Smith DK, Pals SL, Herbst JH, Development of a clinical screening index predictive of incident HIV infection among men who have sex with men in the United States. J Acquir Immune Defic Syndr. 2012 Aug 1;60(4):421–7. doi: 10.1097/QAI.0b013e318256b2f6. PMID: 22487585.22487585
167 Smith DK, Pan Y, Rose CE, A brief screening tool to assess the risk of contracting HIV infection among active injection drug users. J Addict Med. 2015 May-Jun;9(3):226–32. doi: 10.1097/ADM.0000000000000123. PMID: 25961495.25961495
168 Solomon MM, Lama JR, Glidden DV, Changes in renal function associated with oral emtricitabine/tenofovir disoproxil fumarate use for HIV pre-exposure prophylaxis. AIDS. 2014 Mar 27;28(6):851–9. doi: 10.1097/QAD.0000000000000156. PMID: 24499951.24499951
169 Solomon MM, Schechter M, Liu AY, The Safety of Tenofovir-Emtricitabine for HIV Pre-Exposure Prophylaxis (PrEP) in Individuals With Active Hepatitis B. J Acquir Immune Defic Syndr. 2016 Mar 1;71(3):281–6. doi: 10.1097/qai.0000000000000857. PMID: 26413853.26413853
170 Thigpen MC, Kebaabetswe PM, Paxton LA, Antiretroviral preexposure prophylaxis for heterosexual HIV transmission in Botswana. N Engl J Med. 2012 Aug 2;367(5):423–34. doi: 10.1056/NEJMoa1110711. PMID: 22784038.22784038
171 Tordoff DM, Barbee LA, Khosropour CM, Derivation and Validation of an HIV Risk Prediction Score Among Gay, Bisexual, and Other Men Who Have Sex With Men to Inform PrEP Initiation in an STD Clinic Setting. Journal of Acquired Immune Deficiency Syndromes: JAIDS. 2020 11 01;85(3):263–71. doi: 10.1097/QAI.0000000000002438. PMID: 32658131.32658131
172 Van Damme L, Corneli A, Ahmed K, Preexposure prophylaxis for HIV infection among African women. N Engl J Med. 2012 Aug 2;367(5):411–22. doi: 10.1056/NEJMoa1202614. PMID: 22784040.22784040
173 Were EO, Heffron R, Mugo NR, Pre-exposure prophylaxis does not affect the fertility of HIV-1-uninfected men. AIDS. 2014 Aug 24;28(13):1977–82. doi: 10.1097/QAD.0000000000000313. PMID: 25259704.25259704
174 Balkus JE, Brown E, Palanee T, An empiric HIV risk scoring tool to predict HIV-1 acquisition in African women. J Acquir Immune Defic Syndr. 2016 Jul 1;72(3):333–43. doi: 10.1097/QAI.0000000000000974. PMID: 26918545.26918545
175 Centers for Disease Control and Prevention, US Public Health Service. Preexposure prophylaxis for the prevention of HIV infection in the United States—2021 Update: clinical provider's supplement. https://www.cdc.gov/hiv/pdf/risk/prep/cdc-hiv-prep-provider-supplement-2021.pdf. 2021. Accessed May 9 2022.
176 Kasonde M, Niska RW, Rose C, Bone mineral density changes among HIV-uninfected young adults in a randomised trial of pre-exposure prophylaxis with tenofovir-emtricitabine or placebo in Botswana. PLoS ONE. 2014;9(3):e90111. doi: 10.1371/journal.pone.0090111. PMID: 24625530.24625530
177 Liu AY, Cohen SE, Vittinghoff E, Preexposure prophylaxis for HIV infection integrated with municipal- and community-based sexual health services. JAMA Intern Med. 2016 Jan;176(1):75–84. doi: 10.1001/jamainternmed.2015.4683. PMID: 26571482.26571482
178 Anderson PL, Glidden DV, Liu A, Emtricitabine-tenofovir concentrations and pre-exposure prophylaxis efficacy in men who have sex with men. Sci Transl Med. 2012 Sep 12;4(151):1–8. PMID: 22972843.22972843
179 Kebaabetswe PM, Stirratt MJ, McLellan-Lemal E, Factors associated with adherence and concordance between measurement strategies in an HIV daily oral tenofovir/emtricitibine as pre-exposure prophylaxis (Prep) clinical trial, Botswana, 2007-2010. AIDS Behav. 2015 May;19(5):758–69. doi: 10.1007/s10461-014-0891-z. PMID: 25186785.25186785
180 Koss CA, Hosek SG, Bacchetti P, Comparison of measures of adherence to human immunodeficiency virus preexposure prophylaxis among adolescent and young men who have sex with men in the United States. Clin Infect Dis. 2018;66(2):213–9. PMID: 29020194.29020194
181 Corneli AL, McKenna K, Perry B, The science of being a study participant: FEM-PrEP participants' explanations for overreporting adherence to the study pills and for the whereabouts of unused pills. J Acquir Immune Defic Syndr. 2015 Apr 15;68(5):578–84. doi: 10.1097/QAI.0000000000000525. PMID: 25761233.25761233
182 Cramer JA, Roy A, Burrell A, Medication compliance and persistence: terminology and definitions. Value Health. 2008 Jan-Feb;11(1):44–7. doi: 10.1111/j.1524-4733.2007.00213.x. PMID: 18237359.18237359
183 Hosek SG, Landovitz RJ, Kapogiannis B, Safety and feasibility of antiretroviral preexposure prophylaxis for adolescent men who have sex with men aged 15 to 17 years in the United States. JAMA Pediatr. 2017 Sep 05doi: 10.1001/jamapediatrics.2017.2007. PMID: 28873128.28873128
184 Hosek SG, Rudy B, Landovitz R, An HIV preexposure prophylaxis demonstration project and safety study for young MSM. J Acquir Immune Defic Syndr. 2017 Jan 01;74(1):21–9. doi: 10.1097/qai.0000000000001179. PMID: 27632233.27632233
185 Montgomery MC, Oldenburg CE, Nunn AS, Adherence to pre-exposure prophylaxis for HIV prevention in a clinical setting. PLoS One. 2016;11(6):e0157742. doi: 10.1371/journal.pone.0157742. PMID: 27333000.27333000
186 Landovitz RJ, Beymer M, Kofron R, Plasma tenofovir levels to support adherence to TDF/FTC preexposure prophylaxis for HIV prevention in MSM in Los Angeles, California. J Acquir Immune Defic Syndr. 2017 Dec 15;76(5):501–11. doi: 10.1097/QAI.0000000000001538. PMID: 28902074.28902074
187 Chan PA, Mena L, Patel R, Retention in care outcomes for HIV pre-exposure prophylaxis implementation programmes among men who have sex with men in three US cities. J Int AIDS Soc. 2016;19(1):20903. doi: 10.7448/IAS.19.1.20903. PMID: 27302837.27302837
188 van Epps P, Maier M, Lund B, Medication adherence in a nationwide cohort of veterans initiating pre-exposure prophylaxis (PrEP) to prevent HIV infection. J Acquir Immune Defic Syndr. 2018 Mar 01;77(3):272–8. doi: 10.1097/QAI.0000000000001598. PMID: 29210835.29210835
189 Coy KC, Hazen RJ, Kirkham HS, Persistence on HIV preexposure prophylaxis medication over a 2-year period among a national sample of 7148 PrEP users, United States, 2015 to 2017. J Int AIDS Soc. 2019 Feb;22(2):e25252. doi: 10.1002/jia2.25252. PMID: 30775846.30775846
190 Huang YA, Tao G, Smith DK, Persistence With Human Immunodeficiency Virus Pre-exposure Prophylaxis in the United States, 2012-2017. Clin Infect Dis. 2021 Feb 1;72(3):379–85. doi: 10.1093/cid/ciaa037. PMID: 33527117.33527117
191 Clement ME, Nicchitta M, Sun Y, Preexposure Prophylaxis Outcomes in an Urban Community in North Carolina: Discontinuation of Care and Sexually Transmitted Infections. Sex Transm Dis. 2021 03 01;48(3):183–8. doi: 10.1097/OLQ.0000000000001288. PMID: 33003182.33003182
192 Serota DP, Rosenberg ES, Sullivan PS, Pre-exposure prophylaxis uptake and discontinuation among young black men who have sex with men in Atlanta, Georgia: A prospective cohort study. Clin Infect Dis. 2020;71(3):574–82. doi: 10.1093/cid/ciz894.31499518
193 Morgan E, Ryan DT, Newcomb ME, High Rate of Discontinuation May Diminish PrEP Coverage Among Young Men Who Have Sex with Men. AIDS Behav. 2018 Nov;22(11):3645–8. doi: 10.1007/s10461-018-2125-2. PMID: 29728950.29728950
194 Krakower D, Maloney KM, Powell VE, Patterns and clinical consequences of discontinuing HIV preexposure prophylaxis during primary care. J Int AIDS Soc. 2019 Feb;22(2):e25250. doi: 10.1002/jia2.25250. PMID: 30768762.30768762
195 Zarwell M, John SA, Westmoreland D, PrEP Uptake and Discontinuation Among a U.S. National Sample of Transgender Men and Women. AIDS Behav. 2021 Apr;25(4):1063–71. doi: 10.1007/s10461-020-03064-0. PMID: 33057893.33057893
196 Blackstock OJ, Patel VV, Felsen U, Pre-exposure prophylaxis prescribing and retention in care among heterosexual women at a community-based comprehensive sexual health clinic. AIDS Care. 2017 Jul;29(7):866–9. doi: 10.1080/09540121.2017.1286287. PMID: 28147704.28147704
197 Nair G, Ngure K, Szydlo D, Adherence to the dapivirine vaginal ring and oral PrEP among adolescent girls and young women in Africa: interim results from the REACH study. J Int AIDS Soc. 2021;24(S4):71–2.
198 Grant RM, Anderson PL, McMahan V, Uptake of pre-exposure prophylaxis, sexual practices, and HIV incidence in men and transgender women who have sex with men: a cohort study. Lancet Infect Dis. 2014 Sep;14(9):820–9. doi: 10.1016/S1473-3099(14)70847-3. PMID: 25065857.25065857
199 Tittle V, Boffito M, McOwan A, Antiretroviral resistance and management after pre-exposure to prophylaxis. Lancet. HIV. 2020 02;7(2):e84. doi: 10.1016/S2352-3018(19)30404-7. PMID: 32027853.32027853
200 Girometti N, McCormack S, Tittle V, Rising rates of recent preexposure prophylaxis exposure among men having sex with men newly diagnosed with HIV: antiviral resistance patterns and treatment outcomes. AIDS (London, England). 2022;36(4):561–6. doi: 10.1097/QAD.0000000000003143. PMID: 34873084.34873084
201 Weis JF, Baeten JM, McCoy CO, Preexposure prophylaxis-selected drug resistance decays rapidly after drug cessation. AIDS. 2016 Jan 2;30(1):31–5. doi: 10.1097/QAD.0000000000000915. PMID: 26731753.26731753
202 Sullivan PS, Sanchez TH, Zlotorzynska M, National trends in HIV pre-exposure prophylaxis awareness, willingness and use among United States men who have sex with men recruited online, 2013 through 2017. J Int AIDS Soc. 2020 03;23(3):e25461. doi: 10.1002/jia2.25461. PMID: 32153119.32153119
203 Westmoreland DA, Pantalone DW, Patel VV, Demographic, Behavioral, and Geographic Differences Between Men, Transmen, and Transwomen Currently on PrEP, Former PrEP Users, and Those Having Never Used PrEP. AIDS Behav. 2020 May;24(5):1304–11. doi: 10.1007/s10461-019-02722-2. PMID: 31707556.31707556
204 Kanny D, Jeffries WLt, Chapin-Bardales J, Racial/Ethnic Disparities in HIV Preexposure Prophylaxis Among Men Who Have Sex with Men - 23 Urban Areas, 2017. MMWR. 2019 Sep 20;68(37):801–6. doi: 10.15585/mmwr.mm6837a2. PMID: 31536484.31536484
205 Kobayashi T, Van Epps P, Maier MM, Discussion and Initiation of HIV Pre-exposure Prophylaxis Were Rare Following Diagnoses of Sexually Transmitted Infections Among Veterans. J Gen Intern Med. 2021 Aug 02;02:02. doi: 10.1007/s11606-021-07034-7. PMID: 34341917.34341917
206 Schumacher CM, Tao X, Chandran A, Reaching Those Most at Risk for HIV Acquisition: Evaluating Racial/Ethnic Disparities in the Preexposure Prophylaxis Care Continuum in Baltimore City, Maryland. J Acquir Immune Defic Syndr: JAIDS. 2021 08 15;87(5):1145–53. doi: 10.1097/QAI.0000000000002712. PMID: 33883471.33883471
207 Golub SA, Fikslin RA, Goldberg MH, Predictors of PrEP Uptake Among Patients with Equivalent Access. AIDS Behav. 2019 Jul;23(7):1917–24. doi: 10.1007/s10461-018-2376-y. PMID: 30600456.30600456
208 Braksmajer A, Walters SM, Crean HF, Pre-exposure Prophylaxis Use Among Men Who Have Sex with Men Experiencing Partner Violence. AIDS Behav. 2020 Aug;24(8):2299–306. doi: 10.1007/s10461-020-02789-2. PMID: 31953703.31953703
209 Mistler CB, Copenhaver MM, Shrestha R. The Pre-exposure Prophylaxis (PrEP) Care Cascade in People Who Inject Drugs: A Systematic Review. AIDS Behav. 2021 May;25(5):1490–506. doi: 10.1007/s10461-020-02988-x. PMID: 32749627.32749627
210 Wilson EC, Turner CM, Arayasirikul S, Disparities in the PrEP continuum for trans women compared to MSM in San Francisco, California: results from population-based cross-sectional behavioural surveillance studies. J Int AIDS Soc. 2020 06;23 Suppl 3:e25539. doi: 10.1002/jia2.25539. PMID: 32602642.32602642
211 Chittamuru D, Frye V, Koblin BA, PrEP Stigma, HIV Stigma, and Intention to Use PrEP among Women in New York City and Philadelphia. Stigma Health. 2020 May;5(2):240–6. doi: 10.1037/sah0000194. PMID: 33184608.33184608
212 Brooks RA, Cabral A, Nieto O, Experiences of Pre-Exposure Prophylaxis Stigma, Social Support, and Information Dissemination Among Black and Latina Transgender Women Who Are Using Pre-Exposure Prophylaxis. Transgend Health. 2019;4(1):188–96. doi: 10.1089/trgh.2019.0014. PMID: 31482134.31482134
213 Teixeira da Silva D, Bouris A, Ramachandran A, Embedding a Linkage to Preexposure Prophylaxis Care Intervention in Social Network Strategy and Partner Notification Services: Results From a Pilot Randomized Controlled Trial. J Acquir Immune Defic Syndr. 2021 02 01;86(2):191–9. doi: 10.1097/QAI.0000000000002548. PMID: 33109935.33109935
214 Desrosiers A, Levy M, Dright A, A Randomized Controlled Pilot Study of a Culturally-Tailored Counseling Intervention to Increase Uptake of HIV Pre-exposure Prophylaxis Among Young Black Men Who Have Sex with Men in Washington, DC. AIDS Behav. 2019 Jan;23(1):105–15. doi: 10.1007/s10461-018-2264-5. PMID: 30171452.30171452
215 Harawa NT, Schrode KM, McWells C, Small Randomized Controlled Trial of the New Passport to Wellness HIV Prevention Intervention for Black Men Who Have Sex With Men (BMSM). AIDS Educ Prev. 2020 08;32(4):311–24. doi: 10.1521/aeap.2020.32.4.311. PMID: 32897130.32897130
216 Chan PA, Nunn A, van den Berg JJ, A Randomized Trial of a Brief Behavioral Intervention for PrEP Uptake Among Men Who Have Sex With Men at Increased Risk for HIV Infection. J Acquir Immune Defic Syndr. 2021 07 01;87(3):937–43. doi: 10.1097/QAI.0000000000002671. PMID: 33734099.33734099
217 Doblecki-Lewis S, Butts S, Botero V, A Randomized Study of Passive versus Active PrEP Patient Navigation for a Heterogeneous Population at Risk for HIV in South Florida. J Int Assoc Provid AIDS Care. 2019 Jan-Dec;18:2325958219848848. doi: 10.1177/2325958219848848. PMID: 31131679.31131679
218 Meyer J, Price C, Tracey D, Preference for and efficacy of a prep decision aifor women with substance use disorders. Patient Prefer Adherence. 2021;15:1913–27. PMID: CN-02325866 NEW.34511887
219 Siddiqui J, Herchline T, Kahlon S, Infectious Diseases Society of America Position Statement on Telehealth and Telemedicine as Applied to the Practice of Infectious Diseases. Clin Infect Dis. 2017 Feb 1;64(3):237–42. doi: 10.1093/cid/ciw773. PMID: 28096274.28096274
220 Stekler JD, McMahan V, Ballinger L, HIV Pre-exposure Prophylaxis Prescribing Through Telehealth. J Acquir Immune Defic Syndr. 2018;77(5):e40–e2. PMID: 29280768.29280768
221 Siegler A. Electronic Pre-exposure Prophylaxis (PrEP) Initiation and Maintenance Home Care System (ePrEP) [online research protocol] Clinicaltrials.gov Identifier: NCT03729570 (https://clinicaltrials.gov/ct2/show/NCT03729570). 2018. https://clinicaltrials.gov/ct2/show/NCT03729570.
222 Siegler AJ, Brock JB, Hurt CB, An Electronic Pre-Exposure Prophylaxis Initiation and Maintenance Home Care System for Nonurban Young Men Who Have Sex With Men: Protocol for a Randomized Controlled Trial. JMIR Research Protocols. 2019 Jun 10;8(6):e13982. doi: 10.2196/13982. PMID: 31199326.31199326
223 Siegler A. Pre-exposure Prophylaxis (PrEP) at Home (PrEP@Home) [online research protocol] Clinicaltrials.gov Identifier: NCT03569813 (https://clinicaltrials.gov/ct2/show/NCT03569813). 2018. https://clinicaltrials.gov/ct2/show/NCT03569813.
224 PrEPTECH Phase 2 Study of a PrEP Telehealth Intervention. 2021. https://clinicaltrials.gov/ct2/show/NCT04902820. Accessed June 8, 2023.
225 Virtual PrEP: Rendering PrEP Delivery More Efficient. 2021. https://clinicaltrials.gov/ct2/show/NCT05159531 Accessed June 8, 2023.
226 Siegler AJ, Mayer KH, Liu AY, Developing and Assessing the Feasibility of a Home-based Preexposure Prophylaxis Monitoring and Support Program. Clin Infect Dis. 2019 Jan 18;68(3):501–4. doi: 10.1093/cid/ciy529. PMID: 29982304.29982304
227 Cottrell ML, Yang KH, Prince HM, A translational pharmacology approach to predicting outcomes of preexposure prophylaxis against HIV in men and women using tenofovir disoproxil fumarate with or without emtricitabine. J Infect Dis. 2016 Jul 1;214(1):55–64. doi: 10.1093/infdis/jiw077. PMID: 26917574.26917574
228 Massud I, Mitchell J, Babusis D, Chemoprophylaxis with oral emtricitabine and tenofovir alafenamide combination protects macaques from rectal simian/human immunodeficiency virus infection. J Infect Dis. 2016 Oct 1;214(7):1058–62. doi: 10.1093/infdis/jiw312. PMID: 27465645.27465645
229 Keen P, Hammoud MA, Bourne A, Use of HIV Pre-exposure Prophylaxis (PrEP) Associated With Lower HIV Anxiety Among Gay and Bisexual Men in Australia Who Are at High Risk of HIV Infection: Results From the Flux Study. J Acquir Immune Defic Syndr. 2020 Feb 1;83(2):119–25. doi: 10.1097/qai.0000000000002232. PMID: 31935203.31935203
230 Koester K, Amico RK, Gilmore H, Risk, safety and sex among male PrEP users: time for a new understanding. Cult Health Sex. 2017 Dec;19(12):1301–13. doi: 10.1080/13691058.2017.1310927. PMID: 28415911.28415911
231 Whitfield TH F, Jones SS, Wachman M, The Impact of Pre-Exposure Prophylaxis (PrEP) Use on Sexual Anxiety, Satisfaction, and Esteem Among Gay and Bisexual Men. J Sex Res. 2019 Nov-Dec;56(9):1128–35. doi: 10.1080/00224499.2019.1572064. PMID: 30777781.30777781
232 Yacoub R, Nadkarni GN, Weikum D, Elevations in serum creatinine with tenofovir-based HIV pre-exposure prophylaxis: A meta-analysis of randomized placebo-controlled trials. J Acquir Immune Defic Syndr. 2016 Apr 1;71(4):e115–8. doi: 10.1097/QAI.0000000000000906. PMID: 26627105.26627105
233 Baranek B, Wang S, Cheung AM, The effect of tenofovir disoproxil fumarate on bone mineral density: a systematic review and meta-analysis. Antivir Ther. 2020;25(1):21–32. doi: 10.3851/IMP3346. PMID: 32077867.32077867
234 Tang MW, Shafer RW. HIV-1 antiretroviral resistance: scientific principles and clinical applications. Drugs. 2012 September 01;72(9):e1–e25. doi: 10.2165/11633630-000000000-00000. PMID: 22686620.22686620
235 Traeger MW, Schroeder SE, Wright EJ, Effects of pre-exposure prophylaxis for the prevention of HIV infection on sexual risk behavior in men who have sex with men: a systematic review and meta-analysis. Clin Infect Dis. 2018 Mar 2;67(5):676–86. doi: 10.1093/cid/ciy182. PMID: 29509889.29509889
236 Volk JE, Marcus JL, Phengrasamy T, Incident hepatitis C virus infections among users of HIV preexposure prophylaxis in a clinical practice setting. Clin Infect Dis. 2015 Jun 1;60(11):1728–9. doi: 10.1093/cid/civ129. PMID: 25694649.25694649
237 Anstett K, Brenner B, Mesplede T, HIV drug resistance against strand transfer integrase inhibitors. Retrovirology. 2017 Jun 5;14(1):36. doi: 10.1186/s12977-017-0360-7. PMID: 28583191.28583191
238 Clement ME, Kofron R, Landovitz RJ. Long-acting injectable cabotegravir for the prevention of HIV infection. Current opinion in HIV and AIDS. 2020;15(1):19–26. doi: 10.1097/COH.0000000000000597. PMID: 31644481.31644481
239 Dettinger JC, Kinuthia J, Pintye J, Perinatal outcomes following maternal preexposure prophylaxis (PrEP) use during pregnancy: results from a large PrEP implementation program in Kenya. J Int AIDS Soc. 2019 Sep;22(9):e25378. doi: 10.1002/jia2.25378. PMID: 31498563.31498563
240 Kinuthia J, Pintye J, Abuna F, Pre-exposure prophylaxis uptake and early continuation among pregnant and post-partum women within maternal and child health clinics in Kenya: results from an implementation programme. Lancet HIV. 2020 Jan;7(1):e38–e48. doi: 10.1016/s2352-3018(19)30335-2. PMID: 31813837.31813837
241 Wang L, Kourtis AP, Ellington S, Safety of tenofovir during pregnancy for the mother and fetus: a systematic review. Clin Infect Dis. 2013;57(12):1773–81. doi: 10.1093/cid/cit601. PMID: 24046310.24046310
242 Haberer JE, Bangsberg DR, Baeten JM, Defining success with HIV pre-exposure prophylaxis: a prevention-effective adherence paradigm. AIDS. 2015 Jul 17;29(11):1277–85. doi: 10.1097/qad.0000000000000647. PMID: 26103095.26103095
243 Morrison A, Polisena J, Husereau D, The effect of English-language restriction on systematic review-based meta-analyses: a systematic review of empirical studies. Int J Technol Assess Health Care. 2012 Apr;28(2):138–44. doi: 10.1017/s0266462312000086. PMID: 22559755.22559755
244 Pham B, Klassen TP, Lawson ML, Language of publication restrictions in systematic reviews gave different results depending on whether the intervention was conventional or complementary. J Clin Epidemiol. 2005 Aug;58(8):769–76. PMID: 16086467.16086467
245 Study to Assess the Effectiveness and Safety of Lenacapavir for Human Immunodeficiency Virus (HIV) Pre-Exposure Prophylaxis (PURPOSE 2). https://clinicaltrials.gov/ct2/show/NCT04925752. Accessed June 20 2022.
246 Study to Assess Safety and Efficacy of Lenacapavir and Emtricitabine/Tenofovir Alafenamide for Pre-Exposure Prophylaxis in Adolescent Girls and Young Women at Risk of HIV Infection (PURPOSE 1). https://clinicaltrials.gov/ct2/show/NCT04994509. Accessed June 20 2022.
247 Schlesinger E, Johengen D, Luecke E, A tunable, biodegradable, thin-film polymer device as a long-acting implant delivering tenofovir alafenamide fumarate for HIV pre-exposure prophylaxis. Pharm Res. 2016 Jul;33(7):1649–56. doi: 10.1007/s11095-016-1904-6. PMID: 26975357.26975357
248 Romano JW, Baum MM, Demkovich ZR, Tenofovir Alafenamide for HIV Prevention: Review of the Proceedings from the Gates Foundation Long-Acting TAF Product Development Meeting. AIDS Res Hum Retroviruses. 2021 Jun;37(6):409–20. doi: 10.1089/aid.2021.0028. PMID: 33913760.33913760
249 Merck Announces Clinical Holds on Studies Evaluating Islatravir for the Treatment and Prevention of HIV-1 Infection. Merck; 2021. https://www.merck.com/news/merck-announces-clinical-holds-on-studies-evaluating-islatravir-for-the-treatment-and-prevention-of-hiv-1-infection/. Accessed May 10 2022.
250 Corey L, Gilbert PB, Juraska M, Two Randomized Trials of Neutralizing Antibodies to Prevent HIV-1 Acquisition. N Engl J Med. 2021 Mar 18;384(11):1003–14. doi: 10.1056/NEJMoa2031738. PMID: 33730454.33730454
251 Coelho LE, Torres TS, Veloso VG, Pre-exposure prophylaxis 2.0: new drugs and technologies in the pipeline. Lancet HIV. 2019 Nov;6(11):e788–e99. doi: 10.1016/s2352-3018(19)30238-3. PMID: 31558423.31558423
252 Rowan SE, Patel RR, Schneider JA, Same-day prescribing of daily oral pre-exposure prophylaxis for HIV prevention. Lancet HIV. 2021 Feb;8(2):e114–e20. doi: 10.1016/s2352-3018(20)30256-3. PMID: 33128874.33128874
253 Huang YA, Zhu W, Smith DK, HIV preexposure prophylaxis, by race and ethnicity - United States, 2014-2016. MMWR. 2018 Oct 19;67(41):1147–50. doi: 10.15585/mmwr.mm6741a3. PMID: 30335734.30335734
254 Wilson EC, Jin H, Liu A, Knowledge, indications and willingness to take preexposure prophylaxis among transwomen in San Francisco, 2013. PLoS ONE. 2015;10(6):e0128971. doi: 10.1371/journal.pone.0128971. PMID: 26039511.26039511
255 Yager JL, Anderson PL. Pharmacology and drug interactions with HIV PrEP in transgender persons receiving gender affirming hormone therapy. Expert Opin Drug Metab Toxicol. 2020 Jun;16(6):463–74. doi: 10.1080/17425255.2020.1752662. PMID: 32250177.32250177
256 Mascolini M. No Interactions Between Hormone Therapy and PrEP in Transgender Women or Men. Conference on Retroviruses and Opportunistic Infections; 2022 Feb 12-16.
257 Hiransuthikul A, Janamnuaysook R, Himmad K, Drug-drug interactions between feminizing hormone therapy and pre-exposure prophylaxis among transgender women: the iFACT study. J Int AIDS Soc.. 2019 07;22(7):e25338. doi: 10.1002/jia2.25338. PMID: 31298497.31298497
258 Poteat T, Scheim A, Xavier J, Global epidemiology of HIV infection and related syndemics affecting transgender people. JAIDS. 2016 07/18;72(Suppl 3):S210–S9. doi: 10.1097/QAI.0000000000001087. PMID: 27429185.27429185
259 Kuo I, Olsen H, Patrick R, Willingness to use HIV pre-exposure prophylaxis among community-recruited, older people who inject drugs in Washington, DC. Drug Alcohol Depend. 2016 Jul 1;164:8–13. doi: 10.1016/j.drugalcdep.2016.02.044. PMID: 27177804.27177804
260 Escudero DJ, Kerr T, Wood E, Acceptability of HIV pre-exposure prophylaxis (PREP) among People Who Inject Drugs (PWID) in a Canadian setting. AIDS Behav. 2015 May;19(5):752–7. doi: 10.1007/s10461-014-0867-z. PMID: 25086669.25086669
261 Yusuf H, Fields E, Arrington-Sanders R, HIV Preexposure Prophylaxis Among Adolescents in the US: A Review. JAMA Pediatr. 2020 Nov 01;174(11):1102–8. doi: 10.1001/jamapediatrics.2020.0824. PMID: 32391878.32391878
262 Mizushima D, Takano M, Uemura H, Prophylactic effect of PrEP against HBV infection among MSM. Top Antivir Med. 2020;28(1):386–7.
263 Brokus CJ, Stevens J, Silk R, Suboptimal Uptake, Retention, and Adherence of Daily Oral PrEP Among People with OUD Receiving HCV Treatment. Open Forum Infect Dis. 2021 March;9(3):ofab658. doi: 10.1093/ofid/ofab658.35187191