# Acknowledgements

The authors acknowledge research librarian, Tracy Dana, MLS, for conducting the literature searches. The authors also thank the AHRQ Medical Officer, Howard Tracer, MD, as well as the U.S. Preventive Services Task Force.