# Chapter 4 Discussion

## Summary of Review Findings

This report synthesizes evidence on effects of PrEP on risk of HIV infection, harms, and other clinical outcomes; the diagnostic accuracy of instruments for identifying potential candidates for PrEP; and contextual issues related to utilization, adherence, persistence, and antiretroviral drug resistance. Table 10 summarizes the evidence reviewed for this report.

Table 10 Summary of Evidence

Key question | Number of studies (k); Number of participants^*^ (n); Study design | Summary of findings by outcome | Consistency/precision Reporting bias | Overall quality | Body of evidence limitations | Strength of evidence | Applicability
KQ1. Benefits of PrEP: Oral PrEP with TDF-FTC or TDF vs. placebo or no PrEP | HIV infection: k=12 RCTs (n=18,244); All RCTs in prior USPSTF review | 11 trials; RR, 0.46 (95% CI, 0.33 to 0.66); I^2^=67%; ARD, −2.0% (95% CI, −2.8% to −1.2%) after 4 months to 4 years; Stratified by adherence (p=0.0002 for interaction) ≥70% adherence: 6 trials; RR, 0.27 (95% CI, 0.19 to 0.39); I^2^=0%; >40% to <70% adherence: 3 trials; RR, 0.51 (95% CI, 0.38 to 0.70); I^2^=0%; ≤40% adherence: 2 trials; RR, 0.93 (95% CI, 0.72 to 1.20); I^2^=0% | Some inconsistency explained by level of adherence; precise; Funnel plot asymmetry and Egger test statistically significant (p=0.03), but no unpublished studies identified | Good | Variability in duration of followup, although results consistent when trials stratified according to followup duration.; Three trials reported some industry support, but no difference between studies that only reported industry support and those that only reported governmental or nonprofit funding on estimates. | High for benefit of oral PrEP | All trials evaluated daily oral PrEP with TDF or TDF-FTC, except for one trial of event-driven PrEP with TDF-FTC.; Studies of women and men at increased risk via heterosexual contact conducted in Africa; the only study of PWID was conducted in Asia; several studies of MSM were conducted in the U.S., Europe, and Canada.; PrEP was more effective in trials conducted in the U.S., Europe, and Canada (all of these trials reported high adherence and enrolled MSM).
KQ1. Benefits of PrEP: Oral PrEP with TDF-FTC or TDF vs. placebo or no PrEP | Mortality: k=9 RCTs (n=17,744); All RCTs in prior USPSTF review | RR, 0.81 (95% CI, 0.59 to 1.11); I^2^=0% | Consistent; imprecise; No reporting bias detected | Good | See Body of Evidence Limitations for KQ1, HIV infection. Trials were not designed to assess mortality and results were heavily weighted (73%) by a single trial of PrEP in PWID conducted in Thailand. | Low for benefit of oral PrEP | See Applicability for KQ1, HIV infection.
KQ1. Benefits of PrEP: Oral PrEP with TDF-FTC or TDF vs. placebo or no PrEP | Quality of life: k=0 | -- | -- | -- | -- | -- | --
KQ1. Benefits of PrEP: Dapivirine vaginal ring vs. placebo | HIV infection: k=2 RCTs (n=4,564); Both RCTs added for update | 2 trials; RR, 0.71 (95% CI, 0.57 to 0.89); I^2^=0%; ARD, −2.23% (95% CI, −3.75% to −0.74%) after 1.4 to 1.6 years | Consistent and precise; No reporting bias detected | Good | Relatively short duration of follow-up | High for benefit of dapivirine vaginal ring | Dapivirine vaginal ring not FDA-approved and withdrawn from FDA review.; Trials were conducted in women at increased risk of HIV infection in Africa.
KQ1a. Benefits of PrEP in populations of interest | HIV infection: k=12 RCTs (n=18,244); All RCTs in prior USPSTF review | Stratified by risk category (p=0.43 for interaction); MSM: 4 trials; RR, 0.23 (95% CI, 0.08 to 0.62); I^2^=64%; PWID: 1 trial; RR, 0.52 (95% CI, 0.29 to 0.92); Heterosexual contact: 5 trials; RR, 0.54 (95% CI, 0.31 to 0.97); I^2^=82%; No differences in within-study subgroup analyses on age (4 trials) or sex (3 trials) | Some inconsistency within risk category subgroups; precise; No reporting bias detected | Good | See Body of Evidence Limitations for KQ1, HIV infection. | Moderate for benefit of oral PrEP in populations of interest | Studies of women and men at increased risk via heterosexual contact conducted in Africa; the only study of PWID conducted in Asia; several studies of MSM conducted in the U.S., Europe, and Canada.
KQ1b. Benefits of oral PrEP by dosing strategy or regimen | HIV infection: k=12 RCTs of PrEP vs. placebo or no PrEP (n=18,172), 1 RCT of daily vs. intermittent or event-driven PrEP (n=535), 1 RCT of daily vs. event-driven PrEP (n=119); 1 new study of daily vs. event-driven PrEP; otherwise, all other studies in prior USPSTF review | PrEP vs. placebo or no PrEP: Stratified by TDF or TDF-FTC (p=0.65 for interaction); TDF: 5 trials; RR, 0.49 (95% CI, 0.28 to 0.84); I^2^=58%; TDF-FTC: 8 trials; RR, 0.44 (95% CI, 0.27 to 0.72); I^2^=74%; Stratified by daily or on-demand dosing (p=0.13 for interaction); Daily dosing: 9 trials; RR, 0.47 (95% CI, 0.32 to 0.71); I^2^=75%; On-demand dosing: 1 trial; RR, 0.14 (95% CI, 0.03 to 0.63); One head-to-head trial found no difference between daily vs. intermittent or on-demand PrEP and one head-to-head trial of daily vs. event-drivien PrEP were not powered to assess effects on HIV infection and reported few cases. | Some inconsistency in stratified analyses (may be explained by level of adherence); precise for TDF vs. TDF-FTC; imprecise for daily vs. event-driven PrEP; No reporting bias detected | Fair | See Body of Evidence Limitations for KQ1, HIV infection. | High for TDF vs. TDF-FTC, moderate for daily vs. event-driven PrEP | Five trials evaluated TDF alone, which is not approved for PrEP in the U.S.; 1 trial evaluated event-driven PrEP vs. placebo and 2 trials evaluated daily vs. event-driven or intermittent PrEP in MSM; no studies on event-driven or intermittent dosing in women or PWID.
KQ2. Benefits of newer vs. older PrEP regimens: Oral TAF-FTC vs. TDF-FTC | HIV infection: k=1 new RCT (n=5,387) | TAF-FTC vs. TDF-FTC: 1 trial, 0.3% vs. 0.6%; RR, 0.53 (95% CI, 0.23 to 1.26); results within prespecified noninferiority margin | Unable to assess consistency (1 trial); some imprecision.; No reporting bias detected | Good | Single trial | Moderate for noninferiority of TAF-FTC (with potential benefit) | Trial was conducted in cisgender adult men and transgender women who have sex with men in Europe and North America
KQ2. Benefits of newer vs. older PrEP regimens: Long-acting injectable cabotegravir vs. daily oral TDF-FTC | HIV infection: k=2 new RCTs (n=7,668) | Cabotegravir vs. TDF-FTC:; −1 trial in MSM and transgender women (n=4,490): 0.6% vs. 1.7%; RR, 0.33, 95% CI 0.18 to 0.62); −1 trial in women (n=3,178): 0.3% vs. 2.3%; RR, 0.11 (95% CI 0.04 to 0.31) | Consistent; precise; No reporting bias detected | Good | Single trials conducted in different populations; both trials stopped early for meeting pre-specified efficacy threshold | High for reduced risk with cabotegravir | One trial conducted in MSM and transgender men in the United States, Latin America, Asia, and Africa and one trial conducted in women at increased risk of HIV infection in Africa. Cabotegravir has been FDA-approved for PrEP to prevent sexually acquired HIV infection
KQ3. Diagnostic accuracy of instruments for identifying persons at risk of incident HIV infection | k=12 studies of risk prediction or diagnostic accuracy (n=5,544,500); 7 studies in prior USPSTF review and 5 studies added | MSM: 5 studies (n=25,488 in validation cohorts); AUROC, 0.60 to 0.73 for different instruments in 5 studies; a sixth study reported better goodness of fit than with instruments evaluated in other studies (AUROC NR). AUROC, 0.49 to 0.75 for different instruments in 2 studies of Black MSM.; PWID: AUROC, 0.72 in 1 study (n=1,904); Women: Sensitivity 95% (21 cases); General populations: AUROC, 0.77 and 0.84 in two studies (n=33,404 and 606,701 in validation cohorts) | Consistent; precise (for MSM and general populations of HIV-uninfected persons); No reporting bias detected | Fair | Retrospective design; some instruments validated in 1 study or not validated in a cohort independent from the one used to develop the instrument; cutoffs not predefined in some studies. | Moderate (for MSM and general populations); low (for PWID and women) | All studies conducted in the U.S.; some studies utilized cohorts that included persons who underwent HIV testing prior to the year 2000.
KQ4. Harms of PrEP: Oral PrEP vs. placebo | Serious adverse events: k=12 RCTs (n=18,282); All RCTs in prior USPSTF review | RR, 0.93 (95% CI, 0.77 to 1.12); I^2^=56% | Some inconsistency; some imprecision; No reporting bias detected | Good | Small number of serious adverse events in most trials. Composite outcome, some trials had limited details on serious adverse events. | Moderate for no difference | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ4. Harms of PrEP: Oral PrEP vs. placebo | Withdrawals due to adverse events: k=4 RCTs (n=10,563); All RCTs in prior USPSTF review | RR, 1.25 (95% CI, 0.99 to 1.59); I^2^=0% | Consistent; some imprecision; No reporting bias detected, but most trials did not report withdrawals due to adverse events | Good | Most trials did not report withdrawals due to adverse events. Composite outcome, with variability in cause of withdrawal (clinical or laboratory adverse event) and whether adverse event temporary or permanent. | Moderate for increased risk with oral PrEP | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ4. Harms of PrEP: Oral PrEP vs. placebo | Renal adverse events: k=12 RCTs (n=18,170); All RCTs in prior USPSTF review | RR, 1.43 (95% CI, 1.18 to 1.75); I^2^=0%; ARD, 0.56% (95% CI, 0.09% to 1.04%) | Consistent; precise; No reporting bias detected | Good | Variability in definition of adverse renal events (most trials defined as ≥1 grade 1 serum creatinine elevations). | High for increased risk with oral PrEP | See Applicability for KQ1, Oral PrEP vs. Placebo. Most events were mild and reversible
KQ4. Harms of PrEP: Oral PrEP vs. placebo | Gastrointestinal adverse events: k=12 RCTs (n=18,300); All RCTs in prior USPSTF review | RR, 1.63 (95% CI, 1.26 to 2.11); I^2^=43%; ARD, 1.95% (95% CI, 0.48% to 3.43%) | Some inconsistency; precise; No reporting bias detected | Good | Composite outcome, with no difference for specific gastrointestinal adverse events. | High for increased risk with oral PrEP | See Applicability for KQ1, Oral PrEP vs. Placebo. Most events were mild and reversible.
KQ4. Harms of PrEP: Oral PrEP vs. placebo | Fracture: k=7 RCTs (n=15,241); All RCTs in prior USPSTF review | RR, 1.23 (95% CI, 0.97 to 1.56); I^2^=0% | Consistent; precise; No reporting bias detected | Moderate | Limited details on fracture site; most fractures traumatic in studies that provided this information. Results heavily weighted by 1 trial. | Low for increased risk with oral PrEP | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ4. Harms of PrEP: Oral PrEP vs. placebo | Syphilis: k=4 RCTs (n=10,775); All RCTs in prior USPSTF review | RR, 1.08 (95% CI, 0.98 to 1.18); I^2^=0% | Consistent; precise; No reporting bias detected, but NR in most trials | Good | Most trials were blinded, which might affect behaviors differently than when patients know they are on PrEP. | Moderate for no difference | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ4. Harms of PrEP: Oral PrEP vs. placebo | Gonorrhea: k=5 RCTs (n=9,296); All RCTs in prior USPSTF review | RR, 1.07 (95% CI, 0.82 to 1.39); I^2^=49% | Some inconsistency; some imprecision; No reporting bias detected, but NR in most trials | Good | Most trials were blinded, which might affect behaviors differently than when patients know they are on PrEP. | Moderate for no difference | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ4. Harms of PrEP: Oral PrEP vs. placebo | Chlamydia: k=5 RCTs (n=9,296); All RCTs in prior USPSTF review | RR, 0.97 (95% CI, 0.80 to 1.18); I^2^=59% | Consistent; precise; No reporting bias detected, but NR in most trials | Good | Most trials were blinded, which might affect behaviors differently than when patients know they are on PrEP. | Moderate for no difference | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ4. Harms of PrEP: Oral PrEP vs. placebo | Combined bacterial STIs: k=2 RCTs (n=5,291); All RCTs in prior USPSTF review | RR, 1.14 (95% CI, 0.97 to 1.34); I^2^=0% | Consistent; some imprecision; No reporting bias detected, but NR in most trials | Good | Most trials were blinded, which might affect behaviors differently than when patients know they are on PrEP. | Moderate for no difference | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ4. Harms of PrEP: Oral PrEP vs. placebo | Herpes simplex virus infection: k=3 RCTs (n=4,088); All RCTs in prior USPSTF review | RR, 0.85 (95% CI, 0.67 to 1.07); I^2^=19% | Some inconsistency; some imprecision; No reporting bias detected, but NR in most trials | Good | Trials were blinded, which might affect behaviors differently than when patients know they are on PrEP. | Moderate for no difference | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ4. Harms of PrEP: Oral PrEP vs. placebo | Hepatitis C virus infection: k=2 RCTs (n=896); All RCTs in prior USPSTF review | RR, 0.73 (95% CI, 0.25 to 2.10); I^2^=0% | Some inconsistency; imprecise; No reporting bias detected, but NR in most trials | Good | One trial was blinded, which might affect behaviors differently than when patients know they are on PrEP. | Low for decreased risk with oral PrEP | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ4. Harms of PrEP: Oral PrEP vs. placebo | Spontaneous abortion^†^: k=3 RCTs (n=415); All RCTs in prior USPSTF review | RR, 1.09 (95% CI, 0.79 to 1.50); I^2^=0% | Consistent; some imprecision; No reporting bias detected | Good | Analysis restricted to women who became pregnant in trials of PrEP and were taken off PrEP. | Moderate for no difference | Analyses of women at high risk of HIV infection via heterosexual contact who were taken off PrEP at time of pregnancy
KQ4. Harms of PrEP: Dapivirine vaginal ring vs. placebo | Serious adverse events: k=2 RCTs (n=4,587); Both RCTs added for update | RR, 1.73 (95% CI, 0.60 to 4.94); I^2^=80% | Inconsistent; very imprecise; No reporting bias detected | Good | Substantial heterogeneity; events varied widely and did not appear related to PrEP | Insufficient | See Applicability to KQ 2, Dapivirine vs. Placebo
KQ4. Harms of PrEP: Dapivirine vaginal ring vs. placebo | Syphilis: k=1 RCT (n=1,959); Added for update | 1.3% vs. 0.8% | Unable to assess consistency; some imprecision; No reporting bias detected | Good | Trial was blinded, which might affect behaviors differently than when patients know they are on PrEP. | Low for similar risk | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ4. Harms of PrEP: Dapivirine vaginal ring vs. placebo | Gonorrhea: k=2 RCTs (n=4,587); Both RCTs added for update | RR, 1.01 (95% CI, 0.80 to 1.27); I^2^=63% | Some inconsistency; precise; No reporting bias detected | Good | Trials were blinded, which might affect behaviors differently than when patients know they are on PrEP. | Moderate for no difference | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ4. Harms of PrEP: Dapivirine vaginal ring vs. placebo | Chlamydia: k=2 RCTs (n=4,587); Both RCTs added for update | RR, 0.98 (95% CI, 0.89 to 1.07); I^2^=0% | Consistent; precise; No reporting bias detected | Good | Trials were blinded, which might affect behaviors differently than when patients know they are on PrEP. | High for no difference | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ4. Harms of PrEP: Dapivirine vaginal ring vs. placebo | Any STI: k=1 RCT (n=1,959); Added for update | RR, 1.06 (95% CI, 0.96 to 1.16) | Unable to assess consistency; precise; No reporting bias detected | Good | Trial was blinded, which might affect behaviors differently than when patients know they are on PrEP. | Moderate for no difference | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ4. Harms of PrEP: Dapivirine vaginal ring vs. placebo | Pregnancy: k=2 RCTs (n=4,587); Both RCTs added for update | 3.9 vs. 4.0 per 100 person-years and 1.6 vs. 2.0 per 100 person-years | Consistent, precise; No reporting bias detected | Good | Trial was blinded, which might affect behaviors differently than when patients know they are on PrEP | High for no difference | See Applicability for KQ1, Oral PrEP vs. Placebo
KQ5: Harms of PrEP: TAF-FTC vs. TDF-FTC | Serious adverse events, discontinuation due to adverse events, or any adverse event: k=1 new RCT (n=5,387) | Serious adverse events: 7% vs. 7%; Discontinuation due to adverse events: 1% vs. 2%; Any adverse event: 94% vs. 94% | Unable to assess consistency; some imprecision; No reporting bias detected | Good | Adverse events varied and most did not appear related to PrEP | Moderate for no difference | See Applicability for KQ2, TAF-FTC vs. TDF-FTC
KQ5: Harms of PrEP: TAF-FTC vs. TDF-FTC | Renal adverse events: k=1 new RCT (n=5,387) | Any renal adverse event: 10% vs. 10%; Renal adverse event leading to discontinuation: 0.07% vs. 0.2% | Unable to assess consistency; some imprecision; No reporting bias detected | Good | Adverse events leading to discontinuation rare | Moderate for no difference | See Applicability for KQ2, TAF-FTC vs. TDF-FTC
KQ5: Harms of PrEP: TAF-FTC vs. TDF-FTC | Fracture, bone mineral density: k=1 new RCT (n=5,387) | Fracture: 2% vs. 2%; Hip bone mineral density (change from baseline): +0.6% vs. −1.0%, p<0.001; Spine bone mineral density (change from baseline): +0.9% vs. −1.4%, p<0.001 | Unable to assess consistency; precise; No reporting bias detected | Good | Duration may be insufficient to evaluate fracture risk | Moderate for increased bone mineral density with TAF-FTC | See Applicability for KQ2, TAF-FTC vs. TDF-FTC
KQ5: Harms of PrEP: TAF-FTC vs. TDF-FTC | Lipid parameters, weight gain: k=1 new RCT (n=5,387) | Low density lipoprotein cholesterol (change from baseline): median −0.05 vs. −0.18 mmol/L, p<0.0001; Weight gain (change from baseline): median +1.7 vs. +0.5 kg, p<0.0001 | Unable to assess consistency; precise; No reporting bias detected | Good | No additional limitations noted | Moderate for negative effects of lipids and weight gain with TAF-FTC | See Applicability for KQ2, TAF-FTC vs. TDF-FTC. Clinical significance of differences uncertain
KQ5: Harms of Injectable Cabotegravir vs. Oral TDF-FTC | Serious adverse events: k=2 new RCTs (n=7,786) | 5.3% vs. 5.3% and 2.0% vs. 2.0% | Consistent; precise; No reporting bias detected | Good | No additional limitations noted | High for no difference | See Applicability for KQ1, Cabotegravir vs. TDF-FTC.
KQ5: Harms of Injectable Cabotegravir vs. Oral TDF-FTC | Renal events, liver events, STIs: k=2 new RCTs (n=7,786) | No differences in renal events, liver events, or STIs | Consistent; precise; No reporting bias detected | Good | Trial was blinded, which might affect sexual risk behaviors differently than when patients know they are on PrEP. | High for no difference | See Applicability for KQ1, Cabotegravir vs. TDF-FTC.
KQ5: Harms of Injectable Cabotegravir vs. Oral TDF-FTC | Weight gain: k=2 new RCTs (n=7,786) | Mean differences 0.86 kg and 0.4 kg | Consistent; precise; No reporting bias detected | Good | No additional limitations noted | High for increased weight gain with cabotegravir | See Applicability for KQ1, Cabotegravir vs. TDF-FTC.
KQ5: Harms of Injectable Cabotegravir vs. Oral TDF-FTC | Injection site reactions: k=2 new RCTs (n=7,786) | 81.4% vs. 31.3% and 38.0% vs. 10.8% | Consistent; precise; No reporting bias detected | Good | No additional limitations noted | High for increased risk with cabotegravir | See Applicability for KQ1, Cabotegravir vs. TDF-FTC. Injection site reactions were usually mild and occurred most commonly with the first injection, with diminishing frequency over time
KQ5: Harms of Injectable Cabotegravir vs. Oral TDF-FTC | Pregnancy: k=1 new RCT (n=3,178) | 1.5 vs. 1.0 per 100 person-years | Unable to assess consistency; some imprecision; No reporting bias detected | Good | No additional limitations noted | Moderate for similar risk | See Applicability for KQ1, Cabotegravir vs. TDF-FTC. One trial evaluated pregnancy incidence among women in Africa.

* For KQs 1 and 5, number of participants included in analysis.

† In women who became pregnant while on PrEP.

Abbreviations: ARD=adjusted risk difference; aRR=adjusted relative risk; AUROC=area under the receiver operating characteristics curve; CI=confidence interval; FDA=U.S. Food and Drug Administration; FTC=emtricitabine; KQ=key question; MSM=men who have sex with men; NR=not reported; OR=odds ratio; PrEP=pre-exposure prophylaxis; PWID=persons who inject drugs; RCT=randomized, controlled trial; RR=relative risk; STI=sexually transmitted infection; TAF=tenofovir alafenamide; TDF=tenofovir disoproxil fumarate; U.S.=United States; USPSTF=United States Preventive Services Task Force.

As described in the prior USPSTF review, oral PrEP with TDF or TDF-FTC was associated with decreased risk of acquiring HIV infection compared with placebo or no PrEP (11 trials, RR 0.46, 95% CI 0.33 to 0.66, I^2^=67%).^51–55,66–68,118,137,170,172^ The absolute difference in risk of HIV infection was about 2 percent after 4 months to 4 years, for a number needed to treat with oral PrEP to prevent 1 case of HIV infection of about 50. In three trials conducted in the United States and Europe, each of which evaluated MSM (HIV incidence, 4% to 8% with placebo or no PrEP), the pooled absolute difference was larger at about 5 percent after 9 months to 2 years (range, 4% to 6%), for a number needed to treat with PrEP to prevent one case of incident HIV infection of about 20.^52,66,118^ Effects of PrEP on HIV infection risk were very similar for TDF alone (RR, 0.49 [95% CI, 0.28 to 0.84]; I^2^=58%) and TDF-FTC (RR, 0.44 [95% CI, 0.27 to 0.72]; I^2^=74%). However, TDF is not FDA-approved for use as PrEP and is no longer recommended as an alternative regimen in the 2021 CDC guideline.^84^ Although statistical heterogeneity was present in the pooled estimate, this was not related to use of TDF alone or TDF-FTC. On the other hand, there was a strong association between the degree of study-level adherence and estimates of effectiveness, when adherence was analyzed as either a categorical or continuous variable. In six trials in which adherence was 70 percent or greater, the pooled RR was 0.27 (95% CI, 0.19 to 0.39; I^2^=0%), with no statistical heterogeneity.^51,52,66,67,118,170^

Additional analyses also support an association between higher oral PrEP adherence and greater effectiveness, including within-study stratified analyses of trial participants stratified according to PrEP adherence level and analyses on the association between tenofovir levels in persons using PrEP and risk of HIV infection.^51,53,54,135,137,153,170,172^ Modeling based on trial data indicates that PrEP is highly effective in MSM taking four doses per week (estimated reduction in risk, 96%), and reduction in risk is substantial even at two doses per week (reduction in risk, 76%),^178^ suggesting important benefits of PrEP despite incomplete adherence. These findings also suggest the potential use of event-driven (targeted at periods of higher HIV risk) or intermittent (regular nondaily) dosing strategies in this population. One trial (IPERGAY) found event-driven PrEP in MSM associated with substantially reduced risk of HIV infection versus no PrEP (RR, 0.14 [95% CI, 0.03 to 0.63]).^66^ IPERGAY evaluated a population of MSM with relatively frequent sexual intercourse (median, 10 episodes per month) and dosing of PrEP (median, 15 doses per month), potentially reducing applicability to populations in which dosing is less frequent. However, a post hoc subgroup analysis of IPERGAY found that among adherent patients, event-driven PrEP among those who used 15 or fewer doses per month and those who used more than 15 pills per month appeared similarly effective, with no cases of incident HIV infection in either group.^129^

The applicability of evidence on effects of adherence and event-driven or intermittent dosing from studies of MSM to other populations is uncertain. Tenofovir accumulates rapidly and at high concentrations in rectal compared with vaginal tissue, which could reduce the effectiveness of nondaily dosing in women, in whom the primary mode of transmission is through receptive vaginal intercourse. A modeling study estimated that 98 percent or greater of the population achieved protective mucosal tissue levels by the third day of exposure with TDF-FTC, although six doses/week were required to protect the lower female genital tract, compared with two doses/week to protect colorectal tissue.^227^ On the other hand, simian studies have shown protective effects of tenofovir alafenamide from rectal simian HIV challenge despite low rectal mucosal concentrations, suggesting limited correlation between rectal or genital mucosal concentrations of tenofovir and protection from HIV infection.^228^ No study evaluated effectiveness of intermittent or event-driven dosing in women or PWID.

Findings regarding effectiveness of oral PrEP were robust in subgroup and stratified analyses based on HIV risk category (MSM, PWID, or persons at risk of HIV infection via heterosexual contact), study duration, study quality, age, and sex. However, evidence in PWID was limited to one trial conducted in Thailand in which most patients received directly observed therapy and sterile syringes were not provided (RR, 0.52 [95% CI, 0.29 to 0.92]),^53^ and all trials of persons at risk via heterosexual contact were conducted in Africa, which might reduce applicability to U.S. practice. Effects of PrEP were stronger in trials conducted in the United States, Europe, and Canada (RR, 0.13 [95% CI, 0.05 to 0.32]) than in studies conducted in Africa, Asia, or internationally (RR, 0.54 [95% CI, 0.37 to 0.79]); this could be related to high adherence in the North American and European trials or differences across countries in HIV epidemiology and management (e.g., differences in the proportion of partners with HIV treated with ART). No study evaluated effectiveness of PrEP according to a sexual partner with HIV’s use of ART or viral load.^52,66,118^ However, the 2021 CDC guideline notes that persons with HIV with a consistently undetectable viral load pose effectively no risk for HIV transmission to sexual partners. No randomized trial of PrEP enrolled adolescents, but in 2018 TDF-FTC was approved by the FDA for PrEP in adolescents weighing at least 35 kg. This decision was informed by a PrEP demonstration study in MSM ages 15 to 17 years that found a similar safety profile for TDF-FTC compared with the safety profile observed in adults.^183^

Evidence on beneficial effects of oral PrEP on clinical outcomes other than HIV infection was sparse. Oral PrEP was associated with a statistically nonsignificant reduction in mortality risk versus no PrEP or placebo (RR, 0.81 [95% CI, 0.59 to 1.11]; I^2^=0%), and trials were not designed to address this outcome.^51–55,66,67,118,137,170,172^ No trial reported effects of PrEP on quality of life, although observational and qualitative research suggests that PrEP may reduce anxiety or worry about getting HIV.^229–231^

Although oral PrEP was associated with some harms, most appeared relatively mild and reversible with PrEP discontinuation. PrEP was not associated with an increased risk of serious adverse events,^51–55,66–68,118,137,170,172^ and there was a statistically nonsignificant increased risk of withdrawal due to adverse events (RR, 1.25 [95% CI, 0.99 to 1.59]).^51,55,66,137,172^ PrEP was associated with increased risk of gastrointestinal events (RR, 1.63 [95% CI, 1.26 to 2.11]; ARD, 1.95%),^51–55,66–68,118,137,170,172^ that generally improved with longer duration of therapy. Consistent with renal effects of tenofovir, oral PrEP was also associated with an increased risk of renal insufficiency (RR, 1.43 [95% CI, 1.18 to 1.75]; ARD, 0.56%),^51–55,66–68,118,137,170,172^ which generally appeared to be mild and resolved with cessation of PrEP. Our finding of an increased risk of renal adverse events was consistent with another review that found oral PrEP associated with increased risk of grade 1 creatinine elevation or worse versus placebo (OR, 1.39 [95% CI, 1.09 to 1.71]).^232^ Consistent with effects of tenofovir on bone loss, PrEP was associated with a statistically nonsignificant increase in risk of fracture (RR, 1.23 [95% CI, 0.97 to 1.56]);^51–54,66,137,170^ results of the fracture meta-analysis were heavily weighted by the Bangkok Tenofovir Study of PWID.^53^ These findings are consistent with a recent systematic review that found oral PrEP associated with greater bone mineral density decline than placebo, with no statistically significant increase in risk of fractures.^233^ Studies with longer-term followup would be helpful for clarifying fracture risk, given the relatively short followup in the trials (4 months to 4 years) and potential long-term effects of tenofovir on bone density and fracture risk. Based on currently available shorter-term data, effects of PrEP on fracture risk appear small (ARD, 0.21%). One small new crossover trial found event-driven oral PrEP associated with decreased risk of short-term, mild adverse events, but was not designed to assess more serious or longer-term harms.^144^

A large new trial (DISCOVER) found oral daily TAF-FTC to be noninferior to TDF-FTC for incident HIV infection in primarily MSM (2% transgender women), and potentially associated with increased efficacy (RR 0.53, 95% CI 0.23 to 1.26).^121,162^ TAF-FTC was associated with positive short-term effects on bone mineral density versus TDF-FTC and negative effects on lipid parameters and weight gain, without differences in clinical adverse events including renal events and fractures, which require longer-term study. TAF-FTC is not approved for PrEP in women at risk for acquiring HIV infection from receptive vaginal sex because effectiveness has not been evaluated in this situation, and it is not recommended in the 2021 CDC guideline for this population.^84^

Among persons using oral PrEP, the rate of resistance mutations to tenofovir or emtricitabine appears low. Most cases of antiretroviral resistance occurred in persons who were infected with HIV at baseline, reinforcing the importance of clinical history and HIV testing to rule out HIV infection before initiating PrEP. Evidence to determine the effects of PrEP-selected antiretroviral resistance mutations on clinical outcomes is not available, but is likely to depend on the specific resistance mutation(s) present, impact on effectiveness of first-line ART, and availability of alternative (non-first-line) ART regimens, if needed.^234^ Patients with the most common PrEP-selected nucleoside reverse transcriptase inhibitor resistance mutations (K65R, M184I, M184V) can frequently be treated with INSTI or protease-inhibitor based regimens, with limited evidence indicating high rates of virological suppression in persons with these mutations.^199,200^ Furthermore, the number of HIV cases averted by PrEP appears to be substantially higher than the number of cases of antiretroviral resistance caused. Based on data from the Partners PrEP trial, there were an estimated 123 cases of HIV infection averted, compared with five cases of drug resistance.^146^

A concern about PrEP has been the potential for behavioral risk compensation. There was no association between PrEP and increased risk of bacterial STIs in RCTs.^51,118,137,170,172^ However, in most trials, patients were blinded to receipt of PrEP, which might affect sexual behaviors differently than when patients know they are using PrEP, as in clinical practice. One open-label trial (PROUD) found nonstatistically significant associations between PrEP and STIs in MSM, consistent with the higher prevalence of risky sexual behaviors among men randomized to PrEP that was observed in this trial.^118^ In addition, participants in randomized trials may differ from the general population of PrEP users, who may be at higher risk for STIs.^177^ A systematic review that included PROUD, the U.S. demonstration study, and other open-label, nonrandomized studies found PrEP associated with an increased risk of rectal chlamydia (4 studies; OR, 1.59 [95% CI, 1.19 to 2.13]), but no statistically significant association between PrEP and risk of chlamydia at any site (5 studies; OR, 1.23 [95% CI, 1.00 to 1.51]), STIs overall (8 studies; OR, 1.24 [95% CI, 0.99 to 1.54]), syphilis (6 studies; OR, 1.12 [95% CI, 0.86 to 1.47]), or gonorrhea (5 studies; OR, 1.13 [95% CI, 0.78 to 1.64]).^235^ The nonrandomized studies had methodological shortcomings, including use of a before-after study design, failure to adjust for differential STI testing rates, and use of self-report to determine STI rates before initiation of PrEP. Some data suggest that persons who engage in riskier behaviors tend to be more adherent to PrEP (see Contextual Question 1),^53,177,184^ which might result in greater benefits in terms of reduction in HIV incidence that could offset negative effects related to any increase in risky behaviors (e.g., STIs). There was no association between PrEP and risk of HSV infection,^120,150,170^ although some trials^120,170^ found decreased risk or a trend toward decreased risk, consistent with antiviral effects of tenofovir on HSV.^119,120^ Cases of acute hepatitis C virus infection have been reported in U.S. MSM using PrEP,^236^ but data from randomized trials are too limited to determine effects on risk of hepatitis C virus infection.^66,118^ In patients with chronic hepatitis B virus infection, very limited evidence suggests that cessation of oral PrEP is not associated with hepatitis flare.^55,169^ However, almost all randomized trials excluded patients with hepatitis B virus infection at baseline and some trials provided hepatitis B virus vaccination to eligible patients. One trial reported one case of incident hepatitis B virus infection,^54^ though this outcome was not a specified outcome in any trial.

Alternative PrEP regimens that do not require daily administration could improve utilization and adherence. One alternative to oral PrEP in women is the dapivirine vaginal ring, which was not addressed in the 2019 USPSTF review. The dapivirine vaginal ring was associated with decreased risk of infection versus a placebo ring in African women at increased risk of HIV infection (2 trials, RR, 0.71 [95% CI 0.57 to 0.89]), and had a favorable safety profile.^73,74^ However, efficacy versus placebo for preventing HIV infection was lower with the dapivirine vaginal ring than observed in trials of oral PrEP. Open-label extension studies suggest greater adherence and effectiveness in women enrolled in the RCTs who chose to continue with the dapivirine ring, but utilized simulated control groups.^111,112^ The dapivirine ring has not been FDA-approved and has been withdrawn from the manufacturer from further FDA review.

Another alternative to oral PrEP is long-acting injectable cabotegravir, which involves a bimonthly injection. Long-acting injectable cabotegravir was associated with greater reduction in risk of HIV infection than oral TDF-FTC in one new trial of MSM and transgender women (0.6% vs. 1.7%; RR, 0.33 [95% CI, 0.18 to 0.62]^70^ and one new trial of African women at high risk of HIV infection (0.3% vs. 2.3%; RR, 0.11 [95% CI, 0.04 to 0.31]).^88^ Cabotegravir was associated with increased risk of injection site reactions that were usually mild and decreased in frequency following the initial injection, and weight gain (<1 kg). A potential concern with cabotegravir is the prolonged pharmacologic tail (period of declining drug levels) when injections are discontinued or delayed. Low drug levels during the pharmacologic tail could select for antiretroviral drug resistance mutations if HIV infection is acquired.^237,238^ Resistance to one integrase strand transfer inhibitor such as cabotegravir is of concern because it may result in cross-resistance with other integrase strand transfer inhibitors, potentially limiting the use of first-line antiretroviral therapy regimens. Although randomized trials of cabotegravir reported a low incidence of INSTI resistance mutations among persons randomized to this regimen, one trial^70^ reported a high proportion of patients with incident HIV infection had an INSTI mutation. No cases of INSTI resistance mutations acquired following cessation of cabotegravir during the pharmacologic tail period were identified. Longer-term implementation and other studies are required to clarify incidence and consequences of INSTI resistance mutations acquired in persons using cabotegravir for PrEP. Cabotegravir is FDA-approved for use in at-risk adults and adolescents (≥35 kg) to reduce the risk of sexually acquired HIV infection.^75^

Data on effects of PrEP in pregnancy remains limited. Trials excluded pregnant persons and discontinued PrEP in persons who became pregnant. Among persons who became pregnant in the trials, oral PrEP was not associated with increased risk of spontaneous abortion^68,157,172^ or other adverse pregnancy outcomes. Observational studies also indicate no increased risk of adverse pregnancy outcomes among persons with prenatal exposure to oral PrEP.^239,240^ A systematic review of persons infected with HIV or hepatitis B virus who received tenofovir during pregnancy (not for PrEP) found mild to moderate maternal and infant harms that were not considered to be tenofovir-related, no increased risk of growth or bone abnormalities in infants exposed in utero, and no increased risk of congenital abnormalities.^241^ FDA labeling information and perinatal antiretroviral treatment guidelines permit use of TDF-FTC (an FDA pregnancy category B drug) during pregnancy.^84^ Although the FDA-approved label recommends that nursing mothers not breastfeed if they are taking TDF-FTC and data on safety in breastfeeding infants are lacking, the 2021 CDC guideline^84^ notes limited exposure via breast milk. Evidence on safety of cabotegravir for PrEP in pregnant or breastfeeding persons is very sparse, although one trial88 reported no congenital abnormalities in infants with in utero exposure to PrEP.

Understanding PrEP uptake, adherence, and persistence in U.S. primary care and primary care—applicable settings could be useful for assessing applicability of RCTs, which were primarily conducted in low-income settings, and inform efforts for successful implementation of PrEP. Available evidence primarily focused on use of oral PrEP. Disparities in oral PrEP utilization have been reported, with decreased utilization among PWID, transgender women, and adolescents.^93^ Some studies have found disparities in utilization by race/ethnicity,^107,204,205^ though findings were inconsistent. Evidence on primary care interventions to increase utilization was limited but suggested that behavioral and educational interventions tailored to specific populations (e.g., young and/or Black MSM) can increase utilization, potentially reducing disparities.^213–216^ Evidence on effects of telehealth for PrEP on utilization and other outcomes is extremely limited, though RCTs are in progress. Studies of U.S. MSM found that adherence based on documentation of highly protective drug levels varied widely (22% to 90%), with lower levels of adherence in younger MSM; adherence also tended to decrease over time.^177,183–186^ Other factors associated with decreased adherence include non-White race, lower socioeconomic status, presence of other adverse social determinants; a factor associated with increased adherence was presence of higher-risk behaviors, indicating that patients may vary adherence according to degree of risk.^242^ In MSM, discontinuation of oral PrEP is frequent, and appears related to factors similar to those associated with decreased adherence.^177,185,187,192–194^ One RCT of U.S. MSM found higher adherence with daily than intermittent or event-driven PrEP.^136^ Evidence on PrEP utilization, adherence, and persistence in populations other than MSM (e.g., PWID, persons at risk due to vaginal intercourse, transgender persons) remains limited.

However, trials of MSM and transgender women and women at risk due to vaginal intercourse indicate that long-acting injectable cabotegravir is associated with higher adherence (based on lack of delayed or discontinued injections) than oral PrEP (based on protective dried blood spot levels).^70,88^

Instruments that are accurate for predicting risk of incident HIV infection could help inform decisions regarding eligibility for PrEP. Five instruments for predicting incident HIV infection in MSM found moderate discrimination (AUROC estimates ranged from 0.60 to 0.73),^140,155,165,166,171^ though some instruments require further validation. All studies applied instruments retrospectively and some instruments were developed using data from older cohorts in which the effects of factors associated with HIV incidence (e.g., nitrates, amphetamines) may differ from contemporary populations. In general populations of HIV-negative persons, two large studies found two new instruments had moderate to high discrimination (AUROC 0.77 and 0.84) for predicting incident HIV infection.^143,151^ Both instruments utilized a computerized algorithm on items extracted from the electronic medical record.

## Limitations

Our review had limitations. As statistical heterogeneity was anticipated in pooled analyses, we used the DerSimonian and Laird random-effects model to pool studies. The DerSimonian and Laird random-effects model may result in CIs that are too narrow when heterogeneity is present, particularly when the number of studies is small.^125^ Therefore, we repeated analyses in which statistical heterogeneity was present using the profile likelihood method; these sensitivity analyses resulted in similar findings. To explore statistical heterogeneity, we also performed sensitivity and subgroup analyses based on adherence level, study quality, duration of followup, HIV risk category, PrEP regimen, and geographic setting. Although statistical heterogeneity remained present in some analyses, results consistently favored PrEP, although estimates varied according to level of adherence and geographic setting. We did not have access to individual patient data. Therefore, our findings are based on analyses of study-level data and our ability to analyze subgroup effects was restricted to published reports. We excluded non-English—language articles, which could result in language bias. However, some research suggests that English-language restriction has little effect on the conclusions of systematic reviews of non-complementary medicine topics, and we did not identify large non-English trials of PrEP versus placebo in other systematic reviews.^243,244^ We only assessed for publication bias using statistical and graphical methods to assess for small sample effects when there were at least 10 studies, as research indicates that such methods can be misleading with smaller numbers of studies.^127^ Funnel plot asymmetry was present (Appendix C Figure 1) for the outcome of HIV infection and a test for small sample effects was statistically significant. Although small sample effects may be due to publication bias, graphical and statistical tests can be difficult to interpret in the presence of other factors that could influence study results, such as differences across trials in geographic setting, adherence levels, HIV risk category, and other factors. We identified no unpublished trials of PrEP in searches on a clinical trials database (clinicaltrials.gov). Our primary analyses were based on data reported in journal publications. In three trials included in the FDA medical review of PrEP with tenofovir and emtricitabine, there were some discrepancies between the journal articles and the FDA report for numbers of HIV cases and fractures.^126^ In the iPrEx trial, more HIV infections in both the PrEP and placebo arms were reported in the FDA review than in the journal publication.^137^ A sensitivity analysis that used the FDA data resulted in similar results for iPrEx (RR, 0.58 [95% CI, 0.41 to 0.82]) compared with results in the journal publication (RR, 0.53 [95% CI, 0.36 to 0.77]) and no change in the pooled estimate (RR, 0.45 [95% CI, 0.30 to 0.66]). Similarly, although there were some discrepancies in fractures rates between the journal publications and the FDA review of the iPrEx, Partners PrEP, and CDC Safety Study trials, a sensitivity analysis using FDA data did not affect the estimate for fracture risk. Although publication and reporting bias may be associated with industry funding, few PrEP trials reported receipt of industry support, with support in those trials primarily consisting of provision of study drugs. Stratified analyses did not indicate better results for PrEP in trials that reported some industry support. However, some trials that received donated study drugs may not have reported it, which could have resulted in some misclassification.

## Emerging Issues/Next Steps

Alternative PrEP regimens that are easier to tolerate, do not require daily administration, are not associated with adverse renal and gastrointestinal effects, do not select for drug resistance, and achieve protective levels could increase the effectiveness of PrEP, improve the balance of benefits to harms, and facilitate greater uptake of PrEP. In addition to oral TAF-FTC, the dapivirine vaginal ring and long-acting injectable cabotegravir, which were not evaluated in the prior USPSTF review but added for this report, other PrEP regimens that have been studied include oral maraviroc,^113–115^ tenofovir vaginal gel,^54,116,117^ and injectable rilpivirine. However, these regimens have not been approved by the FDA, have limited evidence of effectiveness or evidence of low effectiveness, and are not recommended in clinical practice guidelines. Trials of long-acting (every 6 months) injectable lenacapavir (an HIV-1 capsid inhibitor) for PrEP are currently in progress, with expected completion in 2027.^245,246^

PrEP could also be delivered as a biodegradable, long-acting subcutaneous implant.^247^ A potential advantage of implants over long-acting injectable formulations is that they could be removed if needed without a prolonged pharmacological tail period. However, a review of nonclinical animal model studies of TAF hemifumarate subcutaneous implants identified safety and tolerability issues judged sufficiently concerning by the Gates Foundation to no longer pursue clinical development.^248^ Islatravir, a nucleoside reverse transcriptase translocation inhibitor, has been evaluated in oral and implant formulations for PrEP but studies have been put on clinical holds by the FDA due to observations of decreases in total lymphocyte and CD4+ T-cell counts in some patients receiving islatravir.^249^ Broadly neutralizing HIV-1 monoclonal antibodies were not effective for reducing risk of HIV acquisition in initial trials,^250^ though further research is underway.^251^

Emerging areas to improve uptake of PrEP include use of telehealth for PrEP (see Contextual Question 6), same-day PrEP initiation,^252^ and various behavioral, educational, peer support/mentoring, decision aids, and other interventions (see Contextual Question 5).

## Relevance for Priority Populations

In the U.S., HIV disproportionately affects racial/ethnic minorities, in particular Black and Hispanic persons. One trial found no difference in effectiveness of PrEP between Hispanic and non-Hispanic persons,^137^ and trials found PrEP to be effective in diverse racial/ethnic populations worldwide. Among PrEP-eligible individuals, PrEP coverage is substantially higher among White compared to Black or Hispanic/Latinx individuals, suggesting potential disparities in utilization.^253^ As described in Contextual Question 4, however, evidence indicating presence of disparities in utilization by race/ethnicity are somewhat inconsistent and may be attenuated after controlling for other factors associated with PrEP utilization, such as age, sex and gender, socioeconomic status, and other social determinants. Regardless, race and ethnicity are often correlated with the presence of social determinants that drive disparities in PrEP utilization.

Although PrEP was associated with decreased risk of HIV infection in women at high risk of acquisition via heterosexual contact, all trials of this population were conducted in Africa. As described in Contextual Question 4, some data suggest disparities in the United States with regard to implementation of PrEP in women. Data on the number of pregnant or lactating women on PrEP in the United States are not available, but use in these populations is likely to be low.

Data on PrEP in transgender women remains limited, though one survey using a national probability sample found that PrEP was only utilized in 3 percent of respondents who had sex with cisgender men and/or transgender women.^106^ Barriers to PrEP use in transgender individuals include lack of knowledge, unfavorable attitudes toward PrEP, and stigma.^106,212,254^ Although it is unlikely that there are significant drug interactions between gender-affirming hormone treatments and PrEP,^255^ some evidence indicates small interaction effects of uncertain clinical significance.^256,257^ Randomized trials that included transgender women have not been powered to evaluate effectiveness in transgender individuals. A post hoc analysis of iPrEx^137^ found that PrEP was effective in MSM (HR, 0.50 [95% CI, 0.34 to 0.75]) but not in transgender women (HR, 1.1 [95% CI, 0.5 to 2.7]), although the interaction was not statistically significant (p=0.09),^134^ precluding reliable conclusions regarding decreased effectiveness in transgender women. In the iPrEx trial, adherence was lower in transgender women than in MSM, particularly among those who reported receptive anal intercourse without a condom. In addition, there was an association between TFV drug level detectability and decreased risk of HIV infection, highlighting adherence as a potentially important implementation challenge in transgender individuals. The DISCOVER trial, which compared TAF-FTC versus TDF-FTC, enrolled 2 percent transgender women; no cases of HIV infection occurred in this group in either arm.^121,162^ In HPTN 083, which enrolled 13% transgender women who have sex with men, efficacy was similar in MSM (HR 0.35, 95% CI 0.18 to 0.68) and transgender women (HR 0.34, 95% CI 0.08 to 1.56), suggesting cabotegravir as a potential option in transgender persons with suboptimal adherence on oral PrEP.^70^ No PrEP trial enrolled transgender men and data on the prevalence of HIV infection in this population are lacking.^258^

Evidence on the effectiveness of PrEP in persons at risk due to injection drug use remains limited. One Asian trial found oral PrEP to be effective in PWID.^53^ Uptake of PrEP in PWID appears relatively low (see Contextual Question 4), though surveys indicate opportunities to improve utilization, based on the proportion expressing willingness to take PrEP.^259,260^

The FDA has approved daily oral TDF-FTC, daily oral TAF-FTC, and injectable cabotegravir in adolescents weighing at least 35 kg who otherwise meet indications for use of these regimens as PrEP. Although 22 percent of new HIV Infections in 2018 occurred in adolescents, data on PrEP initiation from the manufacturer indicated that less than 5 percent of individuals receiving new PrEP in 2012 were adolescents, indicating marked underutilization.^261^ In addition to decreased uptake, other barriers to implementation of PrEP in adolescents include lower adherence and persistence (see Contextual Question 1) and potential privacy issues (e.g., for adolescents who may receive PrEP while on their parents’ insurance plan).

## Future Research

Research is needed to clarify the comparative effectiveness and harms of alternative PrEP regimens, including oral TDF-FTC, oral TAF-FTC, and injectable cabotegravir; to determine the comparative effectiveness and harms of daily versus event-driven or intermittent oral PrEP; and to identify effective interventions to improve PrEP uptake, adherence, and persistence (including telehealth approaches and same-day PrEP initiation). Studies comparing TAF-FTC and TDF-FTC should have sufficient power and duration to evaluate whether short-term differences in renal function, bone mineral density, lipid parameters, and weight gain are associated with differences in long-term clinical outcomes. In addition, studies are needed to determine whether TAF-FTC is effective in populations other than MSM, including women at risk due to vaginal intercourse. For cabotegravir, longer-term follow-up and implementation studies are needed to assess adherence in clinical practice and the durability of observed benefits as well as the risk of and clinical consequences of integrase strand transfer inhibitor resistance mutations.

Randomized trials and implementation studies of PrEP in U.S. populations of women at high risk via vaginal intercourse and PWID would be useful to verify the applicability of trials conducted in low-income settings to the United States, including the effectiveness of PrEP in primary care settings. Studies should measure adherence and evaluate the association between adherence and effectiveness, particularly among persons with HIV exposure through cervico-vaginal tissue or blood (i.e., injection drug use). Research is needed to confirm the safety and effectiveness of PrEP during pregnancy or lactation and in gender nonconforming persons, the effectiveness and long-term safety (e.g., bone effects) of PrEP in adolescents, and to understand effects of PrEP on quality of life (including sexual health). To accurately assess effects of PrEP in different populations, studies should collect accurate information on sex and gender identity. Studies on factors associated with adherence and methods for increasing PrEP uptake, adherence, and persistence would be very helpful for guiding strategies for successful implementation, particularly in populations with low adherence, such as adolescents and various racial/ethnic groups, and other underserved populations based on socioeconomic status, insurance status, educational level, health literacy, and other social determinants of health.

Additional research would help to further clarify effects of PrEP related to behavioral risk compensation. Open-label studies, including observational studies that include a concurrent no-PrEP comparison group or compare alternative PrEP regimens and account for differential STI testing rates, would be helpful for understanding behavioral risk compensation effects in clinical practice. Research is also needed to clarify whether oral PrEP confers protective effects against HSV and how any observed effects on HSV affect HIV acquisition risk; determine effects of PrEP on hepatitis C virus infection, particularly in populations at high risk of hepatitis C virus (e.g., PWID, MSM); and determine whether PrEP reduces risk of hepatitis B infection^262^ (due to the antiviral effects of tenofovir and emtricitabine) and verify the safety of PrEP in persons with chronic hepatitis B virus infection.

Research is also needed to further develop and validate instruments for identifying persons at high risk of acquiring HIV infection, particularly for populations other than MSM. Studies should perform validation in independent cohorts, ideally using more current cohorts with prospective application of risk assessment instruments and assessment of HIV incidence, and should be applicable to diverse racial/ethnic groups. For identifying persons eligible for PrEP among general populations of uninfected individuals, studies are needed to verify the accuracy and impact of automated computerized algorithms using electronic medical records data.^143,151^

## Conclusions

In adults at increased risk of HIV infection, oral PrEP with TDF or TDF-FTC is associated with decreased risk of HIV infection compared with placebo or no PrEP, although effectiveness decreases with inadequate adherence. TAF-FTC was non-inferior to TDF-FTC in MSM and long-acting injectable cabotegravir was associated with decreased risk of HIV infection versus TDF-FTC in MSM or transgender women and women at higher risk for HIV infection. Instruments for predicting risk of incident HIV infection have moderate discrimination in MSM and moderate to high discrimination in general populations of persons without HIV infection.