# Chapter 3 Results

A total of 2,576 new references from electronic database searches, manual searches of recently published studies, and prior report references were reviewed, and 208 full-text papers were evaluated for inclusion. Across all KQs, 32 studies (reported in 61 publications) were included (20 RCTs [N=36,575] and 12 diagnostic accuracy studies [N=5,544,500]).^51–55,66–68,70,73,74,88,118,120,121,128–173^ Fourteen RCTs^51–55,66–68,118,120,128,130,133–139,141,146–150,152–154,156–161,168,170,172,173^ and 7 diagnostic accuracy studies^131,140,142,145,155,166,167^ (in 45 publications) were carried forward from the 2019 USPSTF review; six RCTs^70,73,74,88,121,144,162,163^ (including 2 RCTs of dapivirine^73,74^) and 5 diagnostic accuracy studies^143,151,164,165,171^ were new, and 3 new publications reported additional outcome or analyses for previously included trials1^29,132,169^ (in 16 publications). Included studies and quality ratings are described in Appendix B.

## Key Question 1 What Are the Benefits of PrEP in Persons Without Pre-Existing HIV Infection vs. Placebo or No PrEP (Including Deferred PrEP) on the Prevention of HIV Infection and Quality of Life?

### Summary

#### Oral PrEP vs. Placebo or No PrEP

- Oral PrEP with TDF-FTC or TDF was associated with decreased risk of HIV infection versus placebo or no PrEP in populations at higher risk of acquiring HIV (11 trials, N=18,172; relative risk [RR], 0.46 [95% CI, 0.33 to 0.66], I^2^=67%; absolute risk reduction [ARR], −2.0% [95% CI, −2.8 to −1.2%] after 4 months to 4 years).^51–55,66,67,118,137,170,172^
- There was a strong association between degree of adherence and oral PrEP effectiveness (p<0.00001 for interaction)
  ○ Adherence ≥70%: 6 trials; RR, 0.27 [95% CI, 0.19 to 0.39]; I^2^=0%^51,52,66,67,118,170^
  ○ Adherence >40% to <70%: 3 trials; RR, 0.51 [95% CI, 0.38 to 0.70]; I^2^=0%^53,55,137^
  ○ Adherence ≤40%: 2 trials; RR, 0.93 [95% CI, 0.72 to 1.20]; I^2^=0%^54,172^
- Oral PrEP with TDF-FTC or TDF alone was consistently associated with decreased risk of HIV infection versus placebo when trials were stratified according to HIV risk category, study duration, setting (high- or low-income), and study quality, and in subgroup analyses based on age^51,53,137,172^ and gender.^51,53,170^
- Effects of oral PrEP versus placebo or no PrEP on risk of HIV infection were similar with TDF alone (RR, 0.49 [95% CI, 0.28 to 0.84]; I^2^=58%) and TDF-FTC (RR, 0.44 [95% CI, 0.27 to 0.72]; I^2^=74%); all trials evaluated daily PrEP, with the exception of one trial^66^ of event-driven PrEP in MSM (RR, 0.14 [95% CI, 0.03 to 0.63]).
- Oral PrEP with TDF-FTC or FTC was associated with a statistically nonsignificant reduced risk of mortality versus no PrEP or placebo (9 trials; RR, 0.81 [95% CI, 0.59 to 1.11]; I^2^=0%).^51–55,118,137,170,172^
- No trial reported the association between oral PrEP versus placebo or no PrEP and quality of life.

#### Dapivirine Vaginal Ring vs. Placebo Ring

- The dapivirine vaginal ring was associated with decreased risk of HIV infection versus placebo ring in African women at increased risk of HIV infection (2 trials, N=4,564; RR 0.71 [95% CI, 0.57 to 0.89], I^2^=0%; ARR −2.23% [95% CI −3.75% to −0.74%] at 1.4 to 1.6 years).^73,74^

### Evidence

#### Oral PrEP vs. Placebo or No PrEP

Twelve RCTs, all included in the prior USPSTF report, evaluated PrEP versus placebo or no PrEP (Table 2; Appendix B Tables 1–3). The trials were reported in 32 publications; 29^51–55,66–68,118,128,133,134,137,139,146,148–150,152,153,156–159,161,168,170,172,173^ were included in the prior report, and three publications were added^129,132,169^ for this update. The prior USPSTF review reported efficacy data for HIV infection from all trials; both publications added for this update were secondary publications reporting an additional outcome or analysis from IPERGAY,^66^ a previously included trial.

Table 2 Study Characteristics of Placebo-Controlled RCTs of PrEP

Type of PrEP | Study name; Author, year^*^; Country; Duration of followup; Quality | Interventions^†^ | HIV risk group(s); Risk-based inclusion criteria | Patient characteristics | Adherence (method for measuring adherence)
Oral PrEP Versus Placebo or No PrEP | Bangkok Tenofovir Study; Choopanya, 2013^53^; Thailand; 4 years (mean); Good | A. TDF 300mg (n=1,204); B. Placebo (n=1,209) | PWID:; Injection drug use in the previous 12 months | [underlined: A vs. B]; Age 20 to 29: 43% vs. 43%; Age 30 to 39: 38% vs. 37%; Age 40 to 49: 15% vs. 15%; Age 50 to 60: 5% vs. 5%; Male: 80% vs. 80%.; Race: NR | 67% (plasma, tenofovir detectable)
Oral PrEP Versus Placebo or No PrEP | FEM PrEP; Van Damme 2012^172^; Kenya, South Africa, Tanzania; 1 year; Good | A. TDF-FTC 300/200mg (n=1,062); B. Placebo (n=1,058) | High-risk women:; >1 vaginal sex acts in previous 2 weeks or >1 sex partner in the previous month | [underlined: A vs.B]; Age (mean): 24 vs. 24 years; Female: 100%; Race: NR | 37% (plasma, tenofovir level ≥10 ng/mL [consistent with dose in last 48 hours])
Oral PrEP Versus Placebo or No PrEP | CDC Safety Study; Grohskopf 2013; U.S.^52^; 2 years; Good | A. TDF 300 mg (n=201); B. Placebo (n=199) | MSM:; Biological male engaging in anal sex with another man in the previous 12 months | [underlined: A vs. B]; Age (mean): 38 vs. 37 years; Male: 100% vs. 100%; White: 79.6% vs. 66.8%; African American: 23% vs. 37%; Asian/Pacific Islander: 10% vs. 4%; Other race: 8% vs. 25% | 93% (pill count)
Oral PrEP Versus Placebo or No PrEP | IAVI Uganda Study; Kibengo 2013^68^; Uganda; 4 months; Good | A. TDF-FTC 300/200mg (n=24); B. Intermittent TDF-FTC (n=24); C. Daily placebo (n=12); D. Intermittent placebo (n=12) | High-risk heterosexual men and women:; Unprotected vaginal sex with ART-naive HIV-infected partner in the previous 3 months | [underlined: A vs. B vs. C vs. D]; Age (mean): 33 vs. 33 vs. 33 vs. 33 years; Female: 50% vs. 46% vs. 67% vs. 42%; Race NR | 98% (MEMS [daily dosing])
Oral PrEP Versus Placebo or No PrEP | IAVI Kenya Study; Mutua 2012^67^; Kenya; 4 months; Good | A. TDF-FTC 300/200mg (n=24); B. Intermittent TDF-FTC (n=24); C. Daily placebo (n=12); D. Intermittent placebo (n=12) | MSM and high-risk women:; Current or previous STI, multiple episodes of unprotected vaginal or anal sex, or engaging in transactional sex in the previous 3 months | [underlined: A vs. B vs. C vs. D]; Age (mean): 26 vs. 26 vs. 27 vs. 28 years; Female: 12% vs. 0% vs. 8% vs. 8%; Race: NR | 82% (MEMS [daily dosing])
Oral PrEP Versus Placebo or No PrEP | IPERGAY; Molina 2015^66^; France, Canada; 9 months (median); Good | A. On-demand TDF-FTC 300/200mg (n=199); B. Placebo (n=201) | MSM:; Unprotected anal sex with at least two partners in the previous 6 months | [underlined: A vs. B]; Age (median): 35 vs. 34 years (IQR 29-43); Female: 0%; White: 94% vs. 89%; other races; NR | 86% (plasma, tenofovir detectable)
Oral PrEP Versus Placebo or No PrEP | iPrEx; Grant 2010^137,159^; Brazil, Ecuador, Peru, Thailand, South Africa, United States; 1.2 years (median); Good | A. TDF-FTC 300/200 mg (n=1,251); B. Placebo (n=1,248) | Men who have sex with men:; Anal sex with ≥4 male partners, a diagnosis of an STI, history of transactional sex activity, condomless anal sex with an HIV-infected partner or partner of unknown infection status in the previous 6 months | [underlined: A vs. B]; Ages 18 to 24 years: 47% vs. 53%; Ages 25 to 29 years: 22% vs. 19%; Ages 30 to 39 years: 20% vs. 18%; Age ≥40 years: 11% vs. 10%; Born male: 100% vs. 100%; Black: 9% vs. 8%; White: 18% vs. 17%; Mixed race or other: 68% vs. 70%; Asian: 5% vs. 5%; Hispanic: 72% vs. 73% | 48% (plasma, tenofovir or FTC detectable)
Oral PrEP Versus Placebo or No PrEP | Partners PrEP; Baeten 2012^51^; Kenya, Uganda; 2 years (median); Good | A. TDF 300 mg + placebo TDF-FTC (n=1,571); B. TDF-FTC 300/200 mg + placebo TDF (n=1,565); C. Placebo TDF + placebo TDF-FTC (n=1,570) | High-risk heterosexual men and women:; ART-naive HIV-infected partner | [underlined: A vs. B vs. C]; Ages 18 to 24 years: 12% vs. 11% vs. 11%; Ages 25 to 34 years: 46% vs. 44% vs. 43%; Ages 35 to 44 years: 30% vs. 32% vs. 32%; Age ≥45 years: 13% vs. 14% vs. 13%; Male: 62% vs. 64% vs. 61%; Race: NR | 82% (plasma, tenofovir detectable)
Oral PrEP Versus Placebo or No PrEP | PROUD; McCormack 2016^118^; England; 1 year; Fair | A. Immediate TDF-FTC 245/200 mg (n=275); B. TDF-FTC deferred for 1 year (n=269) | Men who have sex with men:; Anal intercourse without a condom in the previous 90 days and likely to have anal intercourse without a condom in the next 90 days | [underlined: A vs. B]; Age (mean): 35 vs. 35 years; Male: 100% vs. 100%; White: 81% vs. 83%; Asian: 5% vs. 6%; Black: 4% vs. 4%; Other race: 10% vs. 8% | 100% (plasma, tenofovir detectable)^‡^
Oral PrEP Versus Placebo or No PrEP | Study of TDF; Peterson 2007^55^; Cameroon, Ghana, Nigeria; 6 months (mean); Good | A. TDF 300 mg (n=469); B. Placebo (n=467) | High-risk women:; Average of ≥3 coital acts per week and ≥4 sexual partners per month | [underlined: A vs. B]; Age (mean): 24 vs. 24 years; 100% female; Race: NR | 69% (pill count)
Oral PrEP Versus Placebo or No PrEP | TDF2; Thigpen 2012^170^; Botswana; 1 year (median); Good | A. TDF-FTC 300/200 mg, (n=611); B. Placebo (n=608) | High-risk heterosexual men and women:; Sexually active in high-prevalence area | [underlined: A vs. B]; Ages 18 to 20 years: 2% vs. 3%; Ages 21 to 29 years: 90% vs. 87%; Ages 30 to 39 years: 8% vs. 10%; Female: 46% vs. 46%; Race: NR | 80% (plasma, tenofovir detectable)
Oral PrEP Versus Placebo or No PrEP | VOICE; Marrazzo 2015^54^; South Africa, Uganda, Zimbabwe; 3 years (maximum); Good | A. TDF 300 mg + placebo (n=1,007); B. TDF-FTC 300/200 mg + placebo (n=1,003); C. Placebo only (n=1,009) | High-risk women:; Sexually active in a high-prevalence area | [underlined: A vs. B vs. C]; Age (mean): 26 vs. 25 vs. 25 years; Female: 100% all groups; Race: NR | 30% (plasma, tenofovir detectable)
Dapivirine Vaginal Ring Versus Placebo Ring | ASPIRE; Baeten, 2016^73^; Malawi, South Africa, Uganda, Zimbabwe; 2.6 years (maximum); 1.6 years (median); Fair | A. Dapivirine 25 mg vaginal ring (n=1,313); B. Placebo vaginal ring (n=1,316) | High-risk women:; Sexually active in a high-prevalence area | [underlined: A vs. B]; Age (mean): 27.2 vs. 27.3; Female: 100%; Race: NR | 82% (plasma, dapirivine level >95 pg/mL)
Dapivirine Vaginal Ring Versus Placebo Ring | Ring Study; Nel, 2016^74^; South Africa, Uganda; 2 years; Fair | A. Dapivirine 25 mg vaginal ring (1,307); B. Placebo vaginal ring (n=652) | High-risk women:; Sexually active in a high-prevalance area | [underlined: A vs. B]; Age (mean):25.9 vs. 26.1; Female: 100%; Black: 99.4% vs. 98.5%; Other: 0.6% vs. 1.5% | 84% (plasma, dapivirine level ≥95 pg/mL)

* Primary publication.

† Daily, oral dose unless specified.

‡ Sample of patients who reported that they were taking PrEP.

Abbreviations: ART=antiretroviral therapy; ASPIRE=Antiretroviral Strategy to Promote Improvement and Reduce Exposure; FTC=emtricitabine; iPrEx=Pre-Exposure Prophylaxis Initiative; MEMS=medication event monitoring system NR=not reported; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; RCTs=randomized, controlled trials; STI=sexually transmitted infection; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Of the 12 trials of oral PrEP, two^67,68^ enrolled 72 patients each; in the other 10 trials, the sample sizes ranged from 400 to 4,726 (total N=18,244). Duration of followup ranged from 4 months to 4 years. Eleven trials randomized patients to PrEP or placebo. The other open-label trial randomized patients to immediate versus delayed PrEP (no PrEP for 1 year, after which patients received PrEP).^118^ Six trials^51,54,55,68,170,172^ enrolled men and women at increased risk of HIV infection due to heterosexual contact, four trials^52,66,118,137^ enrolled MSM or transgender women, one trial^67^ enrolled both MSM and high-risk women, and one trial^53^ enrolled PWID. The mean age in all trials was younger than age 40 years. No trial enrolled pregnant women or persons younger than age 18 years.

Three trials^52,53,55^ evaluated TDF 300 mg, six trials^66–68,137,170,172^ evaluated TDF 300 mg-FTC 200 mg, one trial^118^ evaluated TDF 245 mg-FTC 200 mg, and two trials^51,54^ evaluated both TDF 300 mg alone and TDF 300 mg-FTC 200 mg. PrEP was prescribed daily in 11 trials^51–55,67,68,118,137,170,172^ and dosing was intermittent or event-driven in three trials (two of which also included daily dosing arms).^66–68^ In one trial (the Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs [IPERGAY] trial), event-driven PrEP consisted of two tablets of TDF-FTC 2 to 24 hours before intercourse, followed by one tablet 24 hours and 48 hours after the first dose; additional dosing parameters were provided for multiple consecutive sexual encounters and situations in which event-driven PrEP had been taken within 1 week.^66^ Two other trials evaluated intermittent/event-driven PrEP (consisting of PrEP twice weekly and within 2 hours of intercourse) but either reported no HIV infections or combined results with patients randomized to daily PrEP.^67,68^ In all trials, HIV risk reduction and adherence counseling was provided to all patients. Free condoms were provided in all trials except for one, in which condom provision was not specified.^118^

Seven trials were conducted in Africa,^51,54,55,67,68,170,172^ one in Thailand,^53^ two in Europe or Canada,^66,118^ one in the United States,^52^ and one trial was international (∼10% of patients from U.S. sites).^137^ The trial conducted in the United States (n=400) evaluated daily TDF versus placebo in MSM;^52^ the two trials conducted in Europe and Canada^66,118^ and the international trial^137^ also focused on MSM. All trials of persons at higher risk of HIV infection via heterosexual contact were conducted in Africa, and the only trial of PWID was conducted in Thailand.^53^ In that trial, most patients received PrEP through directly observed therapy and patients were provided bleach with instructions on how to clean needles. Patients were not provided sterile syringes, although these were available at low cost without a prescription at pharmacies. The adherence level in each trial and method for measuring adherence are shown in Table 2. All trials reported funding from government agencies or nonprofit organizations. One trial also reported industry funding,^118^ three trials reported that study medications were donated by industry,^67,68,172^ and one trial noted that two investigators received royalties or funding from industry.^170^ One trial^118^ was rated fair quality because of unclear allocation concealment methods and open-label design (Appendix B Table 4). The remaining trials were rated good quality.

Results for incident HIV infection are summarized in Table 3. Among 12 trials of PrEP versus placebo or no PrEP^51–55,66–68,118,137,170,172^ one small (n=72) trial^68^ reported no cases of HIV infection with either PrEP or placebo. In the other 11 trials (N=18,172), the proportion of patients with new HIV infection ranged from 0 to 5.6 percent among those randomized to PrEP and from 1.4 to 7.0 percent among those randomized to placebo or no PrEP (Appendix B Table 1). PrEP was associated with reduced risk of HIV infection versus placebo or no PrEP (RR, 0.46 [95% CI, 0.33 to 0.66]) (Figure 2), but statistical heterogeneity was present (I^2^=67%). The ARR was −2.0 percent (95% CI, −2.8% to −1.2%; I^2^=58%) after 4 months to 4 years. Funnel plot asymmetry was present and the test for small sample effects was statistically significant (Egger test p-value=0.03) (Appendix C Figure 1). Excluding the single fair-quality study^118^ from the analysis had little effect on the pooled estimate (RR, 0.50 [95% CI, 0.36 to 0.70]) and did not reduce statistical heterogeneity (I^2^=65%). Results were similar using the profile likelihood method (pooled RR, 0.45 [95% CI, 0.26 to 0.65]) and when FDA data on HIV incidence was used instead of the data reported in the journal publication for the Pre-Exposure Prophylaxis Initiative (iPrEx) trial.^126,137^

Figure 2 Meta-Analysis: HIV Infection Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 2 is a forest plot of HIV infection stratified by study drug with two subgroups. The risk ratio for 5 studies in the TDF subgroup is 0.49 (95% confidence interval 0.28 to 0.84) with an I-squared value of 58%. The risk ratio for 8 studies in the FTC-TDF subgroup is 0.44 (95% confidence interval 0.27 to 0.72) with an I-squared value of 74%. The risk ratio for all studies is 0.46 (95% confidence interval 0.33 to 0.66) with I-squared value of 67%.

Table 3 Risk of HIV Infection in Placebo-Controlled RCTs of Oral PrEP

Study characteristics | Subgroups | Number of trials | RR (95% CI) | I^2^
All trials | - | 11^51–55,66,67,118,137,170,172^ | 0.46 (0.33 to 0.66) | 67%
Study quality | Restricted to good-quality trials | 10^51–55,66,67,137,170,172^ | 0.48 (0.33 to 0.71) | 71%
PrEP drug regimen (p=0.79 for interaction) | TDF | 5^51–55^ | 0.49 (0.28 to 0.84) | 58%
PrEP drug regimen (p=0.79 for interaction) | TDF-FTC | 8^51,54,55,66,67,118,137,172^ | 0.44 (0.27 to 0.72) | 67%
Adherence (p<0.00001 for interaction) | Adherence ≥70% | 6^51,52,66,67,118,170^ | 0.27 (0.19 to 0.39) | 0%
Adherence (p<0.00001 for interaction) | Adherence >40% to <70% | 3^53,55,137^ | 0.51 (0.38 to 0.70) | 0%
Adherence (p<0.00001 for interaction) | Adherence ≤40% | 2^54,172^ | 0.93 (0.72 to 1.20) | 0%
HIV risk category (p=0.43 for interaction) | Heterosexual men and women | 5^51,54,55,170,172^ | 0.54 (0.31 to 0.97) | 82%
HIV risk category (p=0.43 for interaction) | Men who have sex with men | 4^52,66,118,137^ | 0.23 (0.08 to 0.62) | 64%
HIV risk category (p=0.43 for interaction) | Persons who inject drugs | 1^53^ | 0.52 (0.29 to 0.92) | Not applicable
Dosing schedule (p=0.13 for interaction) | Daily dosing | 9^51–55,67,118,137,170,172^ | 0.47 (0.32 to 0.71) | 75%
Dosing schedule (p=0.13 for interaction) | On-demand dosing | 1^66^ | 0.14 (0.03 to 0.63) | Not applicable
Followup duration (p=0.35 for interaction) | Duration of followup <1 year | 3^55,66,67^ | 0.21 (0.07 to 0.58) | 0%
Followup duration (p=0.35 for interaction) | Duration of followup ≥1 to 2 years | 4^118,137,170,172^ | 0.48 (0.28 to 0.84) | 70%
Followup duration (p=0.35 for interaction) | Duration of followup ≥2 years | 4^51–54^ | 0.47 (0.22 to 1.00) | 86%
Industry support (p=0.38 for interaction) | Study reported industry support | 3^67,170,172^ | 0.58 (0.27 to 1.22) | 54%
Industry support (p=0.38 for interaction) | Study reported government or nonprofit funding only | 8^51–55,66,118,137^ | 0.39 (0.23 to 0.64) | 77%
Country setting (p=0.004 for interaction) | U.S. or other high-income countries | 3^52,66,118^ | 0.13 (0.05 to 0.32) | 0%
Country setting (p=0.004 for interaction) | Africa, Asia, or international trial | 8^51,53–55,67,137,170,172^ | 0.54 (0.37 to 0.79) | 72%

Abbreviations: CI=confidence interval; FTC=emtricitabme; PrEP=pre-exposure prophylaxis; RCT=randomized, controlled trial; RR=relative risk; TDF=tenofovir disoproxil fumarate; U.S.=United States.

Two African trials (the Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women [FEM PrEP] trial and the Vaginal and Oral Interventions to Control the Epidemic [VOICE] trial)^54,172^ of women at risk of HIV infection via heterosexual contact found PrEP to be substantially less effective (RR, 0.89 [95% CI, 0.55 to 1.44] and RR, 0.95 [95% CI, 0.70 to 1.28]) than the other 10 trials (RR estimates ranged from 0.07 to 0.53). In FEM PrEP and VOICE, adherence to PrEP was low, with 30 to 40 percent of patients randomized to PrEP having detectable plasma levels of tenofovir. A stratified analysis found a strong interaction (p<0.00001) between level of adherence and effectiveness of PrEP (adherence ≥70%: 6 trials; RR, 0.27 [95% CI, 0.19 to 0.39]; I^2^=0%;^51,52,66,67,118,170^ adherence >40% to <70%: 3 trials; RR, 0.51 [95% CI, 0.38 to 0.70]; I^2^=0%;^53,55,137^ and adherence ≤40%: 2 trials; RR, 0.93 [95% CI, 0.72 to 1.20]; I^2^=0%^54,172^) and stratification eliminated statistical heterogeneity (Table 3; Figure 3).^51–55,66,67,118,137,170,172^

Figure 3 Meta-Analysis: HIV Infection Stratified by Adherence

Note: Based on plasma testing, unless otherwise noted.

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 3 is a forest plot of HIV infection stratified by adherence with three subgroups. The risk ratio for 7 studies in the adherence greater than or equal to 70% subgroup is 0.27 (95% confidence interval 0.19 to 0.39) with an I-squared value of 0%. The risk ratio for 3 studies in the adherence greater than 40% and less than 70% subgroup is 0.51 (95% confidence interval 0.38 to 0.70) with an I-squared value of 0%. The risk ratio for 2 studies in the adherence less than 40% subgroup is 0.93 (95% confidence interval 0.72 to 1.20) with an I-squared value of 0%. The overall risk ratio for all studies is 0.44 (95% confidence interval 0.29 to 0.65) with an I-squared value of 72%.

There was also a strong association between adherence and effectiveness when adherence was analyzed as a continuous variable in a meta-regression (p<0.0005) (Figure 4). In the meta-regression, the level of adherence accounted for all of the between-study heterogeneity. For every 10 percent increase in adherence, there was a 21 percent relative reduction in the relative risk. Meta-regression findings were similar when analyses were restricted to trials that evaluated adherence based on plasma levels or when trials were stratified according to whether they used TDF or TDF-FTC. Adherence is further addressed in Contextual Questions 1 and 2.

Figure 4 Meta-Regression: PrEP Efficacy vs. Adherence

*U.S, Canada, or Europe.

Abbreviations: FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 4 is a meta-regression of PrEP efficacy versus adherence. The X-axis indicates adherence in each trial as measured by (in order of preference) presence of detectable tenofovir on drug level testing, MEMS data, pill counts, or self-report, and the Y-axis represents the logRR from each trial for PrEP vs. placebo or no PrEP. The size of the bubble for each study indicates the weighted sample size. The bubbles from left to right, increasing in adherence across the adherence x axis are: VOICE, FEMPrEP, iPrEx, Bangkok Tenofovir Study, Study of TDF, TDF2, IAVI Kenya, Partners PrEP, IPERGAY, CDC Safety Study, and PROUD. The bubbles from bottom to top in increasing log risk ratio are: CDC Safety Study, PROUD, IPERGAY, IAVI Kenya, Partners PrEP, Study of TDF, TDF2, Bangkok Tenofovir Study, iPrEx, FEMPrEP, and VOICE. The bubbles from smallest to largest in increasing weighted sample size are: IAVI Kenya, IPERGAY, CDC Safety Study, PROUD, Study of TDF, TDF2, FEMPrEP, iPrEX, Bangkok Tenofovir Study, VOICE, and Partners PrEP.

There was no clear difference in estimates of effectiveness of PrEP for preventing HIV infection when trials were stratified according to duration of followup (Figure 5) (p=0.35 for interaction) by less than 1 year (3 trials; RR, 0.21 [95% CI, 0.07 to 0.58]; I^2^=0%; ARR, −3.0% [95% CI, −6.0% to −1.0%]; I^2^=69%),^55,66,67^ 1 to less than 2 years (4 trials; RR, 0.48 [95% CI, 0.28 to 0.84]; I^2^=70%; ARR, −3.0% [95% CI, −5.0% to −1.0%]; I^2^=76%),^118,137,170,172^ or 2 or more years (4 trials; RR, 0.47 [95% CI, 0.22 to 1.00]; I^2^=86%; ARR, −2.0% [95% CI, −3.0% to −1.0%; I^2^=54%),^51–54^ or whether trials reported receipt of industry support (3 trials; RR, 0.58 [95% CI, 0.27 to 1.22]; I^2^=54%)^67,170,172^ versus only reporting governmental or nonprofit funding (8 trials; RR, 0.39 [95% CI, 0.23 to 0.64]; I^2^=77%)^51–55,66,118,137^ (Table 3). PrEP was more effective at preventing HIV infection in trials conducted in the United States, Europe, or Canada (3 trials; RR, 0.13 [95% CI, 0.05 to 0.32]; I^2^=0%)^52,66,118^ than in trials conducted in Africa, Asia, or internationally (8 trials; RR, 0.54 [95% CI, 0.37 to 0.79]; I^2^=72%; p=0.004 for interaction) (Figure 6).^51,53–55,67,68,137,170,172^ All three trials conducted in the United States, Europe, or Canada reported high adherence and enrolled MSM.

Figure 5 Meta-Analysis: HIV Infection Stratified by Study Duration

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 5 is a forest plot of HIV infection stratified by study duration with three subgroups. The risk ratio for 4 studies in the duration greater than or equal to 1 year but less than 2 years subgroup is 0.48 (95% confidence interval 0.28 to 0.84) with an I-squared value of 70%. The risk ratio for 4 studies in the duration less than 1 year subgroup is 0.21 (95% confidence interval 0.07 to 0.58) with an I-squared value of 0%. The risk ratios for 4 studies for the duration greater than or equal to 2 years subgroup is 0.47 (95% confidence interval 0.22 to 1.00) with an I-squared value of 86%. The overall risk ratio for all studies is 0.44 (95% confidence interval 0.29 to 0.65) with an I-squared value of 72%.

Figure 6 Meta-Analysis: HIV Infection Stratified by Geographic Setting

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 6 is a forest plot of HIV infection stratified by geographic setting with two subgroups. The risk ratio for 3 studies in the U.S./Canada/Europe subgroup is 0.13 (95% confidence interval 0.05 to 0.32) with an I-squared value of 0%. The risk ratio for 9 studies in the Africa/Asia/multinational subgroup is 0.54 (95% confidence interval 0.37 to 0.79) with an I-squared value of 72%. The overall risk ratio for all studies is 0.44 (95% confidence interval 0.29 to 0.65) with an I-squared value of 72%.

Nine trials (N=17,744)^51–55,118,137,170,172^ reported mortality; one other trial reported no deaths with or without PrEP,^66^ and two small, short-term trials (n=72 each; followup 4 months) did not report mortality.^67,68^ PrEP was associated with a modestly decreased risk of mortality that was not statistically significant (9 trials; RR, 0.81 [95% CI, 0.59 to 1.11]; I^2^=0%); however, due to small numbers of mortality events, risk estimates from individual trials and the pooled estimate were imprecise (Figure 7). There was no funnel plot asymmetry (Appendix C Figure 2). Results for mortality were similar when trials were stratified according to geographic setting and when the profile likelihood method was used for pooling (RR, 0.82 [95% CI, 0.54 to 1.14]). No trial reported effects of PrEP versus placebo on quality of life.

Figure 7 Meta-Analysis: Mortality Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis trial for HIV Prevention Among African Women; FTC=emtricitabine; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate Or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 7 is a forest plot of mortality stratified by study drug with two subgroups. The risk ratio for 5 studies in the TDF subgroup is 0.83 (95% confidence interval 0.59 to 1.18) with an I-squared value of 0%. The risk ratio for 6 studies in the FTC-TDF subgroup is 0.69 (95% confidence interval 0.31 to 1.52) with an I-squared value of 0%. The overall risk ratio for all studies is 0.81 (95% confidence interval 0.59 to 1.11) with an I-squared value of 0%.

#### Dapivirine Vaginal Ring vs. Placebo Ring

Two RCTs,^73,74^ (reported in three publications^73,74,163^) both added for this update, evaluated the dapivirine vaginal ring (25 mg monthly) versus a placebo ring (Table 3; Appendix B Tables 1–3). Both trials (n=2,629 and 1,959; total N=4,588) enrolled sexually active (defined as vaginal intercourse at least once in the last 3 months^73^ or an average or at least once per month in the last 3 months^74^), HIV-negative women 18 to 45 years of age (mean 27 and 32 years) living in high HIV prevalence areas in sub-Saharan Africa. Pregnant and breastfeeding persons were excluded and participants were required to use stable contraception. The duration of followup was 1.6 years (median) in 1 trial^73^ and 1.4 years (mean) in the other trial.^74^ One trial was funded by government^73^ and one by a combination of government, nonprofit, and industry.^74^ In both trials, HIV risk reduction and adherence counseling and condoms were provided to all patients. The trials were rated good quality (Appendix B Table 4).

Both trials (N=4,564) found the dapivirine ring associated with a similarly decreased risk of HIV infection versus placebo (5.4% vs. 7.4%, RR 0.73 [95% CI 0.54 to 0.98]^73^ and 5.9% vs. 8.6%, RR 0.69 [95% CI 0.49 to 0.96]),^74^ with a pooled RR of 0.71 (95% CI 0.57 to 0.89, I^2^=0%; Figure 8). The ARD was −2.23% (95% CI −3.75% to −0.74%) at 1.4 to 1.6 years. Adherence to the dapivirine ring was 82 and 84 percent in the trials, based on dapivirine plasma levels >95 pg/mL.

Figure 8 Dapivirine vs. Placebo: HIV Infection

RD: −2.23% (95% CI, −3.75% to −0.74%)

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel-Haenszel; RD=risk difference.

Figure 8 is a forest plot of HIV infection. The overall risk ratio for 2 studies is 0.71 (95% confidence interval 0.57 to 0.89) with an I-squared value of 0%.

The trials were not designed to assess effects of the dapivirine vaginal ring on mortality and reported very few events, with an imprecise estimate (N=4,587, 0.23% vs. 0.20%, RR 1.23, 95% CI 0.35 to 4.38, I^2^=0%).^73,74^

## Key Question 1a How Do the Benefits of PrEP Differ by Population Subgroups?

### Oral PrEP vs. Placebo or No PrEP

PrEP was effective across population subgroups defined by HIV risk category (Table 4). There were no clear differences in estimates of effectiveness for PrEP versus placebo or no PrEP in risk of HIV infection when trials were stratified according to whether they enrolled men and women at increased risk of HIV infection via heterosexual contact (5 trials; RR, 0.54 [95% CI, 0.31 to 0.97]; I^2^=82%),^51,54,55,68,170,172^ MSM or transgender women (4 trials; RR, 0.23 [95% CI, 0.08 to 0.62]; I^2^=64%),^52,66,118,137^ or PWID (1 trial; RR, 0.52 [95% CI, 0.29 to 0.92]; p=0.43 for interaction) (Figure 9),^53^ although evidence of effectiveness in PWID was limited to one trial conducted in Asia. As noted above, the two trials (FEM-PrEP and VOICE) which found PrEP to be ineffective were conducted in African women at high risk of HIV infection in whom adherence was low.^54,172^

Figure 9 Meta-Analysis: HIV Infection Stratified by HIV Risk Category

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 9 is a forest plot of HIV infection stratified by HIV Risk Category with four subgroups. The risk ratio for 6 studies in the heterosexual men and women category is 0.54 (95% confidence interval 0.31 to 0.97) with an I-squared value of 82%. The risk ratio for 4 studies in the MSM or transgender women category is 0.23 (95% confidence interval 0.08 to 0.62) with an I-squared value of 64%. The risk ratio for 1 study in the mixed population category is 0.17 (95% confidence interval 0.01 to 4.03). The risk ratio for 1 study in the PWID category is 0.52 (95% confidence interval 0.29 to 0.92). The overall risk ratio for all studies is 0.44 (95% confidence interval 0.29 to 0.65) with an I-squared value of 72%.

Table 4 Effect of PrEP vs. Placebo on HIV Infection in Population Subgroups

Type of PrEP | Study | Age | Sex and Gender | Race and Ethnicity | Risk behaviors
Oral PrEP Versus Placebo or No PrEP | Bangkok Tenofovir Study; Choopanya, 2013^53^ | [underlined: Efficacy]; 20-29 years: 33.6% (95% CI, −40.1 to 69.8); 30-39 years: 29.2% (95% CI, −121.7 to 79.1); ≥40 years: 88.9% (95% CI, 41.1 to 99.4); p=NR | [underlined: Efficacy]; Female: 78.6% (95% CI, 16.8 to 96.7); Male: 37.6% (95% CI, −17.8 to 67.9); p=NR | NR | [underlined: Efficacy]; Shared needles; Yes: 54.7% (95% CI, −44.0 to 87.9); No: 47.6% (95% CI, −2.5 to 74); p=NR; Injected during 12 weeks before enrollment; Yes: 44.3% (95% CI, −12.5 to 72.4); No: 57.4% (95% CI, −17.0 to 86.6); p=NR
Oral PrEP Versus Placebo or No PrEP | FEM-PrEP; Van Damme 2012^172^ | ≥25 years: RR, 0.91 (95% CI, 0.41 to 2.05); <25 years: RR, 0.97 (95% CI, 0.55 to 1.72); p=0.91 for interaction | NA | NR | NR
Oral PrEP Versus Placebo or No PrEP | iPrEx; Grant 2010^137^ | <25 years: HR, 0.67 (95% CI, 0.40 to 1.14); ≥25 years: HR, 0.41 (95% CI, 0.24 to 0.87; p=0.36 for interaction | Transgender women: HR, 1.1 (95% CI, 0.5 to 2.7); Male (MSM): HR, 0.50 (95% CI, 0.34 to 0.75); p=0.09 for interaction | Non-Hispanic: HR, 0.48 (95% CI, 0.14 to 1.60); Hispanic: HR, 0.57 (95% CI, 0.37 to 0.89); p=0.79 for interaction | Unprotected receptive anal intercourse; Yes: HR, 0.42 (95% CI, 0.26 to 0.68); No: HR, 1.59 (95% CI, 0.66 to 3.84); p=0.01 for interaction
Oral PrEP Versus Placebo or No PrEP | Partners PrEP; Baeten 2012^51^ | TDF vs. placebo; <25 years: HR, 0.28 (95% CI, 0.01 to 1.01); ≥25 years: HR, 0.34 (95% CI, 0.18 to 0.61); p=0.79 for interaction; TDF-FTC vs. placebo; <25 years: HR, 0.59 (95% CI, 0.21 to 1.61); ≥25 years: HR, 0.17 (95% CI, 0.07 to 0.37); p=0.06 for interaction | TDF vs. placebo; Female: HR, 0.29 (95% CI, 0.13 to 0.63); Male: HR, 0.37 (95% CI, 0.17 to 0.80); p=0.65 for interaction; TDF-FTC vs. placebo; Female: HR, 0.34 (95% CI, 0.16 to 0.72); Male: HR, 0.16 (95% CI, 0.06 to 0.46); p=0.24 for interaction | NR | TDF vs. placebo, unprotected sex with study partner; Yes: HR, 0.47 (95% CI, 0.25 to 0.89); No: HR, 0.13 (95% CI, 0.04 to 0.44); p=0.05 for interaction; TDF-FTC vs. placebo, unprotected sex with study partner; Yes: HR, 0.27 (95% CI, 0.12 to 0.58); No: HR, 0.22 (95% CI, 0.08 to 0.58); p=0.77 for interaction
Oral PrEP Versus Placebo or No PrEP | TDF2; Thigpen 2012^170^ | NR | Female: RR, 0.49 (95% CI, 0.02 to 1.21); Male: RR, 0.20 (95% CI, 0.4 to 0.91); p=0.31 for interaction | NR | NR
Dapivirine Vaginal Ring Versus Placebo Ring | ASPIRE; Baeten, 2016^73^; Peebles, 2020^163^ | [underlined: Efficacy:]; 18 to 21 years: −27% (95% CI, −133 to 31); 22 to 26 years: 56% (95% CI, 19 to 76%); 27 to 45 years: 51% (95% CI, 8 to 74); Over 21 years: 56% (95% CI, 31 to 71), p<0.001; <25 years: 8.1% vs. 8.8%, HR 0.90, 95% CI, 0.57 to 1.41; ≥25 years: 2.4% vs. 6.0%, HR 0.39, 95% CI, 0.23 to 0.68; HIV-1 incidence when also engaging in receptive anal intercourse (RAI): 5.2/100 woman-years (95% CI, 3.4 to 7.7) with dapivirine ring vs. 4.3/100 woman-years (95% CI, 3.4 to 5.3) with placebo ring | All female | NR | STIs at baseline:; Yes: HR 0.78 (95% CI, 0.45 to 1.34); No: HR 0.53 (95% CI, 0.34 to 0.83); Number of sexual partners:; 0-1: HR 0.63 (95% CI, 0.42 to 0.93); 2+: HR 0.62 (95% CI, 0.31 to 1.23); Receptive anal intercourse (RAI): aHR 0.93 (95% CI, 0.57 to 1.54, p=0.71); Reduction of HIV-1 risk with dapivirine ring no RAI vs. RAI: 27% (95% CI, −5% to 49%) vs. 18% (95% CI, −57% to 57%)
Dapivirine Vaginal Ring Versus Placebo Ring | Ring Study; Nel, 2016^74^ | [underlined: Efficacy:]; ≤21 years: 9.0% vs. 10.9%; HR 0.85 (95% CI, 0.45 to 1.60); >21 years: 5.0% vs. 7.9%, HR 0.63 (95% CI, 0.41 to 0.97) | All female | NR | NR

Abbreviations: aHR=adjusted hazard ratio; ASPIRE= Antiretroviral Strategy to Promote Improvement and Reduce Exposure; CI=confidence interval; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; HR=hazard ratio; FTC=emtricitabine; HR=hazard ratio; iPrEx=Pre-Exposure Prophylaxis Initiative; MSM=men who have sex with men; NR=not reported; PrEP=pre-exposure prophylaxis; RAI=receptive anal intercourse; RR=relative risk; STI=sexually transmitted infection; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study.

Five trials performed within-study stratified analyses of PrEP effectiveness (Table 4).^51,53,137,170,172^ Four trials^51,53,137,172^ found no clear differences in PrEP effectiveness in populations defined according to age, and three trials^51,53,170^ found no clear differences between men and women. A post-hoc analysis of the iPrEx trial^137^ found that PrEP was effective in MSM (hazard ratio [HR], 0.50 [95% CI, 0.34 to 0.75]) but not in transgender women (HR, 1.1 [95% CI, 0.5 to 2.7]), although the interaction was not statistically significant (p=0.09).^134^ No other trial compared how results for transgender women differed from other risk groups. Evidence on how effects of PrEP vary by race/ethnicity was limited to iPrEx, which found similar effectiveness in Hispanic and non-Hispanic persons.^137^ Among three trials conducted in the United States, Europe, or Canada, the proportion of participants who were White ranged from 73 to 91 percent.^52,66,118^

Data were limited regarding effects of risk behaviors on effectiveness of PrEP. One trial (iPrEx) found PrEP was effective in transgender women and MSM who reported receptive anal intercourse (HR, 0.42 [95% CI, 0.26 to 0.68]) but not in those who did not report receptive anal intercourse (HR, 1.59 [95% CI, 0.66 to 3.84]; p=0.01 for interaction).^137^ One trial (Partners PrEP) found PrEP to be effective in men and women at risk of HIV infection through heterosexual contact regardless of whether they did or did not report sex without condoms.^51^ This trial also found both TDF and TDF-FTC associated with similar effectiveness when analyzed according to sexual risk behaviors and partner’s viral load (Appendix B Table 1).^161^ A trial of PWID (the Bangkok Tenofovir Study) found no association between drug injection or needle sharing in the 12 weeks before enrollment and effectiveness of PrEP.^53^ A new post-hoc analysis of data from IPERGAY evaluated effects of event-driven PrEP among MSM stratified according to frequency of sexual intercourse and adherence in order to assess effects of more sporadic use of PrEP in persons engaging in less frequent sexual intercourse (compared to persons engaging in frequent sexual intercourse, in whom the frequency of event-driven PrEP more closely resembles daily PrEP).^129^ It found event-driven PrEP associated with decreased HIV incidence versus placebo among those who took ≤15 pills per month with high adherence (0 vs. 9.2 per 100 person-years, p=0.013) and those who took >15 pills per month (0 vs. 8.1 per 100 person-years, p=0.004), but not among those who took ≤15 pills per month with low or no adherence (10.2 vs. 0 per 100 person-years, p=0.19).

When stratified according to patient population, pooled estimates for effects of PrEP versus placebo or no PrEP on mortality were similar (p=0.90 for interaction) in trials of women and men at increased risk of HIV infection via heterosexual contact (4 trials; RR, 0.71 [95% CI, 0.36 to 1.42]; I^2^=0%),^51,54,170,172^ MSM or transgender women (4 trials; RR, 0.87 [95% CI, 0.22 to 3.41]; I^2^=0%),^52,55,118,137^ and PWID (1 trial; RR, 0.85 [95% CI, 0.58 to 1.23]) (Figure 10).^53^

Figure 10 Meta-Analysis: Mortality Stratified by HIV Risk Category

*U.S, Canada, or Europe.

Abbreviatons: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; PWID=persons who inject drugs; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Study of Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 10 is a forest plot of mortality stratified by HIV risk category with three subgroups. The risk ratio for 4 studies in the heterosexual men and women category is 0.71 (95% confidence interval 0.36 to 1.42) with an I-squared value of 0%. The risk ratio for 4 studies in the MSM or transgender women category is 0.87 (95% confidence interval 0.22 to 3.41) with an I-squared value of 0%. The risk ratio for 1 study in the PWID category is 0.85 (95% confidence interval 0.58 to 1.23). The overall risk ratio for all studies is 0.82 (95% confidence interval 0.59 to 1.12) with an I-squared value of 0%.

### Dapivirine Vaginal Ring vs. Placebo Ring

Both trials of the dapivirine vaginal ring conducted analyses stratified by age. Although the dapivirine ring was associated with reduced effectiveness in younger patients in both trials (likely related to lower adherence), the trials differed in the age thresholds evaluated and there was either no statistically significant subgroup difference or a statistical test for a subgroup difference was not reported. In one trial, the dapivirine ring was associated with significant reduction in risk of HIV acquisition among patients older than 21 years (HR 0.63, 95% CI 0.41 to 0.97) but not in those 21 years of age and younger (HR 0.85, 95% CI 0.45 to 1.60; p for interaction=0.43).^74^ The other trial reported a more pronounced difference in effects of the dapivirine ring on reduced risk of incident HIV infection among persons 25 years or older (HR 0.39. 95% CI 0.23 to 0.68) than those younger than 25 years (HR 0.90, 95% CI 0.57 to 1.41; p for interaction not reported).^73^

One of the trials (Microbicide Trials Network 020-A Study To Prevent Infection with a Ring for Extended Use, or ASPIRE)^73^ conducted additional stratified analyses based on STI status, number of sexual partners, and sexual behaviors. The dapivirine ring was associated with smaller reduction in risk of HIV acquisition among persons with an STI at baseline (HR 0.78, 95% CI 0.45 to 1.34) than those without an STI at baseline (HR 0.53, 95% CI 0.34 to 0.83, p for interaction not reported).^73^ The dapivirine ring was associated with smaller reduction in risk of HIV acquisition among persons who engaged in anal intercourse compared with those who did not engage in anal intercourse (risk reduction 18%, 95% CI −57% to 57% and risk reduction 27%, 95% CI −5% to 49%, respectively), but the difference was not statistically significant (p for interaction=0.77).^163^ The reduction in HIV acquisition risk was very similar among persons with two or more sexual partners (HR 0.62, 95% CI 0.31 to 1.23) and those with zero or one sexual partner (HR 0.63, 95% CI 0.42 to 0.93.^73^

## Key Question 1b How Do the Benefits of PrEP Differ by Dosing Strategy or Regimen?

Estimates of effectiveness of oral PrEP versus placebo or no PrEP on risk of HIV infection were very similar when analyses were stratified according to use of TDF (5 trials; RR, 0.49 [95% CI, 0.28 to 0.84]; I^2^=58%)^51–55^ or TDF-FTC (8 trials; RR, 0.44 [95% CI, 0.27 to 0.72]; I^2^=74%; p=0.79 for interaction) (Table 3; Figure 2).^51,54,66,67,118,137,170,172^ Among the trials that used intermittent or event-driven dosing, one trial^68^ reported no HIV events and one trial^67^ combined results for intermittent/event-driven and daily dosing of PrEP arms. The third trial (IPERGAY)^66^ found event-driven PrEP associated with a lower risk of HIV infection than placebo in MSM (RR, 0.14 [95% CI, 0.03 to 0.63]). Although the estimate was stronger than that among trials that used daily dosing (9 trials; RR, 0.47 [95% CI, 0.32 to 0.71]; I^2^=75%) (Table 3; Figure 11),^51–55,118,137,170,172^ the interaction was not statistically significant (p=0.13). The estimate from IPERGAY was similar to the pooled estimate for trials of daily dosing that reported high adherence (5 trials; RR, 0.28 [95% CI, 0.20 to 0.41]).^51,52,67,118,170^ In IPERGAY, men randomized to PrEP took an average of about four doses of PrEP per week (15 doses per month) and had an average of 10 episodes of sexual intercourse per month.

Figure 11 Meta-Analysis: HIV Infection Stratified by Dosing Strategy

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=conftdence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for EHV Prevention Among African Women; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 11 is a forest plot of HIV infection by dosing strategy with two subgroups. The risk ratio for 9 studies in the daily dosing subgroup is 0.47 (95% confidence interval 0.32 to 0.71) with an I-squared value of 75%. The risk ratio for 1 study in the intermittent/on-demand dosing subgroup is 0.14 (95% confidence interval 0.03 to 0.63). The overall risk ratio for all studies is 0.44 (95% confidence interval 0.29 to 0.67) with an I-squared value of 75%.

The open-label HIV Prevention Trials Network 067/Alternative Dosing to Augment PrEP pill Taking (HPTN 067/ADAPT) trial, included in the prior USPSTF report, compared daily versus intermittent (twice a week, plus a dose after sex) or event-driven PrEP with TDF-FTC in MSM or transgender women^136^ (n=357) and heterosexual African women^130^ (n=178) (Tables 5 and 6; Appendix B Tables 1–3), but was not powered to evaluate effects on incident HIV infection (five total cases). One new, small (n=119), fair-quality crossover trial conducted in Hong Kong compared event-driven versus daily oral TDF-FTC among high-risk HIV-negative MSM, but also was not designed to assess effects on incident HIV infection and only reported one case (Tables 5 and 6; Appendix B Tables 1–3).^144^

Table 5 Study Characteristics of Head-to-Head Trials of PrEP

Type of PreP | Study name; Author, year^*^; Country; Duration of followup; Quality | Interventions | HIV risk group(s); Risk-based inclusion criteria | Patient characteristics | Adherence (method for measuring adherence)
Event Driven Versus Daily Oral PrEP^†^ | ADAPT/ HPTN 067; Bekker 2018^130^; South Africa; 34 weeks; Fair; Included in prior report | A. Daily TDF-FTC (n=59); B. Time-driven TDF-FTC (one tablet twice a week, plus a dose after sex; n=59); C. Event-driven TDF-FTC (one tablet both before and after sex; n=60) | High-risk women or transgender men: History of an acute STI, transactional sex, intercourse without a condom with someone of unknown or HIV-infected status, or >1 sex partner in 6 months | [underlined: A vs. B vs. C]; Age, mean: 25 vs. 26 vs. 25 years; Female: 100% (no transgender men enrolled); Black: 98% vs. 100% vs. 100% | [underlined: A vs. B vs. C]; (plasma level ≥2.5 ng/mL at week 30 [consistent with ≥2 doses/week [daily and time-driven] or when reporting sex in prior week [event-driven]): 54% vs. 36% vs. 31%
Event Driven Versus Daily Oral PrEP^†^ | ADAPT/ HPTN 067 Grant, 2018^136^; Thailand, U.S.; 34 weeks; Fair; Included in prior report | A. Daily TDF-FTC (n=119); B. Time-driven TDF-FTC (one tablet twice a week, plus a dose after sex; n=119); C. Event-driven TDF-FTC (one tablet both before and after sex; n=119) | MSM:; Reported anal or neovaginal sex with a man in the past 6 months, and have at least 1 of the following in the past 6 months: sex with >1 man or transgender woman; history of an acute STI; sex in exchange for money, goods, or favors; or intercourse without a condom with an HIV-infected partner or partner of unknown HIV infection status | [underlined: A vs. B vs. C]; Bangkok site:; Age 18 to 24 years: 13% vs. 20% vs. 14%; Ages 25 to 29 years: 22% vs. 32% vs. 27%; Age 30 to 39 years: 60% vs. 39% vs. 48%; Age ≥40 years: 5% vs. 9% vs. 12%; MSM: 98% vs. 98% vs. 100% Transgender: 2% vs. 2% vs. 0%; Race NR; Harlem site:; Age 18 to 24 years: 32% vs. 28% vs. 28%; Age 25 to 29 years: 22% vs. 18% vs. 13%; Age 30 to 39 years:19% vs. 20% vs. 23%; Age ≥40 years: 27% vs. 33% vs. 35%; MSM: 97% vs. 98% vs. 97%; Transgender: 3% vs. 0% vs. 2%; Gender queer: 0% vs. 2% vs. 2%; Black 70%, White 13%, Asian 3%, Native American 3%, Hispanic 25%, Other 21% | [underlined: A vs. B vs. C]; Bangkok site: (peripheral blood mononuclear cell levels consistent with ≥2 tablets on visits when sex was reported in prior week) 97.6% vs. 98.7% vs. 95.7%; Harlem site: (dried blood spot levels consistent with ≥2 tablets on visits when sex was reported in prior week) 48.5% vs. 30.9% vs. 16.7%
Event Driven Versus Daily Oral PrEP^†^ | Kwan, 2021^144^; Hong Kong; 32 weeks; Fair | A: Daily TDF-FTC (n=59); B: Event-driven TDF-FTC (n=60) | MSM:; Had condomless anal intercourse in the preceding 6 months | A vs B; Age, mean: 29 vs. 30 years | Median 100% vs. 93% (self-report, proportion of days with PrEP-covered condomless anal intercourse)
Oral TAF-FTC Versus TDF-FTC | DISCOVER; Mayer, 2020^121^; Ogbuagu, 2021^162^; Europe and North America; 96 weeks; Good | A: TAF-FTC (n=2694); B: TDF-FTC (n=2693) | Cisgender MSM or transgender women who have sex with men: Condomless anal sex with at least two partners in the previous 12 weeks or syphilis, rectal gonorrhea, or rectal chlamydia in the prior 24 weeks | [underlined: A vs. B]; Age (mean): 34 vs. 34 years; Cisgender MSM: 98% vs. 99%; Transgender women who have sex with men: 2% vs. 1%; White: 84% vs. 84%; Black: 9% vs. 9%; Asian: 4% vs. 5%; Hispanic or Latinx ethnicity: 24% vs. 25% | [underlined: A vs. B]; 88%–96% vs. 84%–93% (dried blood spot, random sample consistent with ≥4 doses/week)
Long-acting Injectable Cabotegravir Versus Daily Oral TDF-FTC | HPTN 083; Landovitz, 2021^70^; International; Median 1.4 years; Good | A: Cabotegravir long-acting injectable 600 mg at weeks 5, 9, 17, and every 8 weeks afterward and oral placebo (n=2,282); B: Oral tenofovir disoproxil fumarate 300 mg + emtricitabine 200 mg once daily and injectable placebo (n=2,284) | Cisgender MSM and transgender women who have sex with men | [underlined: A vs. B]; Median age: 26 vs. 26 years; MSM: 88% vs. 87%; Transgender women who have sex with men: 12% vs. 13% | [underlined: A vs. B]; 91.5% (received injection with no delay ≥2 weeks) vs. 74% (plasma, tenofovir level >40 ng/mL [consistent with ≥4 doses/week])
Long-acting Injectable Cabotegravir Versus Daily Oral TDF-FTC | HPTN 084; Delany-Moretwle, 2022^88^; Sub-Sahara Africa; Median 1.24 years; Good | A: Cabotegravir 600 mg in a 3 mL IM injectable every 8 weeks (n=1,592); B: Daily TDF-FTC 300 mg + 200 mg (n=1,586) | High risk women: Reporting at least 2 episodes of vaginal intercourse in the previous 30 days at risk of HIV infection based on an HIV risk score | [underlined: A vs. B] Median age: 25 vs. 25 years; Race/ethnicity: 97.2% vs. 96.5% Black; Gender identity: 99.9% vs. 99.8% female, 0% vs 0.2% male, and 0.1% vs. 0% transgender male | [underlined: A vs. B]; 93% (received injection with no delay ≥2 weeks) vs. 42% (plasma, tenofovir level ≥40 ng/mL)

* Primary publication.

† Additional study (IPERGAY, Molina 2015^66^) of event-driven PrEP, but versus placebo, in Table 2.

Abbreviations: ADAPT= Alternative Dosing to Augment PrEP pill Taking; FTC=emtricitabine; HPTN= HIV Prevention Trials Network; IM=intramuscular; MSM=men who have sex with men; NR=not reported; PrEP=pre-exposure prophylaxis; STI=sexually transmitted infection; TAF=tenofovir alafenamide; TDF=tenofovir disoproxil fumarate.

Table 6 Risk of HIV Infection and Adverse Events in Head-to-Head Trials of PrEP

Type of PrEP | Study name; Author, year^*^ | Interventions | Clinical health outcomes | Adverse events
Event Driven Versus Daily Oral PrEP^†^ | ADAPT/HPTN 067; Bekker 2018^130^ | A. Daily TDF-FTC (n=59); B. Time-driven TDF-FTC (one tablet twice a week, plus a dose after sex; n=59); C. Event-driven TDF-FTC (one tablet both before and after sex; n=60) | A vs. B vs. C; HIV infection: 0% (0/59) vs. 3% (2/59) vs. 3% (2/60); A vs. B: RR, 0.20 (95% CI, 0.01 to 4.08); A vs. C: RR, 0.20 (95% CI, 0.01 to 4.15) | A vs. B vs. C; Any headache, dizziness, or lightheadedness: 12% (43/348) vs. 6% (20/331) vs. 8% (26/332); A vs. B: OR, 2.19 (95% CI, 1.13 to 4.27); A vs. C: OR, 1.66 (95% CI, 0.88 to 3.13); Any GI symptom: 11% (37/348) vs. 9% (29/331) vs. 5% (18/332); A vs. B: OR, 1.24 (95% CI, 0.61 to 2.51); A vs. C: OR, 2.08 (95% CI, 0.98 to 4.40)
Event Driven Versus Daily Oral PrEP^†^ | ADAPT/HPTN 067; Grant, 2018^136^ | A. Daily TDF-FTC (n=119); B. Time-driven TDF-FTC (one tablet twice a week, plus a dose after sex; n=119); C. Event-driven TDF-FTC (one tablet both before and after sex; n=119) | A vs. B vs. C; HIV infection: 0.8% (1/119) vs. 0% (0/119) vs. 0% (0/119); A vs. B; A vs. C: RR, 3.03 (95% CI, 0.12 to 75); South Africa (from Bekker 2017), Bangkok and Harlem sites combined: 0.6% (1/178) vs. 1.1% (2/178) vs. 1.1% (2/179); A vs. B: RR, 0.50 (95% CI, 0.04 to 5.53); A vs. C: RR, 1.01 (95% CI, 0.14 to 7.22) | A vs. B vs. C; Bangkok; Proportion of visits when patients reported neurologic events: 14.2% vs. 14.3% vs. 13.3%; Proportion of visits when patients reported GI events: 13.1% vs. 8.5% vs. 10.5%; Harlem; Proportion of visits when patients reported neurologic events: 6.1% vs. 3.3% vs. 4.5%; Proportion of visits when patients reported GI events: 8.0% vs. 5.8% vs. 7.1%
Event Driven Versus Daily Oral PrEP^†^ | Kwan, 2021^144^ | A: Once-daily TDF-FTC (n=59); B: On-demand TDF-FTC (n=60) | NR | A vs. B; Creatinine clearance: no difference between arms
Oral TAF-FTC Versus TDF-FTC | DISCOVER; Mayer, 2020^121^; Ogbuagu, 2021^162^ | A: TAF-FTC (n=2694); B: TDF-FTC (n=2693) | HIV infection, primary (interim) analysis (for which 100% of patients had completed 48 weeks and 50% had completed 96 weeks): 0.16 vs. 0.34 per 100 person-years, IRR 0.47 (95% CI 0.19 to 1.15); 0.3% (7/2670) vs. 0.6% (15/2665), RR 0.47 (95% CI, 0.19 to 1.14)^‡^; HIV infection at 96 weeks (all patients had completed 96 weeks): 0.16 vs. 0.30 per 100 person-years; IRR 0.54 (0.23 to 1.26); 0.3% (8/2694) vs. 0.6% (15/2693), RR 0.53 (95% CI 0.23 to 1.26)^‡^ | A vs. B; Mortality: 0.1% (3/2694) vs. 0.07% (2/2693), RR 1.50 (95% CI 0.25 to 8.97); Serious adverse event: 7.5% (202/2694) vs. 6.9% (186/2693), RR 1.09 (95% CI 0.90 to 1.32); Discontinuation of study drug due to adverse event: 1.5% (40/2694) vs. 1.9% (51/2693), RR 0.78 (95% CI 0.52 to 1.18); Any adverse event: 94% (2523/2694) vs. 94% (2521/2693), RR 1.00 (95% CI 0.99 to 1.01); Rectal chlamydia: 33% (890/2694) vs. 33% (902/2693), RR 0.99 (95% CI 0.91 to 1.06); Oropharyngeal gonorrhea: 32% (871/2694) vs. 31% (838/2693), RR 1.04 (95% CI 0.96 to 1.12); Rectal gonorrhea: 30% (805/2694) vs. 30% (797/2693), RR 0.99 (95 % CI 0.91 to 1.06); Syphilis: 15% (413/2694) vs. 15% (392/2693), RR 1.05 (95% CI 0.93 to 1.20); Urethral chlamydia: 13% (346/2694) vs. 12% (314/2693), RR 1.10 (95% CI 0.95 to 1.27); Any renal adverse event: 10% (263/2694) vs. 10% (266/2693), RR 0.99 (95% CI, 0.84 to 1.16), in primary (interim) analysis; Grade ≥3 renal adverse event: 0.07% (2/2694) vs. 0.1% (3/2693), RR 0.67 (95% CI 0.11 to 3.99), in primary (interim) analysis; Renal adverse event leading to discontinuation: 0.07% (2/2694) vs. 0.2% (6/2693), RR 0.33 (95% CI 0.07 to 1.65); Creatinine clearance, median percentage change from baseline: -2.3% vs. +1.8%, p<0.0001, in primary (interim) analysis; Fracture: 2.2% (60/2694) vs. 2.2% (60/2693), RR 1.00 (95% CI 0.70 to 1.42); Diarrhea: 18% (480/2694) vs. 17% (453/2693), RR 1.06 (95% CI 0.94 to 1.19); Nausea: 4.2% (114/2694) vs. 4.6% (123/2693), RR 0.93 (95% CI 0.72 to 1.19), in primary (interim) analysis; Hip bone mineral density, percent change from baseline: +0.6% vs. -1.0% in persons ≥25 years (p<0.001) and +1.2% vs. -1.7% in persons <25 years (p=0.04); Spine bone mineral density, percent change from baseline: +0.9% vs. -1.4% in persons ≥25 years (p<0.001) and +1.4% vs. -1.2% in persons <25 years (p=0.14); Body weight, change from baseline (kg): +1.7 vs. +0.5, p<0.0001; Note: outcomes at 96 weeks, except where noted as primary (interim) analysis, for which 100% of patients had completed 48 weeks and 50% had completed 96 weeks
Long-acting Injectable Cabotegravir Versus Daily Oral TDF-FTC | HPTN 083; Landovitz, 2021^70^ | A: Cabotegravir 600 mg in a 3 mL IM injectable every 8 weeks (n=2,282); B: Daily TDF-FTC 300 mg + 200 mg (n=2,284) | A vs. B; HIV infection: 0.57% (13/2,243) vs. 1.71% (39/2,247); RR 0.33 (95% CI, 0.18 to 0.62^‡^); incidence rate per 100 person-years, 0.41 vs. 1.22; HR 0.34 (95% CI 0.18 to 0.62) | A vs. B; Serious adverse events: 5.3% (120/2,280) vs. 5.3% (121/2,282); Grade 3 or higher adverse events: 31.9% (727/2,280) vs. 33.6% (767/2,282); Hepatic-related discontinuations: 2.1% (47/2,280) vs. 2.1% (48/2,282); Decreased creatinine cleareance: 7.0% (159/2,280) vs. 8.3% (190/2,282); Increased aspartate aminotransferase: 2.3% (53/2,280) vs. 3.0% (69/2,282); Increased alanine aminotransferase: 1.0% (23/2,280) vs. 1.4% (32/2,282); Deaths: 0.18% (4/2,280) vs. 0
Long-acting Injectable Cabotegravir Versus Daily Oral TDF-FTC | HPTN 084; Delany-Moretwle, 2022^88^ | A: Cabotegravir 600 mg in a 3 mL IM injectable every 8 weeks (n=1,592); B: Daily TDF-FTC 300 mg + 200 mg (n=1,586) | A vs. B; HIV infection: 0.3% (4/1,592) vs. 2.3% (36/1,586); RR 0.11 (95% CI 0.04 to 0.31^‡^); incidence rate per 100 person-years, 0.20 (95% CI 0.06 to 0.52) vs. 1.85 (95% CI 1.30 to 2.57); HR 0.12 (95% C, 0.05 to 0.31) | A vs. B; Serious adverse events: 2.0% (33/1,614) vs. 2.0% (33/1,610); Grade 3 or higher adverse events: 17.1% (276/1,614) vs. 17.4% (280/1,610); Hepatic-related discontinuation: 0.9% (15/1,614) vs. 1.1% (18/1,610); Deaths: 0.2% (3/1,614) vs. 0; Chlamydia: 16.2% (261/1,614) vs. 17.8% (287/1,610); Gonorrhea: 7.8% (126/1,614) vs. 7.8% (125/1,610); Trichomonas: 7.7% (124/1,614) vs. 6.8% (109/1,610); Grade 3 decreased creatinine clearance: 6.8% (110/1,614) vs. 7.8% (125/1,610)

* Primary publication.

† Additional study (IPERGAY, Molina 2015^66^) of event-driven PrEP, but versus placebo, in Table 2.

‡ Relative risk calculated from data provided in the trial.

Abbreviations: ADAPT= Alternative Dosing to Augment PrEP pill Taking; CI=confidence interval; FTC=emtricitabine; GI=gastrointestinal; HPTN= HIV Prevention Trials Network; HR=hazard ratio; IM=intramuscular; IPERGAY=Intervention Préventive de l’Exposition aux Risques avec et pour les Gays; IRR=incidence rate ratio; NR=not reported; OR=odds ratio; PrEP=pre-exposure prophylaxis; RR=relative risk; TAF=tenofovir alafenamide; TDF=tenofovir disoproxil fumarate.

Data on the effects of use of postexposure prophylaxis on efficacy of PrEP was limited. In the open-label Pre-Exposure Option for Reducing HIV in the United Kingdom: Immediate or Deferred (PROUD) trial, PrEP was more effective than no PrEP at reducing risk of HIV infection in MSM (RR, 0.14, 95% CI, 0.03 to 0.63), despite much less frequent use of postexposure prophylaxis (4.4% vs. 32%) and an increased rate of receptive anal sex without a condom with 10 or more partners (21% vs. 12%) among persons randomized to PrEP.^118^ No other trial reported the proportion of patients who used postexposure prophylaxis, although three trials described postexposure prophylaxis as an HIV prevention intervention offered to all patients;^51,66,137^ PrEP was effective in all three trials (RR, 0.14 to 0.53).

For mortality, estimates for PrEP versus placebo or no PrEP were similar when trials were stratified according to whether they used TDF or TDF-FTC (p=0.65 for interaction) (Figure 7).

## Key Question 2 What Are the Benefits of Newer PrEP Regimens (TAF-FTC, Injectable Cabotegravir, or the Dapivirine Vaginal Ring) vs. TDF-FTC?

### Summary

#### Oral TAF-FTC vs. TDF-FTC

- Oral TAF-FTC was non-inferior to TDF-FTC in cisgender MSM (98.6%) and transgender women (1.4%) who have sex with men for risk of incident HIV infection and associated with a non-statistically significant decreased risk (1 new trial, n=5,387; 0.3% vs. 0.6%, RR 0.53 [95% CI, 0.23 to 1.26]^162^).

#### Long-Acting Injectable Cabotegravir vs. Daily Oral TDF-FTC

- Long-acting injectable cabotegravir was associated with decreased risk of HIV infection versus oral TDF-FTC in 1 new trial of cisgender MSM (87%) and transgender women (12%) who have sex with men (n=4,490, 0.6% vs. 1.7%; RR 0.33 [95% CI, 0.18 to 0.62]^70^) and in 1 new trial of African women at high risk of HIV infection (n=3,178, 0.3% vs. 2.3%; RR 0.11 [95% CI, 0.04 to 0.31]^88^).

No trials compared the dapivirine vaginal ring to TDF-FTC.

### Evidence

#### Oral TAF-FTC vs. TDF-FTC

One trial, published subsequent to the prior USPSTF report, compared PrEP with oral TAF-FTC versus TDF-FTC^121,162^ (Tables 5 and 6, Appendix B Tables 1–3) The DISCOVER trial (n=5,387) was conducted in Europe and North America in HIV-negative cisgender adult men (98.6%) and transgender women (1.4%) who have sex with men and are at high risk of HIV acquisition, based on having condomless anal intercourse with at least two partners in the previous 12 weeks or a STI (syphilis, rectal gonorrhea, or rectal chlamydia) in the previous 24 weeks (Tables 1–3).^121^ Patients were randomized to once-daily oral TAF-FTC (25-200 mg) or TDF-FTC (300-200 mg) and followed for 96 weeks. Mean age was 34 years. Nine percent of participants were Black and 4 percent were Asian; 24 percent were Hispanic/Latinx ethnicity. Sixteen percent of participants were receiving TDF-FTC PrEP at the time of enrollment. The trial was blinded and rated good quality (Appendix B Table 4).

At 96 weeks, TAF-FTC was associated with a non-statistically significant decreased risk of HIV infection versus TDF-FTC (0.3% vs. 0.6%, RR 0.53, 95% CI 0.23 to 1.26^162^); results were within the pre-specified non-inferiority margin. Adherence was high (98% based on median pill count) and 84 to 96 percent based on dried blood spot samples consistent with ≥4 doses/week (Tables 5 and 6).^121,162^ Findings were similar when five patients suspected of acquiring HIV infection before baseline (diagnosed at week 4) were excluded, or when patients suspected of acquiring HIV infection before baseline or with poor adherence were excluded. There were no statistically significant interactions between effects on HIV infection risk and age (<25 vs. ≥25 years), race (Black vs. other, ethnicity (Hispanic/Latinx vs. other), region (United States vs. other), recreational drug use (yes vs. no), binge alcohol use (yes vs. no), or number of unprotected receptive anal intercourse partners (≤3 vs. >3)^121^. However, stratified estimates were imprecise. No infections occurred in transgender women in either arm. DISCOVER was not designed to evaluate mortality; at 96 weeks, there were a total of five deaths (3 in the TAF-FTC arm and 2 in the TDF-FTC arm).^162^

#### Long-Acting Injectable Cabotegravir vs. Daily Oral PrEP

Two concurrently conducted trials (HPTN trials 083 and 084) compared long-acting injectable cabotegravir (600 mg intramuscular every 8 weeks, following a 5 week oral lead-in phase of 30 mg daily) versus daily oral TDF-FTC (300 mg TDF and 200 mg emtricitabine) (Tables 5 and 6, Evidence B Tables 1–3).^70,88^ HPTN 083 enrolled cisgender MSM or transgender women who have sex with men and HPTN 084 (also referred to as the Long-acting Injectable For the Epidemic [LIFE] trial) enrolled women at high risk for sexual acquisition of HIV infection. Both trials were discontinued early, based on cabotegravir meeting pre-defined thresholds for superiority over oral TDF-FTC in pre-planned interim analyses. The trials were rated good quality (Appendix B Table 4).

In HPTN 083 (n=4,566), 87 percent of participants were MSM and 12 percent were transgender women who have sex with men. The trial was conducted in the United States (37%), Latin America (43%), Asia (16%), and Africa (3.3%).^70^ Among U.S. participants, 50 percent were Black and 50 percent non-Black. High risk for HIV acquisition (required for enrollment) was defined as any of the following within the last six months: condomless receptive anal intercourse (except within a monogamous HIV seronegative concordant relationship), >5 sexual partners, stimulant drug use, or STI (rectal or urethral gonorrhea or chlamydia or incident syphilis).

HPTN 083 was designed as a three-year trial but stopped after the first interim analysis. At median follow-up of 1.4 years, injectable cabotegravir was associated with decreased risk of HIV acquisition versus oral TDF-FTC (0.6% vs. 1.7%; RR 0.33, 95% CI 0.18 to 0.62). Adherence was 91.5% for cabotegravir (based on injections received with a delay of less than 2 weeks) and 74% with TDF-FTC (based on a tenofovir plasma concentration >40 ng/ml, consistent with receipt of daily TDF-FTC in the prior week). In stratified analysis, results were similar in MSM (HR 0.35, 95% CI 0.18 to 0.68) and transgender women (HR 0.34, 95% CI 0.08 to 1.56); however, the estimate for transgender women was imprecise. Among U.S. patients, cabotegravir was associated with decreased risk of HIV acquisition among Black (HR 0.28, 95% CI 0.10 to 0.84) and non-Black persons (HR 0.09, 95% CI 0.00 to 2.05); however, no cases occurred in non-Black persons, resulting in an imprecise estimate. Findings were also similar when results were stratified by age (≤30 vs. >30 years) and geographic region.

HPTN 084 (n=3,178) was conducted in seven countries in sub-Saharan Africa.^88^ Participants were aged 18 to 45 years (median 25 years), female sex assigned at birth, reported at least two episodes of vaginal intercourse in the prior 30 days and were assessed as being at high risk for HIV acquisition using a risk prediction instrument. The risk prediction instrument was developed and validated in African women and has items on: age, married/living with partner, partner providing financial or material support, partner having other partner, alcohol use, sexually transmitted infections, and herpes simplex virus 2 serostatus (score range 0 to 11, high risk defined as score ≥5).^174^ Pregnant and breastfeeding persons were not eligible for enrollment; persons who became pregnant during the trial were switched to open-label TDF-FTC through the end of pregnancy and breastfeeding.

HPTN 084 was designed as a 3.5-year trial but stopped after the second interim analysis. At median follow-up of 1.2 years, injectable cabotegravir was associated with decreased risk of HIV acquisition versus oral TDF-FTC (0.3% vs. 2.3%, RR 0.11, 95% CI 0.04 to 0.31). Adherence with cabotegravir was 93.0 percent (based on injection received with a delay of less than 2 weeks) and for TDF-FTC it was 41.9 percent (based on a plasma concentration ≥40 ng/ml) or 18 percent (based on TFV-DP level consistent with taking ≥4 doses/week). Results were similar in stratified analyses based on age (<25 vs. ≥25 years; for interaction=0.53), contraception method (p for interaction=0.87), and body mass index (≤30 vs. >30 kg/m^2^; p for interaction=0.47).

## Key Question 3 What Is the Diagnostic Accuracy of Provider or Patient Risk Assessment Tools in Identifying Persons at Increased Risk of HIV Acquisition Who Are Candidates for PrEP?

### Summary

- In MSM, five studies (three included in the prior USPSTF report and two new; N=25,488 in validation cohorts) of five different instruments (number of items ranged from 4 to 12) reported moderate discrimination for predicting incident HIV infection in validation cohorts (area under the receiver operating characteristic curve [AUROC], 0.60 to 0.73).^140,155,165,166,171^ Evidence on how discrimination varied by race/ethnicity was inconsistent, with some studies showing lower discrimination and others showing similar discrimination.
- In PWID, one study (n=1,904) included in the prior USPSTF found a 10-item instrument associated with AUROC of 0.72 for incident HIV infection, but had methodological limitations.^167^
- In women evaluated in the emergency department, one new study found a 6-item risk prediction instrument on electronic medical record data associated with sensitivity of 95% for incident HIV infection (21 cases); specificity was not reported.^164^
- In general populations of HIV-uninfected persons, two new studies (n=33,404 and 606,701 in validation cohorts) found two different instruments (number of items 23 and 44) based on automated computerized algorithms on electronic medical record data associated with moderate to high discrimination for incident HIV infection (AUROC 0.77, 95% CI 0.74 to 0.79 and 0.84, 95% CI 0.80 to 0.89).^143,151^

### Evidence

Twelve studies evaluated instruments developed and validated in U.S. cohorts for predicting incident HIV infection (Appendix B Tables 5 and 6).^131,140,142,143,145,151,155,164–167,171^ Seven studies^131,140,142,145,155,166,167^ were included in the prior USPSTF review and five studies^143,151,164,165,171^ were added for this update. Eight studies (two new)^165,171^ evaluated risk prediction instruments in MSM,^131,140,142,145,155,165,166,171^ one study (included in the prior USPSTF report) in PWID,^167^ one study (new) in cisgender women,^164^ and two studies (both new) in general populations of HIV-uninfected persons.^143,151^ No study evaluated instruments for predicting incident HIV infection risk in pregnant or postpartum U.S. persons. Sample sizes (including development and validation cohorts) ranged from 21 to 3,750,664 patients (total N=5,544,500). The duration of assessment for incident HIV infection ranged from 0.77 to 7.85 years in studies that reported this information.

In the studies of general populations^143,151^ and the study of cisgender women,^164^ HIV risk assessment was based solely on data extracted from electronic health records; in the studies of MSM and persons who inject drugs, risk assessment was based on information obtained from patient interviews, questionnaires, and health records. One study evaluated patients attending a clinic for lesbian, gay, bisexual, and transgender persons,^131^ two studies evaluated patients attending STI clinics,^155,171^ one study evaluated patients in the emergency department,^164^ and two studies^143,151^ evaluated patients in large health systems (in one of these studies,^143^ the external validation cohort was a health center focusing on sexual health care); the other studies evaluated persons enrolled in research studies.

All studies had methodological shortcomings (Appendix B Table 7). In all studies, risk assessment instruments were developed and validated using previously collected data, except for two studies^143,151^ that performed prospective validation. In some cases, the criteria had to be slightly modified to match the data available. In eight studies, new HIV infections were identified in the study sample by repeat testing using a longitudinal (cohort) design. One study of MSM identified new HIV infections based on a single test for markers for acute or early HIV infection.^140^ Two studies^143,151^ of general populations excluded patients with HIV infection at baseline but did not perform HIV testing in all patients at baseline; the study of cisgender women^164^ focused on patients with a new positive HIV test in the emergency department and did not describe methods for ruling out prior HIV infection. Four studies used cohorts that included persons who had HIV testing before the year 2000.^155,165–167^ In nine studies, the predictive utility of risk assessment instruments was tested (validated) in cohorts independent from the one used to develop the instrument.^140,142,143,145,151,155,165,166,171^ In two studies, accuracy was only reported for the cohort used to develop the instrument^131,167^ and the study of cisgender women^164^ only reported sensitivity (only cases included in analysis). Cutoffs to define a positive test were predefined in four studies.^142,145,164,171^

#### MSM

Eight studies (N=65,284) including development and validation cohorts) evaluated risk prediction instruments in MSM.^131,140,142,145,155,165,166,171^ The studies evaluated six different risk assessment instruments or criteria; four of these (Beymer, the San Diego Early Test [SDET], the Assessing the Risk of Contracting HIV in Men Who Have Sex With Men [ARCH-MSM], and Menza) were in the prior USPSTF report and two instruments (Seattle PrEP Score and SexPro) were added for this update (Table 7). The number of criteria in the risk assessment instruments ranged from 4 to 12). Items assessed in all of the risk instruments were presence of STIs, sex without a condom (particularly receptive anal sex), and number of sexual partners (Appendix B Tables 5 and 6). Age, race/ethnicity, and illicit drug use were included in some instruments but not others. None of the instruments include an item on plasma HIV viral load or use of antiretroviral therapy (ART) in a sexual partner with HIV. Two of the studies compared the performance of risk prediction instruments against the 2014 CDC indications for PrEP in MSM.^131,171^

Table 7 Study Characteristics of Risk Assessment Tools

Study, Year; Followup; Target | Study design | Population characteristics | Sample size; Acquired HIV | Screening instrument items
Beymer, 2017^131^; Mean 1.8 years; MSM | Cohort; MSM who were negative at baseline and had at least one subsequent test; no formal testing protocol | Derivation cohort: Los Angeles LGBT center (2009 to 2014); Age <25 years: 26%; Ages 25 to 29 years: 26%; Ages 30 to 39 years: 28%; Age ≥40 years: 21%; White: 48%; Hispanic: 32%; Black: 7.8% | Derivation cohort: 9,481; Acquired HIV:; Derivation cohort: 3.9% (370/9,481) | 1) Race/ethnicity; 2) History of any STI; 3) Condom use during receptive anal sex, last partner; 4) Race/ethnicity, last partner; 5) Age difference, last partner; 6) Number sex partners, last 3 months; 7) Intimate partner violence; 8) Ecstasy use, prior 12 months; 9) Methamphetamine use, prior 12 months; 10) Nitrates use, prior 12 months; Scoring of items unclear, total
Hoenigl, 2015^140^; SDET score; Duration of followup not applicable due to cross-sectional design; utilized risk behavior data from prior 12 months; MSM | Cross-sectional; MSM who underwent HIV testing and classified as EAH or no EAH | San Diego “Early Test” (2008 to 2014) cohort; Age (median, years): 30 in acute and early HIV infection, 33 in those who remained uninfected; White: 67%; Asian: 8%; Black: 6%; Hispanic ethnicity: 27% | Derivation cohort: 5,568; Validation cohort: 2,758; Acquired HIV: Entire cohort: 2.4% (200/8,326) for acute and early HIV infection | 1) ≥10 male partners (0 or 2); 2) Condomless receptive anal intercourse and ≥5 male partners (0 or 3); 3) Condomless receptive anal intercourse with HIV-infected partner (0 or 3); 4) Bacterial STI (0 or 2)
Jones, 2017^142^; 1) ARCH-MSM; 2) Menza; 3) SDET; Up to 24 months (mean/median NR); MSM | Cohort; Non-Hispanic, Black and White MSM who were HIV-negative at baseline and had HIV testing every 6 months or until HIV-infected for 24 months | Involve[men]t study cohort; Age (mean, years): 27; White: 54%; Black: 46% | 562; Acquired HIV: 5.7% (32/562); 6 were determined to be acutely infected at baseline (included in analysis) | 1) ARCH-MSM: See Smith 2012 (drug use questions modified from last 6 to last 12 months); 2) SDET: See Hoenigl 2015; 3) Menza: See Menza 2009 (drug use question modified from last 6 to last 12 months)
Krakower, 2019^143^; Duration of followup NR; General population (>15 years of age) | Cohort; Development cohort, Atrius health years 2007 to 2015; Prospective validation cohort, Atrius health year 2016; External validation cohort, Fenway Health 2011 to 2016 | Development cohort; Age: 35.0 years; Gender: Male 42.9%, female 57.0%; Race/ethnicity: White 60.0%, Black 5.2%, American Indian/Alaskan Native 0.1%, Asian 5.8%, Native Hawaiian/Other Pacific Islander <0.1%, Other 3.3%, Hispanic or Latinx 2.9%; Prospective validation cohort; Age: 39.1 years; Gender: Male 42.5%, female 57.5%; Race/ethnicity: White 72.7%, Black 6.9%, American Indian/Alaskan Native 0.1%, Asian 6.4%, Native Hawaiian/Other Pacific Islander <0.1%, Other 4.0%, Hispanic or Latinx 3.2%; External validation cohort; Age: 34.5 years; Gender: Male 62.3%, female 31.0%, transgender or gender nonconforming 6.7; Race/ethnicity: White 68.3%, Black 8.1%, American Indian/Alaskan Native 0.2%, Asian 7.1%, Native Hawaiian/Other Pacific Islander 0.4%, Other 10.2%, Hispanic or Latinx 5.6% | Development cohort: n=1,155,966; Prospect-ive validation cohort: n=537,257; External validation cohort: n=33,404; Acquired HIV:; Development cohort: <0.1% (n=150); Prospect-ive validation cohort: <0.1% (n=16); External validation cohort: 1.3% (n=423) | LASSO algorithm (coefficient), based on electronic health record data:; Diagnosis codes:; 1) Syphilis of any site or stage except late latent (1.00); 2) HIV counseling in previous 2 years (1.10); 3) Contact with or exposure to venereal disease (0.29); Lab tests and results; 4) No. of positive gonorrhea tests in previous 2 years (3.07); 5) No. of chlamydia tests (−0.15); 6) No. of HIV tests (0.12); 7) No. of HIV ELISA tests (0.16); 8) No. of HIV tests in previous 2 years (0.23); 9) No. of HIV RNA tests in previous year (0.15); Testing for acute HIV (1.82); 10) Testing for acute HIV in previous 2 years (0.16); Prescriptions; 11) Intramuscular penicillin G benzathine (1.80); 12) Intramuscular penicillin G benzathine in previous year (1.36); 13) Intermuscular penicillin G benzathine in previous 2 years (0.21); 14) Buprenorphine and naloxone in previous 2 years (0.20); Demographics and registration data; 15) Years of previous HER data (−0.07); 16) At least 1 year of previous HER data (−0.63); 17) At least 2 years of previous HER data (−0.40); 18) Any data on primary language (−0.08); 19) English as primary language (−0.42); 20) Black race (1.06); 21) White race (−0.66); 22) Male gender (1.87)
Lancki, 2018^145^; 1) ARCH-MSM; 2) CDC criteria; 3) Gilead indications; Mean 0.77 years; MSM | Cohort; Self-identified as African American or Black, ages 16 to 29 years, oral or anal intercourse with a man within the past 24 months, located on South Side of Chicago, HIV-uninfected, testing at baseline and at 9-month intervals over 18 months | uConnect study cohort; Age (mean, years): NR; White: 0%; Black: 100% | 300; Acquired HIV: 11% (33/300) | 1) ARCH-MSM: See Smith 2012 (drug use questions modified from last 6 to last 12 months); 2) CDC criteria: Any male sex partner in past 6 months, not in a monogramous partnership with a recently tested, HIV-uninfected man and one of the following:; a) Any anal sex without condoms (receptive or insertive); b) Any STI diagnosed or reported in past 6 months; c) In an ongoing sexual partnership with an HIV-positive male partner; 3) Gilead indications:; a) Inconsistent or no condom use; b) Diagnosis of STI; c) Exchange of sex for commodities; d) Use of illicit drugs or alcohol dependence (excluding marijuana); e) Incarceration; f) Partners of unknown HIV-1 status with above factors
Marcus, 2019^151^; Up to 3 years (validation cohort), (mean/median NR); General population (≥18 years of age) | Cohort; Development cohort: Kaiser Permanente Northern California 2007-2014; Prospective validation cohort: Kaiser Permanente Northern California 2015-2017 data | Development cohort:; Age, mean: 44.6 years; Gender: Male 46.5%; Race/ethnicity: White 51.9%, Hispanic 19.3%, Asian 17.2%, Black 7.4%, other 4.1%, unknown 6.8%; Sexual orientation among known: heterosexual 96.4%, gay or lesbian 2.9%, bisexual 0.7%; Unknown sexual orientation: 84.4%; Validation cohort:; Age, mean: 37.4 years; Gender: Male 49.0%; Race/ethnicity: White 44.0%, Hispanic 24.3%, Asian 23.0%, Black 6.4%, other 2.3%, unknown 5.8%; Sexual orientation among known: heterosexual 95.5%, gay or lesbian 3.4%, bisexual 1.1%; NR sexual orientation: 59.7% | 3,750,664; Development cohort: 3,143,963; Validation cohort: 606,701; Acquired HIV: 0.02% (784/3,750,664) within 3 years | LASSO algorithm (coefficient), based on electronic health record data:; 1) Male; 2) MSM; 3) Sexually active; 4) Age 50-59; 5) Age ≥60; 6) Black; 7) Hispanic; 8) Asian; 9) Other race/ethnicity; 10) Neighborhood deprivation index (NDI), Quintile 2; 11) NDI, Quintile 3; 12) NDI, Quintile 4; 13) Received care in one of three cities with high HIV incidence; 14) Resided in one of eight urban ZIP codes with high HIV incidence; 15) Positive urine test for methadone; 16) Positive urine test for cocaine; 17) No. of HIV testing episodes in previous 2 years; 18) No. of HIV antibody or RNA tests in previous 2 years; 19) No. of tests for rectal gonorrhea or chlamydia; 20) No. of positive tests for rectal gonorrhea or chlamydia in previous 2 years; 21) No. of positive tests for urethral chlamydia in previous 2 years; 22) No. of positive tests for urethral gonorrhea in previous 2 years; 23) No. of RPR or treponemal tests for syphilis in previous 2 years; 24) No. of reactive RPR or positive treponemal tests for syphilis in previous 2 years; 25) Medications for erectile dysfunction; 26) No. of penicillin G benzathine injections with syphilis test within 90 days in previous 2 years; 27) No. of anal wart diagnoses; 28) Depression; 29) Any psychiatric diagnosis; 30) Transgender-related diagnosis; 31) High-risk sexual behavior (homosexual); 32) High-risk sexual behavior (not specified); 33) Exposure to HIV; 34) HIV counseling; 35) HIV education
Menza, 2009^155^; Median 3 years (validation cohort); MSM | Cohort; Derivation cohort, MSM were HIV-negative at baseline and had at least one subsequent HIV test; no formal testing protocol; Validation cohort, MSM were HIV-negative at baseline and underwent retesting every 6 months | Derivation cohort: Public Health-Seattle and King County STI Clinic (2001 to 2008) repeat testers cohort; Age <40 years: 80%; Age ≥40 years: 20%; White, Asian, or Pacific Islander: 77%; Other race: 23%; Validation cohort: Project EXPLORE (1999 to 2001); RCT, control arm (behavioral intervention trial); Age <40 years: 76%; Age ≥40 years: 24%; White, Asian, or Pacific Islander: 75%; Other race: 25% | Derivation cohort: 1,903; Validation cohort: 2,081; Acquired HIV:; Derivation cohort: 5.3% (101/1,903); Validation cohort: 6.9% (144/2,081) | 1) Gonorrhea, chlamydia, or syphilis, or a history of these infections (0 or 4 points); 2) Used methamphetamine or inhaled nitrites in the past 6 months (0 or 11 points); 3) Unprotected anal intercourse with an HIV-infected partner or unknown HIV status in the past year (0 or 1 point); 4) 10 or more male sexual partners in the prior year (0 or 3 points)
Ridgway, 2021^164^; Duration of followup NR; Cisgender women | Cohort; Cohort was cisgender women with a new positive HIV test in the ED between January 1, 2011 and April 30, 2018 | Age, median: 38 years (IQR 29-47); Black: 95.2% (20/21) | 21; Acquired HIV: 21 (100%) | Calculated from data available in electronic medical record:; 1) Male sex (7 points); 2) Chief complaint related to STI-associated symptoms (6 points); 3) Age ≤20 years (13 points); 4) Age 21-24 years (8 points); 5) Positive STI in previous 6 months (21 points); 6) MSM (21 points)
Scott, 2020^165^; Sexual Health Promotion (SexPro) tool mysexpro. org; Ranged from 1-3 years (validation cohorts); MSM, inclusive of Black MSM | Cohort; Development cohort: EXPLORE trial 1991 to 2003, US; Validation cohorts: VAX0004 trial from 1998 to 2002, HPTN061 cohort study from 2009 to 2013, HVTN505 trial from 2009 to 2013 | EXPLORE vs. VAX004 vs. HPTN061 vs. HVTN505; Age <35 years: 60.9%, 48.8%, 44.8%, 68.3%; Race/ethnicity: Black 7.4%, 3.4%, 100%, 18.3%, Latino 14.8%, 0.7%, 7.7%, 8.5% | Development cohort: =4,069; Validation cohorts: Total 8,047 (VAX004 n=4,878 vs. HPTN061 n=973 vs. HVTN505 n=2,196); Acquired HIV: Development cohort: 217; Validation cohorts: Total 433 (VAX004 343 vs. HPTN061 25 vs. HVTN505 65) | Final model (score 1-20, with 20=lowest HIV risk):; 1) Age ≤35; 2) Black race; 3) Latino ethnicity; 4) No. of receptive anal intercourse episodes without a condom with HIV positive or unknown status partners; 5) No. of receptive anal intercourse episodes with a condom with HIV positive or unknown status partners; 6) No. of insertive anal intercourse episodes without a condom with HIV positive or unknown status partners; 7) No. of HIV-negative anal sex partners; 8) 1 HIV-negative sex partner only; 9) Heavy alcohol use; 10) Methamphetamine use; 11) Popper use; 12) Gonorrhea, syphilis, or chlamydia diagnosis
Smith, 2012^166^; HIRI-MSM (now ARCH-MSM); Up to 4 years (mean/median NR); MSM | Cohort; In derivation and validation cohorts, MSM were HIV-negative at baseline and underwent retesting every 6 months | Derivation cohort: VAXGEN 004 (1998 to 1999) RCT (HIV vaccine trial); Ages 18 to 28 years: 19%; Ages 29 to 49 years: 48%; Ages 41 to 48 years: 22%; Age ≥49 years: 11%; Non-Hispanic White: 86%; Validation cohort: Project EXPLORE (1999 to 2001) RCT (behavioral intervention trial); Age ≤25 years: 18%; Ages 26 to 30 years: 22%; Ages 31 to 35 years: 22%; Age ≥36 years: 39%; Non-Hispanic White: 75% | Derivation cohort: 4,386; Validation cohort: 3,368; Acquired HIV:; Derivation cohort: 7.2% (318/4,386); Validation cohort: 4.3% (144/3,368) | 1) Age (0 to 8 points); 2) Total number of male partners, prior 6 months (0 to 7 points); 3) Total number of infected male partners, prior 6 months (0 to 8 points); 4) Times had unprotected receptive anal intercourse with any HIV status partner, prior 6 months (0 or 10 points); 5) Used amphetamines, prior 6 months (0 or 5 points); 6) Used poppers, prior 6 months (0 or 3 points)
Smith, 2015^167^; ARCH-IDUs; Median 5.85 years; PWID | Cohort; Patients who reported drug use in the last 11 years and HIV-uninfected, underwent testing every 6 months | Derivation cohort: ALIVE (1988 to 2008) cohort; Age <30 years: 17%; Ages 30 to <40 years: 46%; Ages 40 to <50 years: 27%; Age ≥50 years: 7.9%; MSM: 1.8% | Derivation cohort: 1,904; Acquired HIV: Derivation cohort 11% (205/1,904) | 1) Age (0 to 38 points); 2) In the last 6 months, in methadone maintenance program (0 or 31 points); Next 5 items receive 0 or 1 points on injection subscore:; 3) In the last 6 months, inject heroin 1 or more times; 4) In the last 6 months, inject cocaine 1 or more times; 5) In the last 6 months, share cooker 1 or more times; 6) In the last 6 months, share needle 1 or more times; 7) In the last 6 months, visit shooting gallery 1 or more times; Add 5 injection subscores, 0=score 0, 1=score 7, 2=score 21, 3=score 24, 4=score 24, 5=score 31
Tordoff, 2020^171^; A: Seattle PrEP Score; B: Menza; C: HIRI-MSM; D: SDET; E: CDC 2018; Mean 7.6 years; MSM | Cohort; Derivation and validation cohorts consisted of 2 STD clinic data sets | Derivation cohort (n=13,527; visits 37,814); Age, median: 33 years; Race/ethnicity: White 65.3%, Black 11.0%, Asian 5.6%, Hispanic 5.0%, Native American/Alaskan Native 1.2%, Multiracial/other/unknown 11.8%; Validation cohort data set (n=9,234; visits 18,908); Age, median: 33 years; Race/ethnicity: White 65.6%, Black 10.6%, Asian 6.0%, Hispanic 4.9%, Native American/Alaskan Native 1.2%, Multiracial/other/unknown 11.9% | Derivation cohort: 13,527; Validation cohort: 9,234; Acquired HIV:; Derivation cohort: 1.2% (440/13,527); Validation cohort: 1.1% (200/9,234) | Seattle PrEP Score model (all items based on prior 12 months); 1) Methamphetamine use* (1 point); 2) Condomless receptive anal intercourse* (1 point); 3) ≥10 sex partners* (1 point); 4) Composite: gonorrhea or syphilis diagnosis or self-reported STI history* (1 point); Menza score; Smith’s HIRI-MSM; Hoenigl’s SDET; CDC 2018; 1) Any condomless anal intercourse (1 point); 2) Any HIV-positive sex partner (1 point); 3) Self-reported history of bacterial STI (1 point); 4) Injection drug use in past 6 months (1 point)

Abbreviations: ARCH-IDUs=Assessing the Risk of Contracting HIV in Injection Drug Users; ARCH-MSM=Assessing the Risk of Contracting HIV in Men Who Have Sex With Men; CDC=Centers for Disease Control and Prevention; EAH=early or acute HIV infection; ED=emergency department; ELISA=enzyme-linked immunosorbent assay; EXPLORE=A Randomized Clinical Trial of the Efficacy of a Behavioral Intervention to Prevent Acquisition of HIV Among Men Who Have Sex With Men; HER=historic environment record; HIRI-MSM=HIV Incidence Risk Index for Men Who Have Sex With Men; HPTN= HIV Prevention Trials Network; HVTN=HIV Vaccine Trials Network; LASSO= Least Absolute Shrinkage and Selection Operators; LGBT=lesbian, gay, bisexual, and transgender; MSM=men who have sex with men; NDI=Neighborhood deprivation index; NR=not reported; PrEP= pre-exposure prophylaxis; PWID=persons who inject drugs; RCT=randomized, controlled trial; RNA=ribonucleic acid; RPR=rapid plasma regain;SDET=San Diego Early Test; STD=sexually transmitted disease; STI=sexually transmitted infection; U.S.=United States.

In the cohorts used to develop the risk assessment instruments, four studies reported that the proportion of Black participants ranged from 6 to 15.2 percent of the population;^131,140,165,171^ two studies reported that 5.0 and 7.4 percent of the population was Hispanic/Latinx,^165,171^ one study reported that 5.6 percent of the populations was Asian and 1.2 percent was Native American or Alaskan Native.^171^ One study reported that 23 percent of the population was non-White, Asian, or Pacific Islander;^155^ and two studies reported a non-White proportion of 14 and 35 percent.^166,171^ Two studies evaluated the performance of previously developed risk assessment instruments in MSM cohorts in which 46 percent^142^ or all participants^145^ were Black. In one other study,^165^ all participants were Black in one of four cohorts used to develop and validate a new risk assessment instrument; in the other three cohorts the proportion of Black participants ranged from 3.4 to 18.3 percent.^165^ One study evaluated patients attending a clinic for lesbian, gay, bisexual, and transgender persons,^131^ two studies evaluated patients attending STI clinics,^155,171^ one study evaluated patients in the emergency department,^164^The incidence of HIV infection in the validation cohorts ranged from 1.1 to 11 percent.

For five instruments, discrimination was similar, with AUROCs in the original validation cohorts (N=25,488) ranging from 0.60 to 0.73.^140,155,165,166,171^ A sixth study (n=9,841)^131^ found that a 10-item instrument developed using data from the Los Angeles Lesbian Gay Bisexual and Transgender (LGBT) Center was associated with better goodness of fit based on the Akaike Information Criterion score than instruments developed in two other studies^155,166^ or criteria from the 2014 CDC guidelines for offering PrEP in MSM.^82^ However, the instrument was not validated using a separate (nondevelopment) sample. In addition, some of the items used in the other risk prediction instruments were not identical to variables available in the Los Angeles LGBT Center database, necessitating use of alternative variables for goodness of fit testing. Other studies reported similar discrimination of different risk assessment instruments in MSM.^140,155,165,171^

The six-item ARCH-MSM instrument is included in the CDC PrEP guideline^175^ as a potential tool to identify PrEP-eligible candidates.^166^ ARCH-MSM was developed using a cohort of patients enrolled in an (ineffective) HIV vaccine trial and validated in a cohort of patients enrolled in an (ineffective) behavioral intervention trial.^166^ Based on a suggested post-hoc cutoff of 10 or greater (range, 0 to 48), 62.4 percent of men in the validation cohort (n=3,368) met the threshold, with a sensitivity for future HIV infection of 81.2 percent and specificity of 37.7 percent, and an AUROC of 0.72. The data in the cohorts used to validate and develop the ARCH-MSM instrument were older (collected in 1998-1999 and 1999-2001, respectively) and had a high prevalence of inhaled nitrite and amphetamine use, both of which are included as items in the instrument.

A four-item instrument by Menza et al (score range, 0 to 19) was validated using data from the same validation cohort (n=2,081) as ARCH-MSM.^155^ A cutoff score of 3 or greater with this instrument provided comparable sensitivity (76%) and specificity (43%) to ARCH-MSM for incident HIV infection at a cutoff of 10 or greater, with 64 percent of the sample meeting this threshold. Discrimination was slightly lower with this instrument (0.66 [95% CI, 0.61 to 0.71]) than with ARCH-MSM (0.72 [CI not reported]). Methamphetamine and inhaled nitrite use were included as a single item in the Menza instrument.

The four-item SDET (score range, 0 to 10 points) was developed using a more contemporary (2008-2014) cohort.^140^ As noted earlier, HIV incidence was estimated based on markers for acute or early HIV infection on a single test. In the validation cohort (n=2,758) A cutoff score of 1 or greater resulted in a sensitivity (73%) and specificity (48%) for incident HIV infection most comparable to ARCH-MSM at a cutoff of 10 or greater. The proportion of the sample meeting this threshold was not reported. Discrimination of the SDET score was very similar to ARCH-MSM (0.70 [95% CI, 0.62 to 0.78] vs. 0.72 [CI not reported]). The SDET does not include items on drug use.

A 10-item instrument by Beymer et al was also developed using a more contemporary cohort (Los Angeles LGBT Center 2009-2014; n=9,481).^131^ The instrument includes items on race/ethnicity, partner age and race/ethnicity, and intimate partner violence, as well as illicit drug use. As noted above, a methodological limitation is that this instrument has only been evaluated in the cohort used to develop the instrument. In addition, methods for scoring the instrument (e.g., points assigned for individual items) were unclear. Using a cutoff score of 5 or greater, 51 percent of the cohort met this threshold, with a sensitivity of 74.6 percent and specificity of 50.2 percent for incident HIV infection. The AUROC was not reported. Goodness of fit testing based on the Akaike Information Criterion and Schwarz Bayesian Criteria was slightly better with this instrument than with the ARCH-MSM and similar to the Menza instrument, but this finding is difficult to interpret because goodness of fit was evaluated using data from the same cohort used to develop this instrument, and the other instruments included items that were not an exact match with data available in this database.

The 2014 CDC guideline includes recommended indications for PrEP in MSM (any anal sex without condoms in past 6 months, any STI diagnosed or reported in past 6 months, or ongoing sexual relationship with a partner with HIV).^82^ In the study by Beymer et al, goodness of fit was slightly better with the Los Angeles LGBT Center instrument than the CDC criteria.^131^

The 12-item SexPro instrument (score range, 1 to 20 points) was developed using persons enrolled in an (ineffective) behavioral intervention trial (1999-2001) and validated in three cohorts of participants enrolled in other clinical trials (2009-2013).^165^ In addition to items on sexual risk behaviors, STIs, and illicit drug use, SexPro includes items on age, race/ethnicity, and alcohol use. In the validation cohorts (n=8,047), a cutoff score of 16 or greater on SexPro was associated with sensitivities of 64.4, 100, and 75.4 percent for incident HIV infection. Specificities were 67.4, 0, and 51.8 percent, respectively. The cohort with sensitivity of 100 percent and specificity of 0 percent only included Black participants (the proportion of Black participants in the other cohorts was 3.4% and 18.3%), who had lower SexPro scores compared with other participants. Despite the differences in diagnostic accuracy at the selected cutoff, discrimination was similar across the three validation cohorts (AUROC 0.71 to 0.73). In these cohorts, sensitivity of ARCH-MSM at a cutoff score of ≥10 ranged from 80.0 to 86.2 percent and specificity ranged from 43.2 to 61.2 percent; discrimination of ARCH-MSM (AUROC 0.74 to 0.75) was similar to the SexPro score.

The four-item Seattle PrEP Score (score range, 0 to 4 points) was developed using two large STI clinic cohorts (2001-2015).^171^ In the validation cohort (n=9,234), a cutoff score of 2 or greater was associated with a sensitivity of 46.3 percent and specificity of 69.0 percent. In the combined development and validation cohorts (n=22,761), the Seattle PrEP score performed similarly to the SDET at a cutoff score of 5 or greater (sensitivity for incident HIV infection 33.1% and specificity 67.1%) in this population; three other instruments (Menza [cutoff ≥2], ARCH-MSM [cutoff ≥10], and CDC [meeting criteria for PrEP]) reported higher sensitivity (range 62.7% to 86.7%) but lower specificity (range 13.3% to 37.4%). For all five instruments, discrimination was similar (based on combined development and validation cohorts, 0.66 for Seattle PrEP score and 0.61 to 0.66 for the others [AUROC for instruments other than Seattle PrEP score not reported separately for the validation cohort]).

Evidence on how the accuracy of risk prediction instruments in MSM varied according to race or ethnicity was inconsistent. Two studies found that risk prediction instruments performed more poorly in Black MSM. In one study of MSM, the AUROC for the ARCH-MSM, SDET, and Menza instruments ranged from 0.51 to 0.62 overall, from 0.49 to 0.63 in Black MSM, and from 0.60 to 0.67 in White MSM.^142^ In the other study, the AUROC for the ARCH-MSM was 0.57 in Black MSM, and similar using criteria derived from the CDC recommendations (AUROC, 0.51) or the PrEP package insert (AUROC, 0.54).^145^ However, two other studies reported similar discrimination of risk prediction instruments in Black and White MSM. In one study, the AUROC of the Seattle PrEP Score was 0.64 in White MSM and 0.62 in Black MSM.^171^ In the other study, the AUROC of the SexPro instrument was 0.74 in two validation cohorts of primarily (>95%) White MSM and 0.75 in a validation cohort of 100% Black MSM.^165^ One study reported that discrimination of the SexPro instrument was higher in Asian (0.91) than White (0.64) MSM, but the estimate for Asian MSM was based on only six incident HIV cases and imprecise.^165^

#### PWID

The seven-item Assessing the Risk of Contracting HIV in Injection Drug Users (ARCH-IDUs) instrument (score range, 0 to 100 points) was developed using a cohort (1988-2008) of current and former PWID in Baltimore.^167^ ARCH-IDUs is included as a tool for identifying persons who inject drugs at high risk for HIV acquisition in the 2021 CDC guideline.^175^ The instrument includes seven items on age, enrollment in a methadone maintenance program, and drug use behaviors. The population in the cohort used to develop ARCH-IDUs was primarily non-Hispanic Black (93%) persons; incident HIV infection occurred in 11 percent of the development cohort.

In the sample used to develop ARCH-IDUs (n=1,904), sensitivity was 86 percent and specificity was 42 percent at a cutoff of 46 or greater, with 58 percent of the cohort meeting this threshold. The AUROC was 0.72 (CI not reported). ARCH-IDUs has not been evaluated in a separate validation cohort.

#### Women

One new study by Ridgeway et al evaluated a previously developed 6-item risk prediction instrument (range, 0 to 76) based on data extracted from the electronic medical record.^164^ Even though the instrument included items on male sex and MSM (in addition to STI history or symptoms and age), it was evaluated in a cohort (2011-2018) of women evaluated in the emergency department. Among 21 women newly diagnosed with HIV infection in the emergency department, sensitivity of the instrument was 95 percent (20/21). Because the study only evaluated incident HIV cases, specificity was not available. In this study, all incident HIV infections except for one occurred in Black women.

#### General Populations of HIV-Negative Persons

Two new studies (N=5,477,291, based on derivation and validation cohorts) evaluated instruments for predicting risk of HIV Infection in general populations of HIV-negative persons.^143,151^ Both instruments were developed using large health systems cohorts (2007 to 2015 and 2007 to 2014) and utilized a computerized algorithm developed with machine learning on items extracted from the electronic medical record. The proportion of Black participants in the cohorts used to develop these instruments ranged from 5.2 to 8.1 percent, the proportion of Hispanic/Latinx participants ranged from 2.9 to 5.6 percent, and the proportion of Asian participants ranged from 5.8 to 23 percent. In the cohorts used to validate the instruments, incident HIV infection occurred in 0.01 and 1.3 percent of participants.

One study evaluated a 23-item instrument (score range, 0 to 100,000) that included items on STI history or use of penicillin G, prior HIV testing, use of medications for opioid use disorder, race, gender, and primary language.^143^ In the external validation cohort (n=33,404), at a cutoff of 2 or greater (indicating the top 2% of HIV risk scores), sensitivity for incident HIV infection was 98.1 percent and specificity was 26.8 percent. At a cutoff of 8 or greater, sensitivity was 91.3 percent and specificity was 44.2 percent. The AUROC was 0.77 (95% CI 0.74 to 0.79). In the other study, which evaluated a 44-item instrument, sensitivity for incident HIV infection based on classification as high or very high risk (≥0.20%) was 59.1 percent and specificity was 97.8 percent in the validation cohort (n=606,701), with an AUROC of 0.84 (95% CI 0.80 to 0.89).^151^ In this study, sensitivity for incident HIV infection was similar in Black and White patients.

## Key Question 4 What Are the Harms of PrEP vs. Placebo or No PrEP When Used for the Prevention of HIV Infection?

### Summary

#### Oral PrEP vs. Placebo or No PrEP

- There was no difference between oral PrEP with TDF-FTC or TDF versus placebo or no PrEP in risk of serious adverse events (12 trials, N=18,292; RR, 0.93 [95% CI, 0.77 to 1.12]; I^2^=56%).^51–55,66–68,118,137,170,172^
- Oral PrEP with TDF-FTC or TDF was associated with a trend toward increased risk of withdrawals due to adverse events versus no PrEP or placebo that was not statistically significant (4 trials, N=10,563; RR, 1.25 [95% CI, 0.99 to 1.59]; I^2^=0%).^51,55,66,137,172^
- Oral PrEP with TDF-FTC or TDF was associated with increased risk of renal adverse events (primarily ≥grade 1 creatinine elevation) (12 trials, N=18,170; RR, 1.43 [95% CI, 1.18 to 1.75]; I^2^=0%; absolute risk difference [ARD], 0.56% [95% CI, 0.09% to 1.04%]) versus no PrEP or placebo.^51–55,66–68,118,137,170,172^ Renal abnormalities generally resolved following PrEP cessation.
- Oral PrEP with TDF-FTC or TDF was associated with increased risk of gastrointestinal adverse events (12 trials, N=18,300; RR, 1.63 [95% CI, 1.26 to 2.11]; I^2^=43%; ARD, 1.95% [95% CI, 0.48% to 3.43%]) versus placebo or no PrEP;^51–55,66–68,118,137,170,172^ gastrointestinal events were generally not serious and diminished over time.
- Oral PrEP with TDF-FTC or TDF was associated with a small, non-statistically significant increased risk of fracture versus placebo (7 trials, N=15,241; RR, 1.23 [95% CI, 0.97 to 1.56]; I^2^=0%).^51–54,66,137,170^
- There were no differences between oral PrEP with TDF-FTC or TDF versus placebo in risk of syphilis (4 trials, N=10,775; RR, 1.08 [95% CI, 0.98 to 1.18]; I^2^=0%), gonorrhea (5 trials; RR, 1.07 [95% CI, 0.82 to 1.39]; I^2^=49%), chlamydia (5 trials; RR, 0.97 [95% CI, 0.80 to 1.18]; I^2^=59%) or combined bacterial STIs (2 trials; RR, 1.14 [95% CI, 0.97 to 1.34], I^2^=16%).^51,118,137,170,172^
- There was no difference between oral PrEP with TDF-FTC or TDF versus placebo in risk of HSV (3 trials, N=4,088; RR, 0.85 [95% CI, 0.67 to 1.07]; I^2^=19%) or hepatitis C virus infection (2 trials, N=896; RR, 0.73 [95% CI, 0.25 to 2.10]; I^2^=0%).^66,118,120,150,170^
- Among persons who became pregnant in PrEP trials, PrEP was not associated with increased risk of spontaneous abortion (3 trials, N=415; RR, 1.09 [95% CI, 0.79 to 1.50]; I^2^=0%).^68,157,172^ One trial found no differences between PrEP versus placebo in pregnancy rate, risk of preterm birth, birth anomalies, or postpartum infant mortality.^157^

#### Dapivirine Vaginal Ring vs. Placebo Ring

- Results for the dapivirine vaginal ring versus placebo and risk of serious adverse events were very imprecise and inconsistent (2 trials, N=4,587, RR, 1.73 [95% CI 0.60 to 4.94]; I2=80%).^73,74^
- There were no differences between the dapivirine vaginal ring versus placebo ring in risk of STIs or incidence of pregnancy (2 trials, N=4,587).^73,74^

### Evidence

#### Oral PrEP vs. Placebo or No PrEP

##### Serious Adverse Events

There was no difference between oral PrEP with TDF or TDF-FTC versus placebo in risk of serious adverse events (12 trials, N=18,292; RR, 0.93 [95% CI, 0.77 to 1.12]; I^2^=56%) (Table 8; Figure 12).^51–55,66–68,118,137,170,172^ Results using the profile likelihood method were similar (RR, 0.95 [95% CI, 0.78 to 1.23]) and there was no funnel plot asymmetry (Egger test p-value=0.53) (Appendix C Figure 3). Nine trials evaluated daily PrEP and two trials combined data for daily and intermittent/event-driven PrEP;^67,68^ one trial of event-driven PrEP (IPERGAY) reported a risk of serious adverse events (RR, 1.07 [95% CI, 0.58 to 1.98]) that was similar to the pooled estimate from trials of daily PrEP (11 trials; RR, 0.92 [95% CI, 0.76 to 1.12]; I^2^=59%).^66^ There were also no differences between oral PrEP versus placebo in risk of serious adverse events when trials were stratified according to whether they used TDF (5 trials; RR, 0.79 [95% CI, 0.56 to 1.12]; I^2^=72%)^51–55^ or TDF-FTC (9 trials; RR, 1.02 [95% CI, 0.81 to 1.30]; I^2^=46%; p=0.23 for interaction) (Figure 12).^51,54,66–68,118,137,170,172^ One trial (PROUD) found TDF-FTC associated with a greater risk of serious adverse events than placebo (7.6% [21/375] vs. 2.2% [6/269]; RR, 3.42 [95% CI, 1.40 to 8.35]).^118^ It differed from other trials in that it used an open-label design. Serious adverse events reported by more than one patient on TDF-FTC in PROUD included gastrointestinal events, fractures, and psychiatric events.

Figure 12 Meta-Analysis: Serious Adverse Events Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 12 is a forest plot of serious adverse events stratified by study drug with two subgroups. The risk ratio for 5 studies in the TDF subgroup is 0.79 (95% confidence interval 0.56 to 1.12) with an I-squared value of 72%. The risk ratio for 9 studies in the FTC-TDF subgroup is 1.02 (95% confidence interval 0.81 to 1.30) with an I-squared value of 46%. The overall risk ratio for all studies is 0.93 (95% confidence interval 0.77 to 1.12) with an I-squared value of 56%.

Table 8 Adverse Events in Placebo-Controlled RCTs of PrEP

Outcome | Number of trials^*^ | RR (95% CI) | I^2^
Serious adverse events; PrEP drug regimen (p=0.23 for interaction) | 12^51–55,66–68,118,137,170,172^ | 0.93 (0.77 to 1.12) | 56%
TDF | 5^51–55^ | 0.79 (0.56 to 1.12) | 72%
TDF-FTC | 9^51,54,66–68,118,137,170,172^ | 1.02 (0.81 to 1.30) | 46%
Withdrawal due to adverse events; PrEP drug regimen (p=0.67 for interaction) | 4^51,66,137,172^ | 1.25 (0.99 to 1.59) | 0%
TDF | 1^51^ | 1.00 (0.34 to 2.92) | Not applicable
TDF-FTC | 4^51,66,137,172^ | 1.27 (1.00 to 1.59) | 0%
Fracture; PrEP drug regimen (p=0.50 for interaction) | 8^51–54,66,118,137,170^ | 1.23 (0.97 to 1.56) | 0%
TDF | 4^51–54^ | 1.29 (0.98 to 1.70) | 0%
TDF-FTC | 6^51,54,66,118,137,170^ | 1.06 (0.66 to 1.72) | 0%
Renal adverse events; PrEP drug regimen (p=0.31 for interaction) | 12^51–55,66–68,118,137,170,172^ | 1.43 (1.18 to 1.75) | 0%
TDF | 5^51–55^ | 1.24 (0.87 to 1.76) | 0%
TDF-FTC | 9^51,54,66–68,118,137,170,172^ | 1.54 (1.21 to 1.96) | 0%
Gastrointestinal adverse events; PrEP drug regimen (p=0.30 for interaction) | 12^51–55,66–68,118,137,170,172^ | 1.63 (1.26 to 2.11) | 43%
TDF | 5^51–55^ | 1.45 (1.13 to 1.85) | 0%
TDF-FTC | 9^51,54,66–68,118,137,170,172^ | 1.84 (1.26 to 2.70) | 49%

* Two trials included both TDF and TDF-FTC arms and one trial included both TDF and TDF-FTC arms.

Abbreviations: CI=confidence interval; FTC=emtricitabine; PrEP=pre-exposure prophylaxis; RR=relative risk; TDF=tenofovir disoproxil fumarate.

##### Withdrawals Due to Adverse Events

Withdrawals due to adverse events were reported in five trials (Table 8).^51,55,66,137,172^ One trial (n=936)^55^ reported no withdrawals with either PrEP or placebo. In the other trials, oral PrEP was associated with a small, non-statistically significant trend toward increased risk of withdrawal due to adverse events versus placebo (4 trials, N=10,563; RR, 1.25 [95% CI, 0.99 to 1.59]; I^2^=0%). One trial evaluated TDF (RR, 1.00 [95% CI, 0.34 to 2.92]) and four evaluated TDF-FTC (RR, 1.27 [95% CI, 1.00 to 1.62]; p=0.67 for interaction) (Figure 13). The only trial to report a statistically significant increase in risk of withdrawals (either temporary or permanent) due to adverse events was the FEM-PrEP trial, which evaluated TDF-FTC (RR, 1.68 [95% CI, 1.10 to 2.56]).^172^ The majority (∼90%) of withdrawals in this trial were the result of laboratory abnormalities (grade 2 or higher). In FEM-PrEP, there was no difference in risk of withdrawal due to clinical adverse events, although the estimate was imprecise (RR, 3.53 [95% CI, 0.73 to 17]).

Figure 13 Meta-Analysis: Withdrawals Due to Adverse Events Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; M-H=Mantel-Haenszel test; iPrEx=Pre-Exposure Prophylaxis Initiative; PrEP=pre-exposure prophylaxis; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF=tenofovir disoproxil fumarate; U.S.=United States.

Figure 13 is a forest plot of withdrawals due to adverse events stratified by study drug with two subgroups. The risk ratio for 2 studies in the TDF subgroup is 1.00 (95% confidence interval 0.34 to 2.92). The risk ratio for 4 studies in the TDF-FTC subgroup is 1.27 (95% confidence interval 1.00 to 1.62) with an I-squared value of 0%. The overall risk ratio for all studies is 1.25 (95% confidence interval 0.99 to 1.59) with an I-squared value of 0%.

##### Fracture

Tenofovir exposure is associated with bone loss,^148,159,170,176^ which could result in increased fracture risk. Oral PrEP with TDF or TDF-FTC was associated with a small, non-statistically significant increased risk of fracture versus placebo (7 trials, N=15,241; RR, 1.23 [95% CI, 0.97 to 1.56]; I^2^=0%; ARD, 0.21% [95% CI, −0.21% to 0.62%]) (Table 8; Figure 14).^51–54,66,137,170^ The meta-analysis was heavily weighted (64%) by the Bangkok Tenofovir Study of PWID, which reported a relatively high fracture rate (7.8% vs. 6.0%; RR, 1.29 [95% CI, 0.96 to 1.74]).^53^ There was no statistically significant interaction between the PrEP regimen and fracture risk (p=0.50) (Figure 14). One trial of event-driven dosing (IPERGAY) did not find PrEP associated with an increased risk of fracture, but the estimate was imprecise (RR, 0.51 [95% CI, 0.13 to 1.99]).^66^ Patients averaged 15 doses per month in IPERGAY; effects of intermittent/event-driven dosing with less frequent exposure to PrEP on fracture risk are not available. In trials for which details were available regarding the mechanism of fracture, all or almost all fractures were traumatic.^126^

Figure 14 Meta-Analysis: Fracture Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=conftdence interval; df=degrees of freedom; FTC=emtricitabine; IPERGAY=bitervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 14 is a forest plot of fractures stratified by study drug with two subgroups. The risk ratio for 4 studies in the TDF subgroup is 1.29 (95% confidence interval 0.98 to 1.70) with an I-squared value of 0%. The risk ratio for 6 studies in the FTC-TDF subgroup is 1.06 (95% confidence interval 0.66 to 1.72) with an I-squared value of 0%. The overall risk ratio for all studies is 1.23 (95% confidence interval 0.97 to 1.56) with an I-squared value of 0%.

Results were similar when the profile likelihood method was used for pooling (RR, 1.23 [95% CI, 0.92 to 1.58]). There were discrepancies between the number of fractures reported in journal reports of three trials (the CDC Safety Study,^52^ iPrEx,^137^ and Partners PrEP^51^) and the FDA review^126^ of these trials (Appendix B Tables 1–3). However, the pooled estimate was similar when the FDA data were used in the meta-analysis in place of data reported in the journal articles (RR, 1.20 [95% CI, 0.96 to 1.52]) (Figure 15).

Figure 15 Meta-Analysis: Fracture Using FDA Data (iPrEx, Partners PrEP, CDC Safety Study)

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval, df=degrees of freedom; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test, PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 15 is a forest plot of fracture using FDA data (iPrEx, Partners PrEP, CDC Safety Study). The risk ratio for 8 studies is 1.20 (95% confidence interval 0.96 to 1.52) with an I-squared value of 0%.

##### Renal Adverse Events

Oral PrEP with TDF or TDF-FTC was associated with increased risk of renal adverse events (primarily ≥grade 1 serum creatinine elevation) versus placebo (12 trials, N=18,170; RR, 1.43 [95% CI, 1.18 to 1.75]; I^2^=0%; ARD, 0.56% [95% CI, 0.09% to 1.04%]) (Table 8; Figure 16).^51–55,66–68,118,137,170,172^ Results were similar with the profile likelihood method (RR, 1.44 [95% CI, 1.12 to 1.79]) and no funnel plot asymmetry was present (Egger test p-value=0.29) (Appendix C Figure 4). A trial of event-driven PrEP (IPERGAY) reported an increased risk of renal adverse events (RR, 1.77 [95% CI, 1.06 to 2.95]) consistent with the pooled estimate from trials of daily PrEP (11 trials; RR, 1.38 [95% CI, 1.11 to 1.72]; I^2^=0%).^66^ There was no clear difference in risk of renal adverse events when trials were stratified according to use of TDF or TDF-FTC (p=0.31 for interaction). Serious renal events were rare, and no trial reported a difference between PrEP and placebo in risk of serious renal events or withdrawals due to renal events (Appendix B Tables 1–3).

Figure 16 Meta-Analysis: Renal Adverse Events Stratified by Study Drug

Note: Defined as ≥grade 1 serum creatinine elevation unless otherwise noted.

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 16 is a forest plot of renal adverse events stratified by study drug with two subgroups. The risk ratio for 5 studies in the TDF subgroup is 1.24 (95% confidence interval 0.87 to 1.76) with an I-squared value of 0%. The risk ratio for 9 studies in the FTC-TDF subgroup is 1.54 (95% confidence interval 1.21 to 1.96) with an I-squared value of 0%. The overall risk ratio for all studies is 1.43 (95% confidence interval 1.18 to 1.75) with an I-squared value of 0%.

Six trials^51,67,68,149,152,168^ evaluated whether renal adverse events while on PrEP were persistent (Appendix B Tables 1–3). Three studies^51,149,168^ reported a return to normal serum creatinine levels after cessation of PrEP and two others^67,68^ reported normalization of creatinine level without PrEP cessation.^158^ In one other trial of PWID (the Bangkok Tenofovir Study), six of seven cases of grade 2 or worse creatinine elevation resolved following PrEP cessation.^152^

##### Gastrointestinal Adverse Events

Oral PrEP with TDF or TDF-FTC was associated with increased risk of gastrointestinal adverse events (primarily nausea) versus placebo (12 trials, N=18,300; RR, 1.63 [95% CI, 1.26 to 2.11]; I^2^=43%; ARD, 1.95% [95% CI, 0.48% to 3.43%]) (Table 8; Figure 17).^51–55,66–68,118,137,170,172^ Results were similar using the profile likelihood method (RR, 1.67 [95% CI, 1.26 to 2.25]) and there was no funnel plot asymmetry (Egger test p-value=0.81) (Appendix C Figure 5). The risk of gastrointestinal adverse events was highest in one trial of event-driven PrEP, but the estimate was imprecise (8.0% vs. 1.0%; RR, 8.08 [95% CI, 1.88 to 34.68]).^66^ The HPTN 067/ADAPT trial, which compared different PrEP dosing strategies (daily, time-based, or event-driven), found no difference in risk of gastrointestinal events between daily and non-daily PrEP (Appendix B Tables 1–3).^130^ When stratified according to the PrEP regimen used, the risk of gastrointestinal adverse events was increased for both TDF (5 trials; RR, 1.45 [95% CI, 1.13 to 1.85]; I^2^=0%)^51–55^ and TDF-FTC (9 trials; RR, 1.84 [95% CI, 1.26 to 2.70]; I^2^=49%),^51,54,66–68,118,137,170,172^ with no statistically significant interaction by regimen (p=0.30) (Figure 17). Among studies that reported rates of diarrhea^51,52,54,66,118,170,172^ or vomiting^54,172^ separately, none reported a significant difference between PrEP and placebo (Appendix B Tables 1–3). Three trials reported that the risk of gastrointestinal events diminished over time.^53,137,170^ Serious gastrointestinal events were rare in the trials that reported this outcome, with no differences between PrEP and placebo (Appendix B Tables 1–3).^54,55,118,137,170,172^

Figure 17 Meta-Analysis: Gastrointestinal Adverse Events Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CDC=Centers for Disease Control and Prevention; CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; IAVI=International AIDS Vaccine Initiative; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; Study of TDF=Study of Tenofovir Disoproxil Fumarate; TDF=tenofovir disoproxil fumarate; TDF2= Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 17 is a forest plot of gastrointestinal adverse events stratified by study drug with two subgroups. The risk ratio for 5 studies in the TDF subgroup is 1.45 (95% confidence interval 1.13 to 1.85) with an I-squared value of 0%. The risk ratios for 9 studies in the FTC-TDF subgroup is 1.84 (95% confidence interval 1.26 to 2.70) with an I-squared value of 49%. The overall risk ratio for all studies is 1.63 (95% confidence interval 1.26 to 2.11) with an I-squared value of 43%.

##### STIs

There were no differences between PrEP versus placebo or no PrEP in risk of syphilis (4 trials, N=10,775; RR, 1.08 [95% CI, 0.98 to 1.18]; I^2^=0%) (Figure 18), gonorrhea (5 trials, N=9,296; RR, 1.07 [95% CI, 0.82 to 1.39]; I^2^=49%) (Figure 19), chlamydia (5 trials, N=9,296; RR, 0.97 [95% CI, 0.80 to 1.18]; I^2^=59%) (Figure 20), or combined bacterial STIs (2 trials, N=5,291; RR, 1.14 [95% CI, 0.97 to 1.34]; I^2^=16%) (Figure 21; Table 9).^51,118,137,170,172^ Combined STIs were defined as gonorrhea, chlamydia, or trichomoniasis in one trial^51^ and gonorrhea, chlamydia, or syphilis in the other.^118^ When trials were stratified according to the PrEP regimen, TDF was associated with lower risk of chlamydia or gonorrhea versus placebo than TDF-FTC, but neither regimen was associated with increased risk, and only one trial evaluated TDF. All of the trials except for one were blinded. This could affect risk of STIs if participants who do not know whether they are taking PrEP or placebo behave differently than those who know whether or not they are taking PrEP. The open-label PROUD trial,^118^ which enrolled MSM, found no statistically significant associations between PrEP versus no PrEP and risk of syphilis (RR, 1.28 [95% CI, 0.76 to 2.16]), gonorrhea (RR, 1.07 [95% CI, 0.86 to 1.34]), or chlamydia (RR, 1.32 [95% CI, 0.98 to 1.79]), although estimates were imprecise and indicated increased risk. Although the unadjusted estimate for risk of combined STIs in PROUD was statistically significant (RR, 1.20 [95% CI, 1.01 to 1.42]), the difference was no longer statistically significant after adjustment for the number of screenings (adjusted OR, 1.07 [95% CI, 0.78 to 1.46]). This is consistent with a higher rate in PROUD of condomless receptive anal intercourse with 10 or more partners among men randomized to PrEP (20%) versus deferred PrEP (12%).^118^ In the nonrandomized Demo Project (a PrEP demonstration project in MSM), 26 percent of participants had an STI at baseline and approximately 50 percent had an STI while on PrEP.^177^

Figure 18 Meta-Analysis: Syphilis Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FTC=emtricitabine; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF=tenofovir disoproxil fumarate; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 18 is a forest plot of syphilis stratified by study drug with two subgroups. The risk ratio for 2 studies in the TDF subgroup is 1.13 (95% confidence interval 0.66 to 1.93) with an I-squared value of 0%. The risk ratio for 4 studies in the FTC-TDF subgroup is 1.07 (95% confidence interval 0.98 to 1.18) with I-squared value of 0%. The overall risk ratio for all studies is 1.08 (95% confidence interval 0.98 to 1.18) with an I-squared value of 0%.

Figure 19 Meta-Analysis: Gonorrhea Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF=tenofovir disoproxil fumarate; TDF2= Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 19 is a forest plot of gonorrhea stratified by study drug with two subgroups. The risk ratio for 1 study in the TDF subgroup is 0.57 (95% confidence interval 0.33 to 0.98). The risk ratio for 5 studies in the FTC-TDF subgroup is 1.15 (95% confidence interval 0.97 to 1.37) with an I-squared value of 2%. The overall risk ratio for all studies is 1.07 (95% confidence interval 0.82 to 1.39) with an I-squared value of 49%.

Figure 20 Meta-Analysis: Chlamydia Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF=tenofovir disoproxil fumarate; TDF2= Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 20 is a forest plot of chlamydia stratified by study drug with two subgroups. The risk ratio for 1 study in the TDF subgroup is 0.68 (95% confidence interval 0.52 to 0.90). The risk ratio for 5 studies in the FTC-TDF subgroup is 1.07 (95% confidence interval 0.94 to 1.22) with an I-squared value of 0%. The overall risk ratio for all studies is 0.97 (95% confidence interval 0.80 to 1.18) with an I-squared value of 59%.

Figure 21 Meta-Analysis: Combined Bacterial STIs Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FTC=emtricitabine; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF=tenofovir disoproxil fumarate; U.S.=United States.

Figure 21 is a forest plot of combined bacterial STIs stratified by study drug with two subgroups. The risk ratio for 1 study in the TDF subgroup is 1.21 (95% confidence interval 0.86 to 1.72). The risk ratio for 2 studies in the FTC-TDF subgroup is 1.07 (95% confidence interval 0.80 to 1.44) with an I-squared value of 58%. The overall risk ratio for all studies is 1.14 (95% confidence interval 0.97 to 1.34) with an I-squared value of 16%.

Table 9 Risk of STI in Placebo-Controlled RCTs of PrEP

Outcome | Number of trials^*^ | RR (95% CI) | I^2^
Any bacterial sexually transmitted infection; PrEP drug regimen (p=0.60 for interaction); HIV risk category (p=0.38 for interaction) | 2^51,118^ | 1.14 (0.97 to 1.34) | 16%
TDF | 1^51^ | 1.21 (0.86 to 1.72) | Not applicable
TDF-FTC | 2^51,118^ | 1.07 (0.80 to 1.44) | 58%
Heterosexual men and women | 1^51^ | 1.05 (0.82 to 1.35) | Not applicable
MSM | 1^118^ | 1.20 (1.01 to 1.42) | Not applicable
Syphilis; PrEP drug regimen (p=0.86 for interaction); HIV risk category (p=0.90 for interaction) | 4^51,54,118,137^ | 1.08 (0.98 to 1.18) | 0%
TDF | 2^51,54^ | 1.13 (0.66 to 1.93) | 0%
TDF-FTC | 4^51,54,118,137^ | 1.07 (0.98 to 1.18) | 0%
Heterosexual men and women | 2^51,54^ | 1.05 (0.71 to 1.54) | 0%
MSM | 2^118,137^ | 1.08 (0.98 to 1.18) | 0%
Gonorrhea; PrEP drug regimen (p=0.02 for interaction); HIV risk category (p=0.59 for interaction) | 5^54,118,137,170,172^ | 1.07 (0.82 to 1.39) | 49%
TDF | 1^54^ | 0.57 (0.33 to 0.98) | Not applicable
TDF-FTC | 5^54,118,137,170,172^ | 1.15 (0.97 to 1.37) | 2%
Heterosexual men and women | 3^54,170,172^ | 1.20 (0.76 to 1.92) | 69%
MSM | 2^118,137^ | 1.05 (0.85 to 1.30) | 0%
Chlamydia; PrEP drug regimen (p=0.004 for interaction); HIV risk category (p=0.46 for interaction) | 5^54,118,137,170,172^ | 0.97 (0.80 to 1.18) | 59%
TDF | 1^54^ | 0.68 (0.52 to 0.90) | Not applicable
TDF-FTC | 5^54,118,137,170,172^ | 1.07 (0.94 to 1.22) | 0%
Heterosexual men and women | 3^54,170,172^ | 0.81 (0.47 to 1.41) | 93%
MSM | 2^118,137^ | 1.09 (0.62 to 1.92) | 50%
Herpes simplex virus infection; PrEP drug regimen (p=0.67 for interaction); HIV risk category (p=0.06 for interaction) | 3^120,150,170^ | 0.85 (0.67 to 1.07) | 19%
TDF | 1^120^ | 0.76 (0.48 to 1.21) | Not applicable
TDF-FTC | 3^120,150,170^ | 0.86 (0.62 to 1.18) | 40%
Heterosexual men and women | 2^120,170^ | 0.73 (0.56 to 0.96) | 0%
MSM | 1^150^ | 1.12 (0.80 to 1.56) | Not applicable
Hepatitis C virus infection ^†^ | 2^66,118^ | 0.73 (0.25 to 2.10) | 0%

* Two trials included both TDF and TDF-FTC arms.

† Both trials evaluated TDF-FTC in MSM.

Abbreviations: CI=confidence interval; FTC=emtricitabine; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis RR=relative risk; TDF=tenofovir disoproxil fumarate.

PrEP was not associated with increased risk of bacterial STIs when trials (open-label or blinded) were stratified according to whether they evaluated MSM or persons at risk of HIV infection via heterosexual contact (Table 9; Figures 22–25). The only trial conducted in PWID did not report risk of STI.^53^ Results for bacterial STIs were similar when data were pooled using the profile likelihood method.

Figure 22 Meta-Analysis: Syphilis Stratified by HIV Risk Category

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenzel test; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF=tenofovir disoproxil fumarate; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 22 is a forest plot of syphilis stratified by HIV risk category with two subgroups. The risk ratio for 2 studies in the heterosexual men and women category is 1.05 (95% confidence interval 0.71 to 1.54) with an I-squared value of 0%. The risk ratio for 2 studies in the MSM category is 1.08 (95% confidence interval 0.98 to 1.18) with an I-squared value of 0%. The overall risk ratio for all studies is 1.08 (95% confidence interval 0.98 to 1.18) with an I-squared value of 0%.

Figure 23 Meta-Analysis: Gonorrhea Stratified by HIV Risk Category

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF2=Tenofovir Disoproxil Fumarate Study 2; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 23 is a forest plot of gonorrhea stratified by HIV risk category with two subgroups. The risk ratio for 3 studies in the heterosexual category is 1.20 (95% confidence interval 0.76 to 1.92) with an I-squared value of 69%. The risk ratio for 2 studies in the MSM category is 1.05 (95% confidence interval 0.85 to 1.30) with an I-squared value of 0%. The overall risk ratio for all studies is 1.10 (95% confidence interval 0.86 to 1.40) with an I-squared value of 43%.

Figure 24 Meta-Analysis: Chlamydia Stratified by HIV Risk Category

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Figure 24 is a forest plot of chlamydia stratified by HIV risk category with two subgroups. The risk ratio for 3 studies in the heterosexual category is 0.81 (95% confidence interval 0.47 to 1.41) with an I-squared value of 93%. The risk ratio for 2 studies in the MSM category is 1.09 (95% confidence interval 0.62 to 1.92) with an I-squared value of 50%. The overall risk ratio for all studies is 0.89 (95% confidence interval 0.58 to 1.36) with an I-squared value of 90%.

Figure 25 Meta-Analysis: Combined Bacterial STIs Stratified by HIV Risk Category

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; M-H=Mantel-Haenszel test; MSM=men who have sex with men; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; U.S.=United States.

Figure 25 is a forest plot of any STI stratified by HIV risk category with two subgroups. The risk ratio for 1 study in the heterosexual category is 1.05 (95% confidence interval 0.82 to 1.35). The risk ratio for 1 study in the MSM category is 1.20 (95% confidence interval 1.01 to 1.42). The overall risk ratio for all studies is 1.15 (95% confidence interval 1.00 to 1.32) with an I-squared value of 0%.

Based on three trials from the prior USPSTF report that could be pooled, there was no difference between PrEP versus placebo in risk of HSV infection (3 trials, N=4,088; RR, 0.85 [95% CI, 0.67 to 1.07]; I^2^=19%) (Figure 26).^120,150,170^ Two trials evaluated the risk of HSV infection based on serology in participants who were seronegative for HSV at baseline;^120,150^ the other trial did not report the method for diagnosing HSV infection.^170^ When stratified according to HIV risk category, PrEP was associated with decreased risk of HSV infection versus placebo in two trials of persons at risk via heterosexual contact (RR, 0.73 [95% CI, 0.56 to 0.96]; I^2^=0%)^51^ but not in one trial of MSM (RR, 1.12 [95% CI, 0.80 to 1.56])^150^ (Table 9). However, this analysis was based on few trials, and the test for a subgroup difference was not statistically significant (p=0.06). In the trial included in the prior USPSTF report of MSM, PrEP was not associated with decreased risk of a serological diagnosis of HSV infection, but was associated with lower risk of incident HSV infection with an ulcer (5.9% vs. 2.9%; p<0.05).^150^ One new publication of data from IPERGAY reported risk of HSV seroconversion among MSM who were seronegative at baseline, but did not provide data to calculate RR and could not be pooled with the prior trials.^132^ It found no association between on-demand PrEP versus placebo and risk of HSV-1 (n=108, HR 2.08, 95% CI 0.63 to 7.92) or HSV-2 (n=218, HR 1.16, 95% CI 0.43 to 3.33) seroconversion.

Figure 26 Meta-Analysis: Herpes Simplex Virus Infection Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FTC=emtricitabine; iPrEx=Pre-Exposure Prophylaxis Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; U.S.=United States

Figure 26 is a forest plot of herpes simplex virus infection stratified by study drug with two subgroups. The risk ratio for 1 study in the TDF subgroup is 0.76 (95% confidence interval 0.48 to 1.21). The risk ratio for 3 studies in the FTC-TDF subgroup is 0.86 (95% confidence interval 0.62 to 1.18) with an I-squared value of 40%. The overall risk ratio for all studies was 0.85 (95% confidence interval 0.67 to 1.07) with an I-squared value of 19%.

##### Hepatitis C Virus Infection

There was no difference between PrEP versus placebo or no PrEP in risk of hepatitis C virus infection, but only two trials (N=896) reported this outcome, and the estimate was imprecise (RR, 0.73 [95% CI, 0.25 to 2.10]; I^2^=0%)^66,118^ (Figure 27). Both trials (PROUD and IPERGAY) evaluated PrEP with TDF-FTC in MSM. There were 6 cases of hepatitis C virus infection in one trial^118^ and 8 cases in the other.^66^

Figure 27 Meta-Analysis: Hepatitis C Virus Infection

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; U.S.=United States.

Figure 27 is a forest plot of hepatitis C infection. The risk ratio for 2 studies is 0.73 (95% confidence interval 0.25 to 2.10) with an I-squared value of 0%.

##### Hepatitis B Virus Infection

One trial (VOICE) reported one case of incident hepatitis B virus infection among 1,009 patients randomized to placebo and no cases among 1,007 patients randomized to TDF.^54^ Incident hepatitis B virus infection was otherwise not reported. All trials except for two excluded patients with active hepatitis B virus infection. In one trial (Study of TDF), of 56 patients with active hepatitis B infection at baseline (based on hepatitis B surface antigen positive status), the risk of grade 1 asparate or alanine transaminase elevations (≤42 U/L) following discontinuation of study drug was 4.3% (1/23) for those randomized to TDF and 9.1% (3/33) for those randomized to placebo.^55^ In the other trial (iPrEx), no cases of hepatitis flare occurred following discontinuation of TDF-FTC in five patients with chronic hepatitis B virus infection.^169^

##### Pregnancy-Related Outcomes

No trial of PrEP enrolled pregnant persons, and persons who became pregnant during the course of the trial were withdrawn from participation. Three trials reported on pregnancy outcomes in persons who were withdrawn from PrEP because of pregnancy.^68,157,172^ In one trial, only one pregnancy occurred among persons randomized to PrEP;^68^ in the other two trials, 74 and 192 pregnancies occurred.^51,172^ All of the trials were conducted in Africa and evaluated women at increased risk of HIV infection via heterosexual activity. Among persons who became pregnant in the trials, PrEP was not associated with increased risk of spontaneous abortion (N=415, RR, 1.09 [95% CI, 0.79 to 1.50]; I^2^=0%) (Appendix B Tables 1–3; Figure 28). When stratified according to the PrEP regimen used, TDF was not associated with increased risk, but it was only evaluated in one trial (RR, 0.83 [95% CI, 0.50 to 1.37]).^157^ TDF-FTC was associated with a trend toward increased risk of spontaneous abortion that was not statistically significant (RR, 1.32 [95% CI, 0.86 to 2.01]; I^2^=0%).^68,157,172^ There was no statistically significant interaction between the PrEP regimen and risk of spontaneous abortion (p=0.17). The Partners PrEP trial found no differences between PrEP versus placebo in pregnancy rate, risk of preterm birth, birth anomalies, or postpartum infant mortality, and the FEM-PrEP trial found no difference in risk of any adverse pregnancy outcome (Appendix B Tables 1–3).^157^

Figure 28 Meta-Analysis: Spontaneous Abortion Stratified by Study Drug

*U.S, Canada, or Europe.

Abbreviations: CI=confidence interval; df=degrees of freedom; FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; IAVI=International AIDS Vaccine Initiative; M-H=Mantel-Haenszel test; PrEP=pre-exposure prophylaxis; TDF=tenofovir disoproxil fumarate; U.S.=United States.

Figure 28 is a forest plot of spontaneous abortion stratified by study drug with two subgroups. The risk ratio for 1 study in the TDF subgroup is 0.83 (95% confidence interval 0.50 to 1.37). The risk ratio for 3 studies in the FTC-TDF subgroup is 1.32 (95% confidence interval 0.86 to 2.01) with an I-squared value of 0%. The overall risk ratio for all studies was 1.09 (95% confidence interval 0.79 to 1.50) with an I-squared value of 0%.

#### Dapivirine Vaginal Ring vs. Placebo Ring

Two trials of the dapivirine vaginal ring versus placebo ring reported adverse events. Results for serious adverse events were very imprecise (2 trials, N=4,587; RR 1.73, 95% CI 0.60 to 4.94, I^2^=80%; Figure 29).^73,74^ In addition, marked statistical heterogeneity was present, with one trial finding no increase in risk of serious adverse events (4.0% vs. 3.6%, RR 1.09, 95% CI 0.74 to 1.60) and the other finding an increased risk (2.9% vs. 0.9%, RR 3.16, 95% CI 1.34 to 7.44). In the trial reporting increased risk, the most common serious adverse events were various infections (1.1%) and injuries (0.6%) that did not appear related to use of PrEP. One trial (n=1,959) found no differences between the dapivirine ring versus placebo in risk of any STI (RR 1.06, 95% CI 0.96 to 1.16).^74^ Pooled analyses of the two RCTs found no differences between the dapivirine vaginal ring versus placebo and risk of chlamydia (N=4,587; RR 0.98, 95% CI 0.89 to 1.07, I^2^=0%), gonorrhea (N=4,587; RR 1.01, 95% CI 0.80 to 1.27, I^2^=63%), or trichomoniasis infection (N=4,587; RR 1.06, 95% CI 0.92 to 1.23, I^2^=0%) (Figures 30–32).^73,74^ One trial reported no difference in risk of syphilis (1.3% vs. 0.8%).^74^ In both trials, pregnancy incidence was similar for the dapivirine ring and placebo (3.9 vs. 4.0 per 100 person-years and 1.6 vs. 2.0 per 100 person-years). Neither trial reported congenital abnormalities.

Figure 29 Dapivirine vs. Placebo: Serious Adverse Events

RD: 1.20% (95% CI, −0.59% to 2.99%)

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel-Haenszel; RD=risk difference.

Figure 29 is a forest plot of dapivirine on serious adverse events. The risk ratio for 2 studies is 1.73 (95% confidence interval 0.60 to 4.94) with an I-squared value of 80%.

Figure 30 Dapivirine vs. Placebo: Chlamydia

RD: −0.61% (95% CI, −3.30% to 2.09%)

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel-Haenszel; RD=risk difference.

Figure 30 is a forest plot of dapivirine on chlamydia. The risk ratio for 2 studies is 0.98 (95% confidence interval 0.89 to 1.07) with an I-squared value of 0%.

Figure 31 Dapivirine vs. Placebo: Gonorrhea

RD: 0.19% (95% CI, −3.50% to 3.87%)

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel-Haenszel; RD=risk difference.

Figure 31 is a forest plot of dapivirine on gonorrhea. The risk ratio for 2 studies is 1.01 (95% confidence interval 0.80 to 1.27) with an I-squared value of 63%.

Figure 32 Dapivirine vs. Placebo: Trichomoniasis

RD: 0.92% (95% CI, −1.19% to 3.03%)

Abbreviations: CI=confidence interval; df=degrees of freedom; MH=Mantel-Haenszel; RD=risk difference.

Figure 32 is a forest plot of dapivirine on trichomoniasis. The risk ratio for 2 studies is 1.06 (95% confidence interval 0.92 to 1.23) with an I-squared value of 0%.

#### Event-Driven vs. Daily Oral PrEP

One small, new, crossover trial (n=119) found event-driven oral PrEP associated with decreased risk of any adverse event versus daily oral PrEP (8% [10/119] vs. 31% [37/119], RR 0.27, 95% CI 0.14 to 0.52).^144^ All adverse events were grade 1 except for in one patient, who reported grade 2 symptoms. The most common adverse events were diarrhea, headache, lethargy, dizziness, dyspepsia, and nausea. There was no difference between regimens in change in creatinine clearance (data not provided). Due to the crossover design of the trial, it was not able to compare effects of event-driven versus daily oral PrEP on risk of STIs.

## Key Question 5 What Are the Harms of Newer PrEP Regimens (Oral TAF-FTC, Injectable Cabotegravir, or the Dapivirine Vaginal Ring) vs. TDF-FTC?

### Summary

#### Daily Oral TAF-FTC vs. TDF-FTC

Based on one trial (n=5,387)^162^:

- No differences between TAF-FTC versus TDF-FTC in risk of serious adverse events (7% vs. 7%), discontinuation due to adverse events (1% vs. 2%), or any adverse event (94% vs. 94%).
- No differences between TAF-FTC versus TDF-FTC in rates of any renal adverse event (10% vs. 10%) or renal adverse events leading to discontinuation (0.07% vs. 0.2%).
- No difference between TAF-FTC versus TDF-FTC in the risk of fracture (2% vs. 2%); however, among persons 25 years of age or older, TAF-FTC was associated with greater percent change from baseline than TDF-FTC in hip bone mineral density (+0.6% vs. −1.0%, p<0.001) and spine bone mineral density (+0.9% vs. −1.4%, p<0.001).
- TAF-FTC was associated with smaller reduction from baseline versus TDF-FTC in low density lipoprotein cholesterol (median −0.05 vs. −0.18 mmol/L, p<0.0001) and greater weight gain (median +1.7 vs. +0.5 kg, p<0.0001).

#### Long-Acting Injectable Cabotegravir vs. Daily Oral TDF-FTC

Based on two trials (N=7,786)^70,88^:

- No differences between long-acting injectable cabotegravir versus daily oral TDF-FTC in risk of serious adverse events (5.3% vs. 5.3% and 2.0% vs. 2.0%) or grade 3 or higher adverse events (31.9% vs. 33.6% and 17.1% vs. 17.4).
- No differences between cabotegravir versus TDF-FTC in risk of grade 2 or 3 renal (decreased creatinine clearance) or liver (increased alanine or aspartate transaminase) events, risk of discontinuation due to liver-related adverse events, or risk of STIs.
- Cabotegravir was associated with increased weight gain versus TDF-FTC (mean differences 0.86 and 0.4 kg).
- Cabotegravir was associated with increased risk of injection site reactions (most commonly, pain) versus TDF-FTC (81.4% vs. 31.3% and 38.0% vs. 10.8%) that were usually mild and diminishing following the initial injection.
- In one trial that enrolled women, pregnancy incidence was low with cabotegravir and TDF-FTC (1.5 [95% CI, 1.0 to 2.2] vs. 1.0 [95% CI, 0.6 to 1.6] per person-years), with no congenital abnormalities observed.^88^

### Evidence

#### Daily Oral TAF-FTC vs. TDF-FTC

The DISCOVER trial (n=5,387)^121^ found no difference between TAF-FTC versus TDF-FTC in risk of serious adverse events (7.5% vs. 6.9%) or discontinuation of study drug due to adverse events, which was uncommon (1.5% vs. 1.9%).^162^ The types of serious adverse events varied and most did not appear related to PrEP (e.g., appendicitis, suicidal ideation or attempt, hepatitis A, pneumonia, depression, cellulitis, acute kidney injury, or atrial fibrillation). Rates of any adverse event (94% vs. 94%) were very similar; the most common non-STI adverse event was diarrhea (18% vs. 17%). There were also no differences in rates of sexually transmitted infections (rectal or urethral chlamydia, rectal or urethral gonorrhea, or syphilis) (Appendix B Tables 1–3).

There were also no differences between TAF-FTC versus TDF-FTC in rates of any renal adverse event (10% vs. 10%) or renal adverse events leading to discontinuation (0.07% vs. 0.2%). Regarding bone adverse events, there was no difference in the risk of fracture (2.2% vs. 2.2%) or nontraumatic fracture (1 vs. 2 cases; <1% in each arm). However, among persons 25 years of age or older, TAF-FTC was associated with greater percent change from baseline than TDF-FTC in hip bone mineral density (+0.6% vs. −1.0%, p<0.001) and spine bone mineral density (+0.9% vs. −1.4%, p<0.001).

TAF-FTC was associated with smaller reduction from baseline versus TDF-FTC in low density lipoprotein cholesterol (median −0.05 vs. −0.18 mmol/L, p<0.0001) and greater weight gain from baseline versus TDF-FTC (median +1.7 vs. +0.5 kg, p<0.0001).

#### Long-Acting Injectable Cabotegravir vs. Daily Oral TDF-FTC

In HPTN 083 and 084 (N=7,786), there were no differences between long-acting injectable cabotegravir versus daily oral TDF-FTC in risk of serious adverse events (5.3% [120/2280] vs. 5.3% [121/2282] and 2.0% [33/1614] vs. 2.0% [33/1610]) or grade 3 or higher adverse events (31.9% [727/2280] vs. 33.6% [767/2282] and 17.1% (276/1614) vs. 17.4% [280/1610]) (Appendix B Tables 1–3).^70,88^ There were also no differences in risk of grade 2 or 3 renal (decreased creatinine clearance) or liver (increased alanine or aspartate transaminase) events, risk of discontinuation due to liver-related adverse events, or risk of incident rectal or urethral gonorrhea, rectal or urethral chlamydia, or syphilis infections. In both trials, cabotegravir was associated with increased weight gain versus TDF-FTC, which occurred early during treatment (mean differences 0.86 and 0.4 kg). Injection site reactions (most commonly, pain) were more frequent with cabotegravir than TDF-FTC (81.4% vs. 31.3% and 38.0% vs. 10.8%). Injection site reactions were usually mild and occurred most commonly with the first injection, with diminishing frequency over time. In one trial that enrolled women (HPTN 084), pregnancy incidence was similar and low with cabotegravir and TDF-FTC (1.5 [95% CI 1.0 to 2.2] vs. 1.0 [95% CI 0.6 to 1.6] per 100 person-years), with no congenital abnormalities observed.^88^

## Contextual Questions

### Contextual Question 1. What Are Rates of Adherence to and Persistence of PrEP and Factors Associated With Increased or Decreased Adherence in U.S. Primary Care Settings?

Adherence, or medication compliance, refers to the degree to which patients take medications as directed (e.g., every day for oral daily PrEP). The prior USPSTF report^2^ found a strong association between increased adherence and greater PrEP effectiveness. In six placebo-controlled trials in which adherence was 70 percent or greater, the pooled RR of PrEP for preventing HIV infection was 0.27 (95% CI, 0.19 to 0.39; I^2^=0%).^51,52,66,67,118,170^ Additional subgroup and modeling analyses also support the association between increased adherence and greater PrEP effectiveness. One analysis based on trial data estimated a 96 percent reduction in HIV infection risk among MSM taking at least four oral PrEP doses a week,^178^ suggesting important benefits even when adherence is incomplete.

Methods for measuring adherence include drug levels (plasma, dried blood spot levels, or urine), self-report, pill count, and others. Some studies have shown lower levels of adherence based on drug levels than by self-report or pill counts,^54,128,141,179,180^ although other evidence indicates more concordance.^118^ Some discrepancies between drug levels and self-reported adherence or pill counts could be related to use of financial incentives or other benefits for trial participation (patients in such a trial might have concerns about trial dismissal and loss of financial compensation or access to care as a result of low adherence) or social desirability bias (patients might overreport adherence to avoid disappointing study personnel with whom they have developed relationships).^181^ Dried blood spot samples measuring intracellular drug concentrations of TFV-DP (the active moiety of tenofovir) reflect longer-term cumulative drug exposure compared with tenofovir plasma levels, correlating with the number of doses taken in the last several weeks (plasma levels indicate dosing within the last week).

Persistence refers to continuation of treatment for the prescribed length of time.^182^ Persistence and adherence are distinct concepts; among patients with PrEP persistence, adherence may be incomplete or fluctuate. Persistence is a necessary condition for PrEP effectiveness, though patients may re-start PrEP following periods of non-persistence. Definitions and methods for measuring persistence vary and include temporary or permanent discontinuation of PrEP, lapses in prescription coverage that exceed specified thresholds, or non-retention in PrEP care.

In the United States, evidence on adherence is primarily available for daily oral PrEP in populations of MSM (Appendix D Table 1). In five observational studies of primarily MSM, adherence rates ranged from 22 to more than 90 percent, based on TFV-DP dried blood spot levels of 700 fmol/punch or greater (consistent with an average of ≥4 pills/week over the last 1 to 2 months).^177,183–186^ One study (n=557) found that the proportion of patients meeting the adherence threshold ranged from 80 to 86 percent from week 4 to 48 (proportion meeting the adherence threshold on all samples, 62 percent),^177^ and another study (n=301) found that adherence was 83 percent at week 4 and 66 percent at week 48.^186^ A smaller study (n=50) found that 90 percent (19/21) of patients met the adherence threshold at a mean PrEP duration of 4.4 months.^185^ Two other studies (n=200 and 72) using dried blood spot samples reported lower adherence rates.^183,184^ Both focused on younger MSM (mean ages 20 and 16 years) than the studies described above (mean age >30 years). The proportion of patients meeting the 4 or more doses/week threshold was approximately 50 percent at week 12, decreasing to 34 and 22 percent at week 48. The proportion of patients with dried blood spot levels of 350 fmol/punch or greater (consistent with ≥2 doses/week) was 72 and 59 percent at week 12, decreasing to 49 and 26 percent at week 48.

Several U.S. studies reported adherence in MSM using methods other than dried blood spot samples. Two studies described above found adherence rates based on self-report were similar to rates based on dried blood spot testing.^177,185^ Another observational study (n=267)^187^ found that 92 percent of patients reported taking four or more pills in the last week at 3 and 6 months. An RCT of a group-based behavioral HIV prevention intervention in young MSM (n=20 randomized to PrEP) found tenofovir detected in 63 percent of plasma samples among those randomized to PrEP at week 4, decreased to 20 percent at week 24.^141^ Another RCT of MSM (n=373) utilized medication event monitoring system data.^52^ Adherence was 79 percent based on doses taken and 93 percent based on pill count.

An RCT (n=179) of MSM (97%) and transgender women (2%) enrolled at a U.S. site compared adherence with daily, intermittent, and event-driven oral PrEP, based on TFV-DP dried blood spot levels of 326 fmol/punch or greater (consistent with ≥2 doses/week; 2 doses per week associated with an estimated reduction in risk of HIV acquisition of 76%^178^).^136^ During weeks in which sex was reported, adherence was higher for daily (49%) than intermittent (31%) or event-driven (17%) PrEP. Adherence was also higher for daily PrEP than intermittent or event-driven PrEP based on event monitoring system data (65% vs. 46% vs. 41% of tablets used/recommended, respectively).

Among U.S. MSM, evidence on factors associated with higher or lower adherence suggests differences in adherence based on race/ethnicity, socioeconomic status or other social determinants, and presence of higher-risk behaviors. One study (n=557; mean age 34 to 35 years) of MSM (98%) and transgender women (1.4%) found Black race associated with lower adherence compared with White race (adjusted OR, 0.28 [95% CI, 0.12 to 0.64]).^177^ Latino, Asian, and “other” race/ethnicity were also associated with decreased likelihood of adherence, but estimates were imprecise and differences were not statistically significant. The study also found having stable housing (renting or owning) associated with higher adherence versus less stable housing (living with friends or family, public housing, or homeless) (adjusted odds ratio [OR], 2.02 [95% CI, 1.14 to 3.55]) and having condomless receptive anal sex with two or more partners (vs. 0 or 1 partner) in the past 3 months associated with higher adherence (adjusted OR, 1.82 [95% CI, 1.14 to 2.89]). There were no clear associations between age, educational level, PrEP awareness, income level, health insurance status, depression, and alcohol or drug use and adherence to PrEP. A study of younger (ages 18 to 22 years) MSM (n=200) found that those who reported engaging in recent sex without condoms had higher TFV-DP levels than those who did not report this behavior (p=0.01).^184^ There was a similar but statistically nonsignificant trend toward higher TFV-DP levels among participants who reported condomless receptive anal sex with their last sexual partner. Patients who did not like taking pills were more likely to be nonadherent (p=0.02). Evidence on differences in adherence among MSM by mode of PrEP administration is addressed in Contextual Question 2.

Evidence on adherence with PrEP in U.S. populations other than MSM is limited. A large observational study (n=1,086, indication for PrEP not reported), which assessed adherence based on prescription refill data, found the median proportion of days covered in the first year was 0.74 (interquartile range, 0.40 to 0.92).^188^ In this study, older age (ages 50 to 64 vs. <35 years; adjusted OR, 2.00 [95% CI, 1.37 to 2.92]), being men (vs. women; adjusted OR, 3.39 [95% CI, 1.37 to 8.42]) and White race (vs. Black race; adjusted OR, 2.02 [95% CI, 1.43 to 2.87]) were associated with increased adherence.^188^ Other factors, including comorbid substance use disorder or depression, low socioeconomic status, rural living, and region of the United States, were not significantly associated with adherence. A small (n=29) study evaluated PrEP adherence among people (72% men, 93% heterosexual) with opioid use disorder and receiving HCV treatment. It found that the proportion of patients with dried blood spot levels consistent with ≥4 doses/week was 68% at week 24, declining to 25% at week 36. Estimates based on dried blood spot levels were substantially lower than adherence based on self-report, which was 71% at 12 weeks and 88% at 48 weeks.

Evidence on PrEP persistence in U.S. populations indicates that discontinuations are frequent (Appendix D Table 1). However, interpretation is complicated by differences in the methods used to measure persistence and the populations assessed. A large (n=13,906; 95% men) observational study of persons in an integrated health system found that among those who initiated PrEP, 52.5% (95% CI 48.9% to 55.7%) discontinued PrEP at least once, defined as >120 days without PrEP based on pharmacy refill data.^107^ At 2 years, the proportion who had discontinued PrEP was 38.4% (95% CI 37.2% to 39.6%). Among those who discontinued at least once, the proportion who reinitiated PrEP was 60.2% (95% CI 52.2 to 68.3%). The highest rates of discontinuation occurred in the first two years after initiating PrEP. In unadjusted analyses, factors associated with increased likelihood of discontinuation were younger age (<45 years, HR 2.17, 95% CI 1.92 to 2.38), Black race (vs. White race, HR 1.36, 95% CI 1.17 to 1.57), Latino ethnicity (vs. White non-Latino, HR 1.33, 95% CI 1.22 to 1.46), being a woman (HR 1.99, 95% CI 1.67 to 2.38), greater neighborhood deprivation (vs. highest quintile, HR 1.40, 95% CI 1.26 to 1.57 for lowest quintile), and having a substance use disorder (HR 1.23, 95% CI 1.09 to 1.39). Another large study (n=7,148; 97% men) of PrEP users in a national pharmacy database found rates of persistence (defined as at least 16 days of PrEP filled per 30-day period for at least three-quarters of a 12 or 24 month period) were 56 percent in year 1 and 41 percent in year 2.^189^ Factors associated with increased likelihood of persistence were older age (for 50+ years vs. 18 to 24 years, adjusted OR 2.77, 95% CI 2.25 to 3.41), being a man (adjusted OR 2.46, 95% CI 1.77 to 3.41), having commercial insurance (vs. government, adjusted OR 1.96, 95% CI 1.69 to 2.27; vs. cash/other, adjusted OR 1.69, 95% CI 1.33 to 2.13), and having a lower copay (≤$20 vs. >$20, adjusted OR 1.64, 95% CI 1.45 to 1.85). Another large study (n=11,807; 98% men) reported persistence (defined as no gap in refills >30 days) of 54.0 percent in a commercially insured cohort and 29.9 percent in a Medicaid-insured cohort.^190^ As in the prior two studies, being a man and older age were associated with increased likelihood of persistence; among Medicaid-insured patients, Black race was associated with decreased likelihood of persistence versus White race (4.7% vs. 7.3%, p=0.003). A study of Veterans Affairs patients (n=1,086; 96% men) found that 44 percent discontinued PrEP in the first year (defined as a >120 day gap).^188^

Discontinuation was more common among younger persons (<35 vs. 50-64 years, 51.5% vs. 39.2%, p=0.008), Black compared with White persons (52.4% vs. 41.6%, p=0.05), and women versus men (80.0% vs. 42.8%, p<0.001). The above studies were based on analyses of administrative or pharmacy databases; information regarding indication for PrEP was not available. A smaller study (n=271, 86% men, 81% MSM) of persons using PrEP in two health centers found that 47.2 percent discontinued PrEP (defined as missing more than 2 quarterly visits with no additional visits by the end of follow-up) and 11.4 percent had intermittent care (missing at least 2 quarterly visits but then reinitiating care).^191^ Factors associated with decreased risk of discontinuation included older age (adjusted OR 0.97, 95% CI 0.94 to 1.00) and being an MSM (vs. non-MSM, adjusted OR 0.26, 95% CI 0.10 to 0.64); estimates for race/ethnicity and having a partner with HIV were imprecise.

In six U.S. studies (n=50 to 693) of primarily or exclusively MSM, discontinuation rates (variably defined) ranged from 15% to 69% (Appendix D Table 1).^177,185,187,192–194^ In the largest (n=663) study, factors associated with decreased time to discontinuation were younger age (vs. 30 to 39 years, adjusted HR for 18 to 24 years 2.0, 95% CI 1.4 to 2.9; adjusted HR for 25 to 29 years 2.2, 95% CI 1.6 to 3.1), being a transgender woman (vs. cisgender man, adjusted HR 2.0, 95% CI 1.2 to 3.4), and having more mental health disorders (per additional disorder, adjusted HR 1.2, 95% CI 1.1 to 1.4). Another study (n=267) found no clear association between age, race/ethnicity, educational level, being a man who has sex with men, income, or insurance status and likelihood of retention in care, though some estimates were imprecise.^187^

Evidence on rates of and factors associated with PrEP persistence in populations other than MSM was very limited. A study (n=51) of transgender men (80%) or women (20%) found that among those who ever received PrEP, 49 percent (25/51) had discontinued.^195^ A small (n=21) study of heterosexual women initiated on PrEP found that 61 percent (13/21) were retained in care (defined as a clinic visit within 1 month) at 3 months and 37.5 percent (8/21) were retained at 6 months.^196^ A small study (n=29) of people using PrEP with opioid use disorder receiving HCV treatment found that retention decreased from 86.2 percent (25/29) at week 4 to 31.0 percent (9/29) at week 36.

### Contextual Question 2. How Does Adherence to and Persistence of PrEP Vary According to Mode of Administration (e.g., Oral, Injectable, or Vaginal Ring)?

Two head-to-head trials compared injectable cabotegravir versus daily oral TDF-FTC.^70,88^ The method used to assess adherence differed for the two modalities. For cabotegravir, adherence was based on “coverage,” defined as no delay of longer than two weeks between scheduled injections. For TDF-FTC, adherence was measured using dried blood spot levels consistent with ≥4 doses/week. In HPTN 083 (n=4,570; U.S. 37%), which enrolled 87 percent MSM and 12 percent transgender women, coverage with injectable cabotegravir was 91.5 percent of person-years, compared with adherence with oral TDF-FTC of 72.3 percent based on dried blood spot samples.^70^ In HPTN 084 (n=3,898), which was conducted in women in Africa, coverage with injectable cabotegravir was 93.0 percent of person-years, compared with adherence with oral TDF-FTC of 42 percent based on dried blood spot samples.^88^ In both trials, discontinuation rates with cabotegravir and TDF-FTC were similar (19.5% vs. 20.3% in HPTN 083 and 5.3% vs. 6.8% in HPTN 084). Because participants in these trials were blinded to receipt of cabotegravir or TDF-FTC (via a placebo injection or tablet), generalizability to clinical practice is uncertain.

Evidence comparing adherence and persistence using the dapivirine ring versus oral PrEP is very limited. Published trials of the dapivirine ring used a placebo comparator. Interim results from one crossover trial, which compared the dapivirine ring versus daily oral PrEP in young (16 to 21 years) women in Africa, have been reported as a conference abstract.^197^ “High” adherence (defined as dapivirine levels indicating release of 3.0 mg/28 d) was observed in 50.2 percent (687/1368 timepoints) of ring users (based on residual drug levels) and 22.4 percent (294/1310 timepoint) of oral PrEP users (based on dried blood spot levels).

### Contextual Question 3. What Is the Risk of Infection With Antiretroviral Drug–Resistant HIV in Persons Using PrEP, and What Is the Effect of Infection With PrEP-Related, Antiretroviral Drug–Resistant HIV on Treatment Outcomes?

Ten placebo-controlled RCTs, all included in the prior USPSTF review, reported rates of antiretroviral drug resistance in persons randomized to oral PrEP with TDF or TDF-FTC (N=8,661) (Appendix D Table 2).^51–55,66,118,137,170,172^ One trial evaluated event-driven PrEP^66^ and the other nine trials evaluated daily PrEP. Five trials evaluated PrEP with TDF alone^51–55^ and seven trials evaluated TDF-FTC;^51,66,137,172^ two trials^51,54^ evaluated both regimens. The most commonly reported mutations were the tenofovir resistance mutations K65R and K70E and the emtricitabine mutations M184I and M184V (both tenofovir and emtricitabine are nucleoside reverse transcriptase inhibitors).

Resistance rates were low with oral PrEP. Among all patients randomized to PrEP, 0.06 percent (2/3,149) of patients on TDF (4 trials)^51–54^ and 0.3 percent (14/5,085) of patients on TDF-FTC (7 trials)^51,54,66,118,137,170,172^ were identified as having incident HIV infection with a drug resistance mutation. Among patients with incident HIV infection, 1.1 percent (3/282) had a tenofovir resistance mutation.^51,53–55,66,118,137,170,172^ Seven of the trials reported no cases of tenofovir resistance mutations (N=198),^53,54,66,118,137,172^ and two trials reported one or two cases (n=10^170^ and n=35^51^). All three cases were attributed to undiagnosed baseline HIV infection and involved M184V and K65R mutations (including one case of multiple resistance mutations to K65R, M184V, and A62V).^51,170^ No other case of multidrug resistance was identified in patients randomized to PrEP.

In six trials of PrEP with TDF-FTC, 8 percent (14/174) of patients diagnosed with HIV infection after initiating PrEP were diagnosed with emtricitabine resistance mutations (M184I or M184V).^51,54,66,118,137,170,172^ The number of cases of emtricitabine resistance in each trial ranged from 0 to 4. Nine of the 14 cases of emtricitabine resistance occurred in persons who were infected with HIV upon trial enrollment, including 1 case of multiple resistance mutations described above.

Data on drug resistance mutations in patients using oral PrEP were also available from the iPrEX-OLE observational study,^198^ which enrolled patients (n=1,225) from the United States, South Africa, South America, and Thailand, and four U.S.-based observational studies (total N=696) (Appendix D Table 2).^177,183–185^ All of these studies evaluated PrEP with daily TDF-FTC. Among a total of 1,936 patients receiving PrEP across the observational studies, two were diagnosed with an antiretroviral drug resistance mutation (0.1%). In iPrEx-OLE, one of 28 patients (3.6%) diagnosed with HIV infection had the M184V mutation.^198^ Among the four U.S.-based studies, one of 10 patients diagnosed with HIV infection while on PrEP was found to have M184V and multiple thymidine analog mutations.^185^

Data to compare risk of antiretroviral resistance associated with different oral PrEP regimens are limited. For event-driven PrEP, one placebo-controlled trial (n=400) reported two cases of HIV infection among patients randomized to PrEP, with no resistance mutations identified;^66^ a head-to-head trial (n=119) of daily versus event-driven PrEP was not designed to evaluate HIV incidence or antiretroviral resistance.^144^ The DISCOVER Trial (n=5,387) compared oral TAF-FTC versus TDF-FTC.^121,162^ Among 20 patients who were infected with HIV infection and had resistance testing results, an M184V or M184I resistance mutation was detected in four patients. All of the infections occurred in patients randomized to TDF-FTC who were suspected of having an infection at baseline.

Two placebo-controlled trials (ASPIRE and the Ring Study) not included in the prior USPSTF report provided data on resistance mutations with the dapivirine vaginal ring.^73,74^ Dapivirine is a nonnucleoside reverse transcriptase inhibitor (NNRTI). Across both trials, the proportion of patients randomized to dapivirine with an NNRTI resistance mutation was 0.8 percent (22/2,620). In ASPIRE, the rate of NNRTI resistance mutations among patients with incident HIV infection was similar in patients randomized to the dapivirine ring versus those randomized to placebo (11.8% [8/68] vs. 10.4% [10/96], p=0.80).^73^ Among dapivirine ring patients, there were two cases of the K103N mutation, two cases of the V90I mutation, three cases of the E138A mutation, and one case each of the K101E, K103S, V106M, V108I, E138G, V179D, and H221Y mutations. In the Ring Study, the rate of NNRTI resistance mutations was also similar between the dapivirine ring and placebo arms (18.2% [14/77] vs. 16.1% [9/56], p=0.75). Dapivirine was associated with a nonstatistically significant increased risk of E138A resistance mutations versus placebo (11.7% [9/77] vs. 1.8% [1/56], p=0.07); other specific NNRTI resistance mutations (A98G, K103N, K101E, V106M, V090I, V108I, E138Q, Y181C, Y188C, H221Y) were less common (occurring in 1 to 5 patients across both arms).^74^ In open label extensions of these trials (N=2,397), NNRTI resistance mutations (K103N, E138A, A98G, V179D, V106M, K101E) occurred in 20% (7/35) and 29% (5/17) of patients with incident HIV infection.^111,112^

Two new trials (HTPN 083 and 084) provided data on resistance mutations among persons randomized to injectable cabotegravir versus daily oral TDF-FTC.^70,88^ Cabotegravir is an integrase strand transfer inhibitor (INSTI). Across both trials, among all patients randomized to cabotegravir, the proportion with an INSTI resistance mutation was 0.1 percent (4/3874). In HPTN 083, INSTI resistance mutations were observed in 4 of 9 (44.4%) incident HIV cases in whom resistance testing was available (resistance testing unavailable for 4 incident HIV infections); one such mutation was identified in a patient with baseline infection.^70^ In HPTN 084, there were no cases of INSTI resistance mutations in four individuals with incident HIV infections.^88^ Neither trial reported any cases of INSTI resistance mutation acquired following cessation of cabotegravir, during the pharmacological tail period. Among individuals randomized to TDF-FTC across both trials, the proportion with antiretroviral resistance mutations was 0.1 percent (5/3870). In HPTN 083, among individuals randomized to TDF-FTC, nucleoside reverse transcriptase inhibitor resistance mutations (K65R, M184V and M184I) with or without a nonnucleoside reverse transcriptase inhibitor mutation were identified in four of 39 (10.3%) incident cases.^70^ In HPTN 084, one of 36 (2.8%) patients randomized to TDF-FTC with incident infection had an M184V (nucleoside reverse transcriptase inhibitor) resistance mutation and “several” participants (specific data not provided) had a nonnucleoside reverse transcriptase inhibitor resistance mutation (primarily K103N).^88^

Evidence on effects of acquiring antiretroviral resistant HIV infection while receiving PrEP on clinical outcomes is very limited but suggests that virological suppression with antiretroviral therapy remains achievable. One study reported that among five patients previously exposed to PrEP and diagnosed with HIV infection with an M184V or M184I mutation, four had an undetectable viral load 3 months after starting antiretroviral therapy, with one patient lost to followup.^199^ All patients received TDF and FTC with either darunavir and cobicistat or dolutegravir. Another study found that among patients diagnosed with HIV infection, 52 reported recent PrEP exposure.^200^ Of these, 30 percent (13/52) had an M184V or M184I infection, 3.8 percent (2/52) had another nucleoside reverse transcriptase inhibitor resistance mutation (L74V or M41L and/or L210W and/or T215Y/F), and 9.6 percent (5/52) had a nonnucleoside reverse transcriptase inhibitor resistance mutation (3 K103N/S, 1 V108V/I, and 1 G190A/S/E); there were no protease inhibitor resistance mutations. All 39 individuals with a viral load >200 copies/mL at baseline who received antiretroviral therapy achieved an undetectable viral load at 24 weeks. All patients were started on tenofovir-based antiretroviral therapy, with the third agent boosted darunavir, bictegravir, dolutegravir, or raltegravir; 43 percent of patients were switched off boosted darunavir to an integrase inhibitor combination within 3 months from antiretroviral therapy initiation based on clinic protocol. Results were not reported separately for patients with antiretroviral resistance mutations. No study was designed to evaluate effects of infection with antiretroviral resistant HIV infection while on PrEP on long-term clinical outcomes. When PrEP-selected mutations occur, some data indicates the mutations will become undetectable in the absence of antiretroviral therapy but “archived” mutations (those that reemerge following exposure to antiretroviral therapy) are possible.^201^

### Contextual Question 4. What Factors (e.g., Race and Ethnicity, Age, Sex, Gender, Sexual Orientation, HIV Risk Category, Socioeconomic Status, Cultural Factors, Educational Attainment, or Health Literacy) Are Associated With Disparities in Utilization of PrEP?

National CDC surveillance data indicate that in 2019 (the last year with reliable data); PrEP coverage (the proportion of persons with PrEP indications who were prescribed PrEP) was higher among men (25.5%) than women (9.3%); higher among White persons (60.5%) than Black (7.9%) or Hispanic/Latinx (13.8%) persons; and lower among persons 16 to 24 years of age (15.0%) compared with adults ≥25 years of age (19.6% to 26.6%).^103^ The surveillance data did not report utilization by HIV risk category and did not control for other factors that could impact utilization. Additional data on disparities in utilization of PrEP in the United States were available from a recent (searches through 2019) meta-analysis of 95 surveys^93^ (N=95,854), six large recent additional studies (three nationwide surveys [n=4,475,^202^ n=10,504,^203^ n= 4,056^204^], and three retrospective cohorts [n=13,906,^107^ n=23,312,^205^ n=25,886_206_]. Two smaller studies focused on specific factors associated with PrEP utilization in MSM^207,208^ and one study focused on the association between insurance status and PrEP utilization.^104^ Evidence primarily focused on disparities in utilization among MSM; data on HIV risk categories other than MSM were limited. Although evidence indicates disparities in PrEP utilization related to age, sexual orientation, socioeconomic status, and educational attainment, evidence on disparities related to race and ethnicity were somewhat inconsistent. Data on disparities related to gender were limited, and data on disparities related to health literacy were lacking. A challenge in interpreting data on PrEP utilization is the intersectionality between multiple factors potentially associated with disparities.

The meta-analysis included 95 surveys of self-reported PrEP use in U.S. populations at higher risk for HIV infection; 46 surveys collected data from 2015-2017, subsequent to the publication of the Centers for Disease Control and Prevention guideline on PrEP. In 2015-2017, the overall proportion of respondents reporting PrEP use was 11.3%, whereas from 2004-2014, the proportion of respondents with PrEP use ranged from 0.3% to 3.2%. Eighty studies reported PrEP use in MSM, 26 studies in Black persons, 19 in Hispanic/Latinx persons, and 19 studies in youth. Few studies reported PrEP use in PWID (k=6), transgender women (k=9) and cisgender or unspecified women (k=4). From 2015-2017, MSM were more likely to report PrEP use (pooled prevalence [PP] 13.9%, 95% CI 8.8 to21.1) than non-MSM (PP 5.3%, 95% CI 3.7 to 7.5) and other groups at high risk for HIV acquisition, including PWID (PP 3.7%, 95% CI 0.8 to 16.1) and transgender women (PP 11.2%, 95% CI 5.8 to 20.6). Youth, even when including MSM, reported relatively low PrEP use (PP 7.3%, 95% CI 4.7 to 11.2). Hispanic/Latinx (PP 11.5%, 95% CI 7.1 to 18.1) and Black persons (PP 9.9%, 95% CI 8.3 to 11.8) reported PrEP use at rates similar to the overall proportion. The meta-analysis was not limited to surveys of individuals at high HIV acquisition risk; although surveys generally focused on populations frequently at risk for HIV acquisition (e.g., MSM, PWID, or persons attending STI clinics or in other higher-risk settings), they did not necessarily exclude individual respondents within those populations at lower risk. The meta-analysis had other limitations including reliance on self-report data, potential overlap among surveyed populations, high statistical heterogeneity among included studies (even when restricting analysis to only include recent surveys), and inclusion of some studies (k=19) assessed as having high risk for bias.

Eight additional studies published after the systematic review also reported disparities in PrEP utilization in different U.S. populations. Five studies reported factors associated with PrEP utilization in MSM; each accounted for confounders such as demographic factors, geographic location, HIV risk factors, income, and education. A survey of 4,475 MSM (891 considered PrEP-eligible), found no difference in utilization by race/ethnicity (Black versus White adjusted prevalence ratio [aPR] 1.09, 95% CI 0.88 to 1.37; Hispanic versus White aPR 0.91, 95% CI 0.76 to 1.09) but did find differences in utilization based on age <25 years versus ≥25 years (aPR 0.44, 95% CI 0.35 to 0.55), rural versus urban MSM (aPR 0.45, 95% CI 0.33 to 0.62) and insured versus uninsured MSM (aPR 2.98, 95% CI 1.93 to 4.59).^202^ Another survey of 10,504 people at high risk of HIV acquisition (predominantly MSM) compared current PrEP users and PrEP-naïve individuals.^203^ It found no differences in PrEP utilization by race/ethnicity (vs. White persons, adjusted odds ratio [aOR] for Black race 0.92, 95% CI 0.71 to 1.18; for Latino ethnicity aOR 0.95, 95% CI 0.83 to 1.09; for Asian race aOR 0.90, 95% CI 0.77 to 1.05) and no difference in utilization between MSM and transgender women (aOR= 1.27, 95% CI 0.41 to3.88). However, increasing age (aOR 1.2, 95% CI 1.16 to 1.24) and higher education (aOR 1.91, 95% CI 1.65 to 2.20) were associated with increased likelihood of PrEP use while bisexual orientation (aOR 0.67, 95% CI to 0.62 to 0.72), low income (aOR 0.47, 95% CI 0.37 to 0.59), housing instability (aOR 0.79, 95% CI 0.65 to 0.96) and residence in a state without Medicaid expansion (aOR 0.62, 95% CI 0.5 to 0.76) were associated with decreased likelihood of PrEP. utilization. A survey of 4,056 MSM with likely PrEP indications found that White MSM were more likely than Latino or Black MSM to use PrEP (White versus Hispanic aPR 1.2, 95% CI 1.1 to 1.3; White versus Black aPR 1.4, 95% CI 1.2 to 1.6).^204^ One study (n=368) found MSM at increased risk for HIV acquisition with an HIV-positive main partner were more likely to use PrEP than those without an HIV-positive main partner (OR =3.12; 95% CI=1.05-9.31)^207^ and one study (n=863) found certain forms of intimate partner violence associated with decreased PrEP use.^208^

Two large, recent retrospective studies described PrEP use in general U.S. populations eligible for PrEP. In a retrospective review of 13,906 individuals referred to PrEP or with a PrEP-coded encounter within a single healthcare system, Black and Latino patients were slightly less likely than Asian patients to initiate PrEP compared to White patients (vs. White patients, HR for Black patients 0.87, 95% CI 0.80 to 0.95; for Latinx patients HR 0.90, 95% CI 0.86 to 0.95; and for Asian patients HR 1.06, 95% CI 1.00 to1.12).^107^ Some disparities in utilization were also identified for younger (age ≤45) versus older persons (HR 1.09, 95% CI 1.02 to 1.1), women versus men (HR 0.71, 95% CI 0.64 to 0.80), people with a substance use disorder versus no substance use disorder (HR 0.88, 95% CI 0.81 to 0.95.), people of lower versus higher socioeconomic status (HR 0.93, 95% CI 0.87 to 0.99) and people with public versus private insurance (HR 0.96, 95% CI 0.86 to1.07). A retrospective review of 23,312 patients within the Veteran Health Administration (8,001 patients with indication for PrEP based on diagnosis of gonorrhea or early syphilis) also found some disparities in PrEP initiation by race (White vs. Black, OR 1.7, 95% CI 1.0 to2.7) and age (<35 years vs. 35-49 years, OR1.3, 95% CI 0.8 to2.0), though estimates were imprecise and not statistically significant. In this study, men were more likely to initiate PrEP than women (OR 6.2, 95% CI 2.5 to15.2) and urban residence was associated with increased likelihood of PrEP initiation than rural residence (OR 5.0, 95% CI 1.8 to 13.5).^205^ A retrospective review of 25,886 people (8,063 with a PrEP indication) found no difference in likelihood of PrEP prescriptions between Black versus White patients (aPR 0.92, 95% CI 0.84 to 1.00) or Hispanic versus White patients (aPR 1.10, 95% CI 0.97 to 1.23).^206^ Among PWID, non-MSM were less likely to be prescribed PrEP than MSM (aPR 0.72, 95% CI 0.56 to 0.91). A systematic review of 10 studies published between 2013 and 2020 reported infrequent PrEP use among PWID, ranging from 0 to 3%.^209^ One study found being insured associated with increased likelihood of PrEP utilization versus being uninsured (adjusted OR 4.49, 95% CI 1.68 to 12.01).^104^

Data on transgender identity and PrEP use are limited. One study of 863 people started on PrEP found that the likelihood of PrEP use was lower in transgender women than MSM (aPR 0.52, 95% CI 0.32 to 0.85);^206^ similarly, a survey also found transgender women (n=369) were less likely to use PrEP than MSM (n=399) (Prevalence Ratio [PR] 0.36, 95% CI 0.28 to 0.47).^210^ Data on other factors such as transactional sex, cultural factors, and health literacy and disparities in PrEP utilization were lacking. Perceived stigma regarding PrEP has been associated with decreased likelihood of PrEP initiation in transgender women as well as women not identifying as transgender.^211,212^

### Contextual Question 5. What Is the Effectiveness of Primary Care Interventions to Increase Utilization of PrEP and Decrease Disparities in Utilization?

Five randomized trials^213–217^ and one non-randomized study^218^ evaluated interventions relevant to U.S. primary care settings to increase utilization of PrEP in persons at higher risk of HIV infection. Sample sizes ranged from 50 to 164 (Appendix D Table 3). Four trials evaluated MSM;^213–216^ among these trials, one also included transgender women,^213^ one focused on young MSM,^214^ and three trials^213–215^ focused on Black populations. One other trial^217^ evaluated persons interested in PrEP without restricting to a specific risk category and the non-randomized study^218^ evaluated women with substance use disorders in addiction treatment. The interventions varied in intensity and methods, but generally involved counseling and education; other approaches included peer mentoring and a patient-centered decision aid. All studies were conducted in the United States and participants were recruited from STI, addiction treatment, and other outpatient clinics; using social network applications; or at community events, community organizations, and public venues.

Four trials of HIV-negative MSM at higher risk of HIV infection found interventions associated with increased uptake of PrEP.^213–216^ Three trials focused on Black MSM and one of these focused on younger MSM, suggesting that the interventions could potentially reduce disparities in PrEP utilization among these populations. However, the trials were not designed to directly measure impacts on disparities in PrEP utilization. One trial (n=146, median age 26 years) of Black MSM and Black transgender women presenting in STI clinics found an intervention based on the information-motivation-behavioral skills model (administered by a social work interventionist in a 60 minute face-to-face session) associated with increased likelihood of PrEP initiation at 3 months versus usual services (24% vs. 11%, p=0.05 based on self-report; 20% vs. 11%, p=0.15 based on electronic medical record linked data).^213^ A smaller (n=50) trial of young (16 to 25 years, mean age 22 years) Black MSM recruited using social networking applications evaluated a personalized comprehensive client-centered counseling and education intervention (administered by a staff member who self-identified as a Black MSM) versus standard PrEP education.^214^ The comprehensive counseling and education intervention was associated with increased likelihood of PrEP initiation at 3 months (24% vs. 0%, p=0.02). Another trial (n=80) of older (mean age 44 years) Black MSM recruited from public venues, community organizations, and community events compared an intervention consisting of peer mentoring and group behavioral/educational activities with a customized needs assessment and incentivized referrals to health and support services versus the needs assessment and incentives alone. The addition of peer mentoring and group activities was associated with a non-statistically significant increase in use of PrEP at 6 months (22% vs. 9%, p>0.05).^215^ The fourth trial (n=86, mean age 32 years) evaluated MSM of various races/ethnicities (65% White, 10% Black, 5.8% Asian; 26% Latinx) attending STI clinics. Versus usual care, it found a brief (15 to 20 minute) motivational interviewing intervention administered by an STI counselor followed by a brief (<10 minute) telephone booster associated with increased likelihood of further discussing PrEP with a prescriber (OR 6.0, 95% CI 2.3 to 15.6), attending the prescriber appointment (OR 3.6, 95% CI 1.5 to 8.9), and PrEP receipt (OR 3.6, 95% CI 1.5 to 8.9).^216^

Evidence on the effectiveness of interventions to increase uptake of PrEP in populations other than MSM is limited. One trial (n=61) of adults (mean age 40 years; 34% Black, 11% White non-Hispanic, 43% Hispanic) attending outpatient clinics and interested in PrEP evaluated a strengths-based case management intervention administered by a patient navigator in one 45-to-60 minute session and up to 4 additional followup visits or phone/text message contacts.^217^ In this trial, 15 percent of participants were women, 3.2 percent reported injection drug use, and 52 percent reported sexual orientation as gay or bisexual. The strengths-based case management intervention was associated with an increased likelihood of PrEP initiation at 12 weeks versus usual care that was not statistically significant (40% vs. 29%, p=0.37). One non-randomized study (n=164, mean age 40 years; 16% Black, 75% White) of women in addiction treatment found use of a decision aid tailored to this population and setting associated with increased likelihood of seeing a provider for PrEP that was of borderline statistical significance (15.7% vs. 6.2%, p=0.05).^218^

### Contextual Question 6. What Is the Effectiveness of PrEP Delivered Using Telehealth vs. Office-Based PrEP?

Telehealth modalities could support uptake and adherence to PrEP, particularly in rural communities and other populations with limited access or other barriers to traditional office-based health services.^84,219^ Telehealth for PrEP encompasses a variety of modalities, including various provider-to-patient and provider-to-provider (e.g., telementoring or “e-Consults”) approaches. However, evidence on the effectiveness of PrEP delivered using telehealth versus office-based PrEP is very limited. One small (n=48) observational study conducted in Washington state of men and transgender women who have sex with men with risk factors for HIV infection evaluated a telehealth approach to facilitate PrEP initiation.^220^ In this clinic, in-person visits with a physician to initiate PrEP were offered one day a week. Patients who could not attend clinic on that day or who did not wish to wait were offered a telehealth approach, in which the physician was present through interactive videoconference; however, patients still attended clinic for in-person counseling with an HIV counselor and diagnostic testing. Ten patients received the telehealth approach. There were no differences between the telemedicine and standard office-based approach in the proportion of participants prescribed PrEP (70% vs. 79%), the proportion attending the first follow-up visit at 1 month (83% vs. 85%), or adherence at 1 month (median missed doses 2 vs. 1). However, among patients not linked to a primary care provider, only 40 percent (2/5) of telehealth participants attended the 3-month followup visit, compared with 87 percent (20/23) of standard care participants. The telehealth participants reported missing 10 and 14 doses in the prior month, compared with a median of 2 (IQR 0 to 2) for standard care participants. Given the observational nature of the study, these differences were ascribed to confounding related to the reasons for initially selecting the telehealth approach. No cases of HIV infection occurred in either group.

No published randomized trials of telehealth versus office-based PrEP were identified. However, two U.S. trials are scheduled for completion in May 2022,^221–223^ and one other U.S. and one Canadian trial are estimated to be completed in the summer of 2023.^224,225^ One trial (n=396) compares a home-based support system (self-testing, centralized laboratory processing, and electronic behavioral monitoring) for followup in MSM on PrEP, versus standard office-based follow-up visits, targeting enrollment of 50 percent of persons ages 18 to 34 years (18 to 49 years eligible) and 50 percent Black persons.^223^ This intervention (PrEP@Home) is intended to replace three of four annual followup visits, and was previously found to be highly acceptable to patients in an uncontrolled pilot study.^226^ The other trial (n=217) compares a home-based system (ePrEP) for initiation as well as followup of PrEP among young, rural MSM (age 18 to 29 years) versus standard office-based care.^221,222^ The ePrEP intervention consists of video teleconsultations, secure messaging, behavioral risk surveys, and self-testing with centralized laboratory processing. In both trials, the primary outcome is adherence based on blood spot sample levels for TFV-DP; the ePrEP trial will also assess initiation and retention of PrEP. The PrEPTECH trial (n=400) aims to test the effectiveness of website providing access to PrEP to U.S. adolescent and adult MSM and adult transgender women.^224^ Via the website, participants will have access to laboratory testing for PrEP eligibility delivered to their home, telehealth care, and PrEP prescriptions delivered through an online pharmacy, and the primary outcome will be self-report PrEP initiation. The Canadian Virtual PrEP (VPrEP) cross-over trial (n=142) will compare delivery of PrEP through the Freddie^®^ mobile Health (mHealth) platform, where communication could occur over a number of days and minimizes the need for in-person interactions, versus standard delivery, with the primary outcome patient preference of the model of delivery.^225^ Both of these trials will also measure adherence.