# Chapter 2 Methods

## Key Questions and Analytic Framework

Using the methods developed by the USPSTF,^108^ the USPSTF and the Agency for Healthcare Research and Quality determined the scope and Key Questions for this review. Investigators created an analytic framework with the Key Questions and the patient populations, interventions, and outcomes reviewed (Figure 1). Key informants were engaged for input, the draft research plan was posted for public comment, and comments were addressed before finalization.

Figure 1 Analytic Framework and Key Questions

*Harms also include renal dysfunction, adverse effects on bone, pregnancy-related outcomes, infection with antiretroviral drug-resistant HIV, gastrointestinal harms, headaches, and discontinuation due to adverse events.

Key Questions

1. What are the benefits of PrEP in persons without pre-existing HIV infection vs. placebo or no PrEP (including deferred PrEP) on the prevention of HIV infection and quality of life?
  a. How do the benefits of PrEP differ by populations of interest (e.g., defined by age, sex, gender identity, race and ethnicity, and HIV risk category)?
  b. How do the benefits of PrEP differ by dosing strategy or regimen?
2. What are the benefits of newer PrEP regimens (oral TAF-FTC, injectable cabotegravir, or the dapivirine vaginal ring) vs. TDF-FTC?
3. What is the diagnostic accuracy of provider or patient risk assessment tools in identifying persons at increased risk of HIV acquisition who are candidates for PrEP?
4. What are the harms of PrEP vs. placebo or no PrEP when used for the prevention of HIV infection?
5. What are the harms of newer PrEP regimens (oral TAF-FTC, injectable cabotegravir, or the dapivirine vaginal ring) vs. TDF-FTC?

Abbreviations: HIV=human immunodeficiency virus; PrEP=pre-exposure prophylaxis; STIs=sexually transmitted infections; TAF-FTC=tenofovir alafenamide-emtricitabine; TDF-FTC=tenofovir disoproxil fumarate-emtricitabine.

The analytic framework depicts the relationship between the population, intervention, outcomes, and harms of pre-exposure prophylaxis (PrEP) for the prevention of HIV infection. The far left of the framework describes the target population as persons without pre-existing HIV infection. To the right of the population is an arrow which represents assessment of patients for use of PrEP (key question 3) which leads to boxes representing a candidate for PrEP or not a candidate for PrEP. From the candidate for PrEP population box, an arrow representing the use of PrEP leads through a box representing adherence to the effects of PrEP on the clinical outcomes of HIV infection and quality of life (key questions 1 and 2; and also key questions 1a and 1b for whether population subgroups and dosing strategy or regimen affect effectiveness). Key Questions 2 and 5 examine the benefits of newer PrEP regimens versus tenofovir disoproxil fumarate-emtricitabine (TDF-FTC). The assessment of any potential harms of PrEP (key questions 4 and 5), which include other STIs, renal dysfunction, adverse effects on bone, pregnancy-related outcomes, infection with antiretroviral drug- resistant HIV, gastrointestinal harms, headaches, and discontinuation due to adverse events.

### Key Questions

1. What are the benefits of PrEP in persons without pre-existing HIV infection vs. placebo or no PrEP (including deferred PrEP) on the prevention of HIV infection and quality of life?
  a. How do the benefits of PrEP differ by populations of interest (e.g., defined by age, sex, gender identity, race and ethnicity, and HIV risk category)?
  b. How do the benefits of PrEP differ by dosing strategy or regimen?
2. What are the benefits of newer PrEP regimens (oral TAF-FTC, injectable cabotegravir, or the dapivirine vaginal ring) vs. TDF-FTC?
3. What is the diagnostic accuracy of provider or patient risk assessment tools in identifying persons at increased risk of HIV acquisition who are candidates for PrEP?
4. What are the harms of PrEP vs. placebo or no PrEP when used for the prevention of HIV infection?
5. What are the harms of newer PrEP regimens (oral TAF-FTC, injectable cabotegravir, or the dapivirine vaginal ring) vs. TDF-FTC?

### Contextual Questions

Six Contextual Questions were also requested by the USPSTF to help inform the report. Contextual Questions are not reviewed using systematic review methodology.

1. What are rates of adherence to and persistence of PrEP and factors associated with increased or decreased adherence in U.S. primary care settings?
2. How does adherence to and persistence of PrEP vary according to mode of administration (e.g., oral, injectable, or vaginal ring)?
3. What is the risk of infection with antiretroviral drug–resistant HIV in persons using PrEP, and what is the effect of infection with PrEP-related, antiretroviral drug–resistant HIV on treatment outcomes?
4. What factors (e.g., race and ethnicity, age, sex, gender, sexual orientation, HIV risk category, socioeconomic status, cultural factors, educational attainment, or health literacy) are associated with disparities in utilization of PrEP?
5. What is the effectiveness of primary care interventions to increase utilization of PrEP and decrease disparities in utilization?
6. What is the effectiveness of PrEP delivered using telehealth vs. office-based PrEP?

## Search Strategies

We searched MEDLINE, the Cochrane Database of Systematic Reviews, the Cochrane Central Register of Controlled Trials, and Embase starting in January 2018 (the prior report searches went through June 2018, with surveillance through January 2019) to May 16, 2022, and carried forward the relevant included studies from the prior report. We also reviewed reference lists of relevant articles. Search strategies are available in Appendix A1. Additional surveillance for new literature was conducted through March 24, 2023, and no new eligible trials were found.

## Study Selection

All titles and abstracts identified through searches were independently reviewed by two members of the research team for eligibility against predefined inclusion and exclusion criteria, as specified using the PICOTS (population, intervention, comparator, outcome, timing, study design) framework (Appendix A2). Studies marked for possible inclusion by any reviewer underwent full-text review. All results were tracked in an EndNote^®^ database (Thomson Reuters, New York, NY). We excluded non-English–language articles and studies published only as conference abstracts. In accordance with the USPSTF Procedure Manual,^108^ studies assessed as poor quality were excluded.

Each full-text article was independently reviewed by two members of the research team for inclusion or exclusion on the basis of the eligibility criteria. If the reviewers disagreed, conflicts were resolved by discussion and consensus or by consulting another member of the review team. Results of the full-text review were also tracked in the EndNote database, including the reason for exclusion for full-text publications. The selection of literature is summarized in the literature flow diagram (Appendix A3). Appendix A4 lists the included studies, and Appendix A5 lists the excluded studies with reasons for exclusion.

## Scope of Review

The population of interest for PrEP was HIV-uninfected persons at higher risk of HIV acquisition. The review addresses evidence on PrEP in adults, including pregnant persons without HIV and persons without HIV seeking to become pregnant with a partner with HIV, as well as adolescents (defined as persons 13 to <18 years of age). Patient populations of interest were based on demographic characteristics (age, sex, gender identity, race and ethnicity, and pregnancy status) and HIV risk category (MSM, PWID, or persons at risk due to heterosexual contact). For the Key Question on risk assessment, we included studies on the diagnostic accuracy of provider or patient assessment instruments to predict HIV acquisition, for identification of potential candidates for PrEP.

The PrEP interventions addressed in this report were oral daily TDF-FTC, the first FDA-approved PrEP regimen and the more recently FDA-approved regimen of oral daily TAF-FTC. Oral TDF monotherapy was also included, even though it is not approved by the FDA for PrEP, since it has been evaluated in several randomized trials and a large trial found no clear difference between TDF and TDF-FTC in effects on risk of HIV acquisition.^51^ Although oral TDF monotherapy was noted as an option for PrEP in PWID and heterosexual men and women in the 2017 United States Public Health Service guideline^82^ and the 2019 USPSTF recommendation,^1^ it is no longer^84^ a recommended option. Therefore, sensitivity analyses will be conducted without TDF monotherapy. We also included injectable cabotegravir for PrEP, given the publication of recent randomized trials and inclusion in recent guidelines;^84,87,109^ on 12/20/21, injectable cabotegravir was approved by the FDA for PrEP.^75^ We also evaluated alternative (non-daily) oral dosing schedules (e.g., event-driven [on-demand]^66^ or intermittent dosing^67,68^), which are not approved by the FDA but have been evaluated in randomized, controlled trials (RCTs) and adopted in some settings and recommended in the updated United States Public Health Service guideline as an option for MSM.^84^ We stratified analyses according to the regimen used as well as the dosing regimen (daily or event-driven/intermittent). We also included the dapivirine vaginal ring, even though it is not currently FDA-approved for any indication (and has been withdrawn from FDA review), because it is recommended by the WHO as an option for PrEP in women at increased risk and is being studied in a randomized trial of PrEP during pregnancy.^73,74,80,110–112^ We did not include other PrEP regimens (e.g., oral maraviroc,^113–115^ tenofovir vaginal gel,^54,116,117^ or injectable rilpivirine) because they are not approved by the FDA, have limited evidence of effectiveness or evidence of low effectiveness, and are not recommended in clinical practice guidelines. The main comparisons were PrEP versus placebo or delayed PrEP.^118^ Because newer PrEP regimens have only been compared against TDF-FTC, we added new Key Questions assessing benefits and harms with this comparison. To address effects of dosing method on effectiveness, we also included randomized trials of daily versus nondaily (intermittent or event-driven) PrEP.

The primary outcome was the rate of HIV infection; other outcomes were mortality, quality of life, and harms, including rates of non-HIV STIs (gonorrhea, syphilis, chlamydia, herpes simplex virus [HSV] infection, or any STI), hepatitis B and C virus infection, renal insufficiency, fractures, gastrointestinal adverse events, and pregnancy-related outcomes. HSV infection was addressed as a potential harm because of possible effects of behavioral risk compensation, although tenofovir may have antiviral effects that decrease risk of HSV transmission.^119,120^ Although the report focuses on effects of PrEP on health outcomes, for comparing newer versus older PrEP regimens effects on weight gain and lipid profiles were also addressed, given some data suggesting potential differences.^121^

We included randomized trials of PrEP versus placebo or no PrEP and randomized trials of newer PrEP regimens versus TDF-FTC. For evaluation of risk assessment instruments, we included studies assessing predictive utility.

Because the association between adherence and effectiveness of PrEP has been well established, we removed a Key Question from the 2019 review addressing this question. We included Contextual Questions on adherence to PrEP and factors associated with increased or decreased adherence in U.S. primary care practices in order to help assess current implementation of PrEP. Methods for measuring adherence include patient diaries and self-report, pill counts, adherence monitoring devices, drug levels (e.g., plasma, dried blood spots, or urine levels), and prescription fill data. In addition to adherence (taking PrEP as instructed) we also evaluated factors associated with PrEP persistence (continuation). We retained a Contextual Question on the association between use of PrEP and presence of antiretroviral drug resistance, as well as effects of infection with antiretroviral drug–resistant HIV infection on clinical outcomes, given that this was identified as an evidence gap in the prior review. Like the prior review, this was not addressed as a Key Question because antiretroviral resistance due to PrEP appears to be uncommon, effects of antiretroviral resistance on clinical outcomes depend on a variety of factors (e.g., type of resistance mutation, availability of alternative antiviral regimens, and adherence to alternative regimens), and evidence on effects of PrEP-selected resistance on clinical outcomes appears to be very limited.^122^ We added new Contextual Questions on disparities in utilization of PrEP and interventions to increase utilization (including same-day initiation) and reduce disparities. In the context of the COVID-19 era and to potentially facilitate implementation of PrEP, we also added a new Contextual Question on effectiveness of telehealth-delivered PrEP versus standard office-based PrEP.

Contextual Questions were addressed through targeted literature searches to identify key articles to inform the USPSTF. Contextual Questions on adherence and utilization focused on randomized trials of PrEP and large implementation studies, surveys, and other observational studies conducted in the United States. For antiretroviral resistance, we used randomized trials of PrEP and open-label extensions of the trials. For interventions to increase PrEP utilization and PrEP by telehealth, we used randomized trials and comparative observational studies relevant to U.S. primary care settings.

## Data Abstraction and Quality Rating

For studies meeting inclusion criteria, we updated data abstraction forms from the prior USPSTF review to summarize characteristics of study populations, interventions, comparators, adherence, and methods for assessing adherence, outcomes, study designs, settings, and methods. One investigator conducted data abstraction, which was reviewed for completeness and accuracy by another team member.

Predefined criteria were used to assess the quality of individual controlled trials, systematic reviews, and observational studies by using criteria developed by the USPSTF; studies were rated as “good,” “fair,” or “poor” based on the seriousness of methodological shortcomings (Appendix A6). We evaluated the credibility of subgroup analyses based on whether the subgroups were predefined, whether subgroup characteristics were measured at baseline, whether the analyses were across or within studies, whether within-study comparisons were randomized, whether statistical tests for interaction were significant, the precision of estimates, the consistency of subgroup effects across studies, and whether results were biologically plausible.^123^

For each study, quality assessment was performed by two team members. Disagreements were resolved by consensus.

## Data Synthesis and Analysis

Meta-analyses were updated and new meta-analyses were conducted for outcomes and comparisons for which there were multiple studies homogeneous enough to provide a meaningful combined estimate. The appropriateness of meta-analyses was based on the quality and number of studies and similarity between studies in design, patient population, interventions, and outcomes. Due to anticipated statistical heterogeneity, meta-analyses to calculate risk ratios for effects of PrEP on HIV infection, mortality, and harms were conducted using the DerSimonian and Laird random-effects model. Statistical heterogeneity was assessed using the I^2^ statistic.^124^ When the I^2^ was greater than 30 percent, sensitivity analysis was performed with the profile likelihood method, as the DerSimonian and Laird model can result in overly narrow confidence intervals (CIs) in this situation.^125^ We conducted sensitivity and stratified analyses based on study quality, PrEP drug regimen, HIV risk category (MSM, PWID, and men and women at increased risk via heterosexual contact), dosing schedule (daily or event-driven/intermittent), study duration (<1 year, ≥1 to <2 years, or ≥2 years), and country (United States and other high-income countries or low-/middle-income countries and international studies). We also conducted sensitivity analyses using data from the FDA medical review of PrEP on HIV incidence and fracture rates in place of data reported in journal articles for these outcomes.^126^ For analyses with at least 10 trials, we constructed funnel plots and performed the Egger test to detect small sample effects (a marker for potential publication bias).^127^

Qualitative data was summarized in summary tables providing estimate ranges, descriptive analysis, and interpretation of results. Assessments of applicability were based on the countries in which studies were performed, the demographic characteristics of the patients enrolled, the PrEP interventions used, and rates of HIV acquisition, adherence, and use of postexposure prophylaxis.

For all Key Questions, the overall quality of evidence was determined using the approach described in the USPSTF Procedure Manual.^108^ Evidence was rated “good,” “fair,” or “poor” based on the number, quality and size of studies, consistency of results between studies, and directness of evidence.^108^

## USPSTF and AHRQ Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and key questions and to resolve issues around scope for the final evidence synthesis.

AHRQ staff provided oversight for the project, coordinated the systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.

## Expert Review and Public Comment

The draft Research Plan was posted for public comment on the USPSTF website from November 4, 2021, to December 8, 2021. The Research Plan underwent minor revisions to improve clarity. In addition, hepatitis B was added as an outcome, “persistence” was added to Contextual Questions 1 and 2, and Contextual Question 5 was expanded to address primary care interventions to increase utilization of PrEP in general, in addition to addressing interventions to decrease disparities in utilization.

A draft version of this report was reviewed by content experts and Federal representatives (Appendix A7), and minor edits were made for clarity and language/terminology regarding gender. In addition, the draft was posted for public comment from 12/13/22 to 1/17/23. The comments were reviewed and minor edits were made to improve clarity, but no changes to the studies or conclusions were required.