# Chapter 1 Introduction and Background

## Purpose

Effective strategies to prevent HIV infection are an important public health priority. Pre-exposure prophylaxis (PrEP) involves use of antiretroviral medications on an ongoing basis (e.g., daily or bimonthly) or before and after HIV exposure events (“on-demand” or “event-driven” PrEP) to decrease the risk of acquiring HIV infection. This report will be used by the U.S. Preventive Services Task Force (USPSTF) to update its 2019 recommendation on PrEP for the prevention of HIV infection; at the time, this was a new topic for the USPSTF. In 2019, the USPSTF recommended that clinicians offer PrEP with effective antiretroviral medications to persons at high risk of HIV acquisition (Grade A Recommendation).^1^ The recommendation was based on convincing evidence that PrEP is of substantial benefit in reducing the risk of HIV infection in persons at high risk of HIV acquisition and adequate evidence of small harms, resulting in high certainty of substantial net benefit. The USPSTF also found convincing evidence that the effectiveness of PrEP is highly correlated with adherence.

In October 2019, following the release of the USPSTF recommendation, the U.S. Food and Drug Administration (FDA) approved tenofovir alafenamide fumarate (TAF)-emtricitabine (FTC) for PrEP. Subsequently, the USPSTF commissioned a brief, focused update on TAF-FTC for PrEP, which found it to be noninferior to the standard PrEP regimen of tenofovir disoproxil fumarate (TDF)-FTC in reducing risk of HIV infection. In December 2021, extended-release cabotegravir was FDA-approved for PrEP in December 2021.

This report will update the 2019 USPSTF review on PrEP.^2^ Like the prior review, it will synthesize evidence on benefits and harms of PrEP (including newer regimens), effects of adherence, and accuracy of methods for identifying potential candidates for PrEP. In addition, it will address utilization of PrEP, including potential disparities, as well as methods for reducing disparities.

Note: Studies on PrEP vary in precision when describing the distribution of gender identity and sex assigned at birth of study populations. In the absence of specific and detailed information on gender and sex (e.g., cisgender man, transgender man), we will use gender terminology (e.g., man, woman) rather than terminology commonly used to describe biological sex at birth (e.g., male, female, intersex). We recognize that information on gender reported in studies is often inferred or assumed based on anatomy or personal presentation and may not reflect some patients’ self-identified gender. We also recognize that binary construction of gender fails to account for individuals who do not identify as men or women. We aim to accurately describe the gender composition of the studies underlying the included evidence to the extent possible, and to use gender-inclusive language where reporting clarity can be retained without gender identifiers. In this document, the terms man and woman generally refers to cis man and cis woman, though it is not always certain that other genders are excluded.

## Condition Background

### Condition Definition

HIV is a ribonucleic acid retrovirus that infects immune cells in humans—in particular, CD4+ T helper cells (referred to as CD4 count in this report). Untreated, HIV infection results in progressive immunodeficiency and AIDS in more than 90 percent of patients. AIDS is a potentially life-threatening condition that occurs when HIV becomes severe, as defined by a CD4 count of 200 cells/mm^3^ or less or one or more AIDS-defining neoplastic conditions or opportunistic infections.^3^ HIV-1 infection is the most common variant in the United States. HIV-2 infection is rare in the United States, less clinically severe, and endemic in parts of West Africa.^4^

### Prevalence and Burden of Disease/Illness

Since the first cases of AIDS (Stage 3 HIV) were reported in 1981, more than 766,380 persons diagnosed with AIDS in the United States have died, and 1,307,283 persons have been diagnosed.^5^ The Centers for Disease Control and Prevention (CDC) estimates that approximately 1.2 million persons in the United States were living with HIV infection in 2019,^6^ including 13 percent who were unaware of their infection. This represents a decrease since 2008, when approximately 20 percent of infected persons were estimated to be unaware of their HIV infection status.^7–9^ In 2019, 36,585 persons were newly diagnosed with HIV, a rate of 11.1 per 100,000 people; whereas in 2016 there were 39,552 new infections.^10^ There were 16,232 deaths among adults and adolescents with HIV in the United States in 2019 from any cause; there were 16,372 deaths in 2016.^10^ Although the CDC reported that the number of HIV diagnoses declined to 30,403 in 2020, it noted that data might be less reliable due to COVID-19 related disruptions to HIV testing, care-related services, and surveillance.^10^

Groups more affected by HIV infection in the United States include men who have sex with men (MSM) and Black and Hispanic/Latinx persons. Between 2006 and 2009, there was a 21 percent increase in HIV incidence among persons ages 13 to 29 years, driven largely by a 34 percent increase among MSM, the only risk group to experience a significant increase in incidence during this period (p<0.001).^11^ In 2019, of total HIV diagnoses, 29,589 (81%) were among adult and adolescent men (age 13 years or older), 6,939 (19%) were among adult and adolescent women, and 57 (0.1%) were among children younger than age 13 years.^10^ Among adolescents, the incidence of HIV infection rose sharply from ages 13 to 14 years (0.2 cases per 100,000 persons) to ages 15 to 19 years (7.8 cases per 100,000 persons). In 2019, the highest rates (per 100,000 persons) by age group were 27.5 among persons 20 to 24 years of age, 31.4 among those 25 to 29 years of age, and 25.3 among those 30 to 34 years of age. By race/ethnicity, 42 percent of new diagnoses occurred among Black persons, 25 percent among White persons, and 27 percent among Hispanic/Latinx persons. Among men, having sex with men is the most common transmission method (81%), followed by heterosexual contact (9.1%), injection drug use (4.7%), and having sex with men and injection drug use together (5.1%). Among women, heterosexual contact is the most common transmission method (83%), followed by injection drug use (17%).^10^ Among transgender women, the prevalence of HIV is 62 percent in Black transgender women, 35 percent in Hispanic/Latinx transgender women, and 17 percent in White transgender women.^12^

### Etiology and Natural History

HIV infection is acquired through mucosal or intravenous exposure to infected bodily fluids such as blood, semen, and genital tract secretions. The presence of sexually transmitted infections (STIs) increases risk, as do certain sexual behaviors (e.g., penile-anal or penile-vaginal intercourse without a condom, sex with multiple partners, sex with persons with HIV with a detectable viral load^13^ or at high risk of HIV infection), and high viral load in the infected partner.^14,15^ In persons who inject drugs (PWID), factors associated with HIV infection include increased frequency or duration of injection behaviors and certain drug use behaviors (e.g., sharing needles or backloading [injecting drugs from one syringe into the back of another opened syringe]).^16^

The primary HIV infection syndrome usually develops 2 to 4 weeks following initial exposure to HIV.^17^ Acute infection is often associated with a clinical syndrome resembling infectious mononucleosis.^18,19^ Very early after acute infection, there is rapid virus production that then declines to a set point (the set point varies between individuals) as the host immune system responds, although continuous rapid virus production and clearance occurs at all stages of infection.^20–25^

Although a small proportion of untreated persons with HIV remain asymptomatic and show little evidence of progressive immune suppression after 10 or more years of infection, more than 90 percent of untreated patients eventually develop AIDS.^3^ In the era before highly active antiretroviral therapy (HAART) was available, the median time from seroconversion to the development of AIDS was 7.7 to 11.0 years, and median survival was 7.5 to 12 years.^26,27^

The primary mechanism through which chronic HIV infection causes immune deficiency is through a decrease in the level and functioning of CD4 cells. In untreated HIV infection, the CD4 count declines an average of 50 to 75 cells/mm^3^ per year.^28^ Most patients with CD4 counts over 200 cells/mm^3^ are either asymptomatic or have mild disease,^29^ although data indicate an increased risk of AIDS or death even in patients with CD4 counts over 500 cells/mm^3^.^30^ Patients with CD4 counts less than 200 cells/mm^3^ have advanced immunodeficiency and are at markedly increased risk of AIDS-related opportunistic infections, other AIDS-related complications, and AIDS-associated mortality.^31–33^

A higher HIV viral load is a strong independent predictor of more rapid progression to AIDS.^31–36^ Other predictors of more rapid progression include older age at the time of infection,^26,27,31,32,35,37,38^ more severe symptoms at the time of primary HIV infection,^39^ and other clinical and genetic factors. A factor associated with slower progression is the cysteine-cysteine chemokine receptor 5 delta32 genotype.^40–44^

### Risk Factors

Persons at increased risk of HIV infection include MSM; men and women who have condomless vaginal or anal intercourse with more than one partner; men and women who exchange sex for drugs or money; persons with a history of or current injection drug use; persons with or seeking treatment for other STIs; persons with a history of blood transfusion between 1978 and 1985; persons whose past or current sexual partners are infected with HIV with a detectable viral load,^13^ bisexual, or PWID; transgender persons; and persons who do not report one of these risk factors but who request HIV testing.^45–47^ Settings in which the prevalence of HIV infection is often more than 1 percent include STI clinics, correctional facilities, homeless shelters, tuberculosis clinics, clinics specialized in the care of sexual and gender minorities, and clinics caring for an adolescent community with a high prevalence of STIs.^48^

### Rationale for Preventive Strategies

HIV infection remains incurable, requiring lifelong treatment, and can have important health consequences. Therefore, preventing HIV infection is an important public health and clinical priority. In the absence of an effective vaccine, HIV prevention strategies include screening, as recommended by the USPSTF^49^ and others, to identify infected persons; treatment with antiretroviral therapy (ART) in persons with HIV to reduce risk of transmission^50^; and behavioral counseling to reduce high-risk sexual and drug use behaviors.

For persons at increased risk of HIV infection who are not infected, PrEP with antiretroviral medications^51–55^ in combination with risk behavior counseling is another prevention strategy to reduce risk of acquiring HIV infection.^56^ PrEP involves use of antiretroviral medications on an ongoing, regular (e.g., daily) basis or before and after HIV exposure events to lower the likelihood of acquiring HIV infection. PrEP differs from nonoccupational postexposure prophylaxis, which involves use of antiretroviral medications for 28 days after a single high-risk exposure.^57^ Expanded use of PrEP has been highlighted as a critical component in the national initiative to end the HIV epidemic in the United States.^58^

### Interventions/Treatment

The standard antiretroviral regimen for PrEP has been a daily oral fixed-dose combination of the nucleoside reverse transciptase inhibitors TDF (a prodrug of tenofovir) and FTC. This combination was selected because of its effectiveness as part of antiretroviral treatment for HIV infection, favorable safety profile, relatively high genetic barrier to resistance, and achievement of high concentrations in rectal tissue (TDF) and female genital tissue (FTC).^59^ In 2012, the FDA approved daily oral TDF-FTC for PrEP in adults at risk of sexual acquisition of HIV-1 infection.^60^ In 2018, the FDA expanded the indication for PrEP to include adolescents weighing at least 35 kg (77 lb).^61^ Oral daily TDF without FTC has also been evaluated for PrEP, but is not FDA-approved for this indication. As described above, FDA approved TAF-FTC for PrEP in adolescents and adults weighing at least 35 kg in 2019 to reduce risk of sexually acquired HIV-1 infection, excluding those at risk of acquiring HIV through receptive vaginal sex, due to the lack of clinical data in this population.^62^ Like TDF, TAF is a prodrug of tenofovir, a nucleoside reverse transcriptase inhibitor of HIV. However, TAF is transported into peripheral blood mononuclear cells (the target of HIV) more rapidly than TDF and achieves higher and more sustained intracellular drug levels at lower tenofovir serum levels.^63^ Higher intracellular levels of tenofovir could result in increased effectiveness and lower serum levels could result in increased safety, including reduction in known negative effects of tenofovir on kidney function and bone mineral density.

Because effectiveness of PrEP depends on adherence,^2,64^ there has been interest in nondaily oral regimens that may enhance adherence while maintaining effectiveness of PrEP,^65^ as well as other approaches to enhance adherence. Alternative regimens include event-driven^66^ (taken before and after an anticipated HIV exposure event; also referred to as “on-demand” or “2-1-1” PrEP) or intermittent (scheduled, nondaily) dosing of oral PrEP.^67,68^ Studies have also evaluated alternative, nonoral modes of PrEP that require infrequent dosing (e.g., long-acting injectables^69–71^ or an intravaginal ring^72–74^). As mentioned earlier, on December 20, 2021, cabotegravir was FDA-approved in adults and adolescents >35 kg^75^ for PrEP to reduce risk of sexually acquired HIV infection. In the trials conducted to obtain FDA approval, cabotegravir was initiated with a daily oral lead-in for up to five weeks, followed by monthly injections for two months, and then bimonthly injections. The oral lead-in was designed to assess tolerability; given the high tolerability observed in the trials, the FDA-approved label considers the oral lead-in to be optional.

Factors that may affect the balance of benefits and harms in persons prescribed PrEP include adverse drug-related events, the potential for antiretroviral resistance in persons who acquire HIV while taking PrEP, and the potential for behavioral risk compensation. Behavioral risk compensation refers to an increase in behaviors associated with HIV transmission (e.g., sex without a condom or multiple sexual partners). Because PrEP does not protect against STIs such as syphilis, chlamydia, and gonorrhea, behavioral risk compensation could increase the rate of STIs, a potential harm that could attenuate benefits from preventing HIV acquisition, or result in unintended pregnancy. Another potential harm is that PrEP could induce antiretroviral resistance in persons with HIV who inadvertently receive PrEP or in HIV-uninfected persons who acquire infection while on PrEP. With long-acting injectables such as cabotegravir, an extended pharmacokinetic tail (persistence of the drug at slowly declining levels) following administration poses a risk for selection of resistance in persons who are not adherent.^76^ Adverse effects of TDF include negative effects on bone density and kidney function.^77–79^ A potential advantage of TAF over TDF is that it achieves higher and more sustained intracellular drug levels at lower tenofovir serum levels, which could reduce negative impacts on kidney function and bone health.^63^ The dapivirine vaginal ring is inserted monthly, may enhance autonomy in use of PrEP, and results in little systemic absorption, potentially increasing safety during pregnancy. However, data indicate lower efficacy than standard oral PrEP regimens.^80^ Among transgender persons, potential issues related to use of PrEP include concerns that PrEP could negatively affect hormone therapy, or that hormones might decrease the efficacy of PrEP.^81^

### Current Clinical Practice/Recommendations of Other Groups

In 2014, the United States Public Health Service issued a guideline^82^ recommending PrEP with TDF-FTC in adults at high risk of infection, including MSM with a high number of sexual partners or inconsistent condom use, MSM and heterosexual persons in HIV-serodiscordant relationships, other high-risk heterosexual persons, and PWID who have an HIV positive partner or share injection equipment; the guideline was updated in 2017^83^ and in 2021.^84^ Required elements for PrEP include documentation of a negative HIV test prior to initiating PrEP, ongoing adherence and behavioral risk reduction support, and periodic (every 6 months) screening for STIs. Criteria from the 2021 guideline for PrEP were revised and simplified in persons at risk due to sexual exposure to include those who have had anal or vaginal sex in the past 6 months and: 1) an HIV-positive sexual partner (particularly if the partner has an unknown or detectable viral load); 2) bacterial sexually transmitted infection in the last 6 months; or 3) inconsistent or no condom use with sexual partners(s) of unknown HIV status (Table 1). PrEP is also recommended in those who do not meet these criteria, but request it, due to potential undisclosed risk. Changes in the 2021 guideline^84^ include recommendations for PrEP in adolescents weighing at least 35 kg; TAF-FTC as an option for men and transgender women at sexual risk; a recommendation and guidance for use of cabotegravir when FDA-approved (it was approved shortly after guideline publication^75^); and guidance on PrEP by telehealth, same-day PrEP initiation, and off-label use of TDF/FTC to MSM using an on-demand (“2-1-1”) regimen. Unlike the prior guidelines, TDF alone is no longer a recommended option for PrEP. The guideline recommends that providers offer PrEP with TDF-FTC to women seeking to conceive and pregnant or breastfeeding persons whose sexual partner has HIV, especially when their current partner’s viral load is unknown or detectable. FDA labeling information and perinatal antiretroviral treatment guidelines permit use of TDF-FTC (as well as TAF-FTC) during pregnancy, with data indicating no increased risk of adverse effects among fetuses exposed to these medications when used as PrEP or for HIV treatment. The guideline notes that evidence on safety of PrEP with TDF-FTC or TAF-FTC in breastfeeding infants is lacking, though data indicate limited exposure via breast milk. Data on safety of cabotegravir in pregnancy or while breastfeeding are lacking;^85^ data suggest a possible association between fetal exposure to dolutegravir (a medication in the same integrase strand inhibitor class as cabotegravir) and small increase in risk of neural tube defects.^86^

Table 1 Summary of Guidance on Use of PrEP

Organization | Guidance for | Details
U.S. Public Health Service/CDC, 2021^84^ | Sexually-active adults and adolescents | Anal or vaginal sex in past 6 months AND any of the following:; - HIV-positive sexual partner (especially if partner has an unknown or detectable viral load); - Bacterial STI in past 6 months; - History of inconsistent or no condom use with sexual partner(s)
U.S. Public Health Service/CDC, 2021^84^ | Persons who inject drugs | - HIV-positive injecting partner; OR; - Sharing injection equipment
IAS-USA, 2020^87^ | Individuals at risk for HIV infection | - Initiation of PrEP is recommended as soon as feasible for individuals who have chosen to use it; - Tenofovir disoproxil fumerate/emtricitabine once daily is recommended for oral PrEP; - For MSM, a double dose (2 pills) of tenofovir disoproxil fumerate/emtricitabine is recommended on the first day; - For MSM with or at risk for kidney dysfunction, osteopenia, or osteoporosis, daily tenofovir alafenamide/emtricitabine is recommended; - Oral PrEP dosing using the 2-1-1 (or on-demand) method is recommended only for MSM; - Injectable cabotegravir every 8 weeks is recommended as PrEP for cisgender men and transgender women who have sex with men
WHO, 2016^89^ and 2021^80^ | Individuals at substantial risk for HIV infection | - Oral PrEP containing TDF should be offered as an additional prevention choice for people at substantial risk of HIV infection as part of combination HIV prevention approaches; - Provisional definition of substantial risk is defined as HIV incidence higher than 3 per 100 person-years in the absence of PrEP; - HIV incidence higher than 3 per 100 person-years has been identified among some groups of MSM, transgender women in many settings, and heterosexual men and women who have sexual partners with undiagnosed or untreated HIV infection. Individual risk varies within groups at substantial risk, depending on individual behavior and the characteristics of sexual partners.; - The WHO now also recommends the dapivirine vaginal ring as a new choice for women at substantial risk of HIV infection^80^

Abbreviations: IAS=Intemational AIDS Society; PrEP=pre-exposure prophylaxis; STI=sexually transmitted infection; TDF-FTC=tenofovir disoproxil fumarate-emtricitabine, WHO=World Health Organization.

The International Antiviral Society-USA also recommends PrEP in adults and adolescents at risk for HIV infection (Table 1).^87^ Daily TDF-FTC is recommended for oral PrEP, with on-demand TDF-FTC an option for MSM and TAF-FTC for MSM at risk for kidney dysfunction, osteoporosis, or osteopenia. The society recommends injectable cabotegravir for cisgender men and transgender women who have sex with men contingent on FDA approval.^75^ The guideline does not address cabotegravir for cisgender women, as the trial in which cabotegravir was evaluated in this population had not yet been published.^88^

The World Health Organization (WHO) recommends oral PrEP containing TDF for people at substantial risk of HIV infection.^89^ “Substantial risk” was provisionally defined as HIV incidence around 3 per 100 person-years or higher in the absence of PrEP, including some groups of MSM, transgender women in many settings, and heterosexual men and women who have sexual partners with undiagnosed or untreated HIV infection (Table 1). WHO now also recommends the dapivirine vaginal ring as an option for women at substantial risk of HIV infection.^80^ However, the dapivirine ring is not approved by the Food and Drug Administration for any indication and has been withdrawn by its manufacturer from FDA review, due to the manufacturer’s assessment of a low likelihood of obtaining approval.^90^ The WHO has issued an implementation tool for PrEP.^91^

Recent data indicate that implementation of PrEP in the United States has increased,^92^ but remains limited.^93^ In 2019, the CDC estimated that approximately 285,000 of 1.2 million eligible individuals for PrEP (or 23%) received it, an increase from about 20 percent in 2015.^94^ A number of clinician and patient barriers to wider use of PrEP have been identified, including lack of knowledge/awareness of PrEP (particularly among primary care providers),^95–98^ perception of HIV risk, stigma, distrust of healthcare providers and systems, access to PrEP and costs, and concerns about harms.^99,100^ Even among academic primary care providers with high awareness of PrEP, one 2015 survey found that only a minority (approximately one-third) had adopted it.^101^ An analysis of a large commercial insurance database found that primary care physicians prescribed 79 percent of PrEP while infectious disease physicians prescribed 7 percent; however, the majority of prescribing physicians provided HIV care (primary care or infectious disease).^92^

Under the Affordable Care Act, U.S. health plans are required to cover USPSTF “A” and “B” recommendations without cost sharing starting one year from the issue date of the recommendation (June 30, 2020),^102^ potentially increasing utilization and uptake by removing a financial barrier. However, data on PrEP utilization following the 2019 USPSTF recommendation are not yet available.

### Disparities

Significant disparities have been reported around use of PrEP. Although Black persons are estimated to account for approximately 40 percent of persons in the U.S. with indications for PrEP, data indicate that in 2019, the number of White persons prescribed PrEP was approximately five times higher than the number of Black persons.^103^ In 2019, CDC estimated PrEP coverage (the proportion eligible that received PrEP) at 7.9 percent in Black persons and 13.8 percent in Hispanic/Latinx persons, compared with 60.5 percent among White persons. Other factors associated with decreased utilization of PrEP include younger age, being women, substance use disorder, and being uninsured.^103,104^ Similar patterns were observed in 2020 and 2021; however, 2020 data were considered less reliable due to COVID-19 related disruptions and 2021 data were considered preliminary.^103^ Although the incidence of HIV infection is particularly high among Black and Hispanic/Latino adolescent and young adult MSM, data indicate low awareness and uptake of PrEP in this population.^105^ Utilization of PrEP also appears low in transgender persons; one study based on a national probability sample found that 3 percent of transgender persons at risk for HIV infection reported currently taking PrEP, despite most (72%) reporting favorable attitudes towards PrEP.^106^ In populations with less utilization of PrEP, some evidence indicates that disparities may be related to both decreased likelihood of PrEP initiation as well as increased likelihood of discontinuation among those who initiate.^107^