# Appendix D Contextual Question Tables

Appendix D Table 1 Rates of Adherence and Persistence to PrEP in U.S. Primary Care Settings

Study, year; Type of PrEP | Study design | N | Population | Years PrEP Administered | Adherence: Drug levels | Adherence: Self report | Adherence: Other method | Persistence
ANCHOR; Brokus, 2021^263^; Oral PrEP | Treatment series | 29 | People with OUD receiving HCV treatment; Median age: 54 years; Male: 72%; Black: 90%; Heterosexual: 93% | NR | TFV-DP DBS detectable at week 4 94% (17/18); consistent with ≥4 pills/week 68% at week 24 and 25% at week 36 | 7 pills/week: 52.2% (12/23) at 4 weeks, 47.6% (10/21) at 12 weeks, 62.5% (5/8) at 48 weeks; ≥4 pills/week: 73.9% (17/23) at 4 weeks, 71.4% (15/21) at 12 weeks, 87.5% (7/8) at 48 weeks | NR | Retention: 86.2% (25/29) at week 4, 72.4% (21/29) at week 12, 44.8% (13/29) at week 24, 31.0% (9/29) at week 36
Blackstock, 2017^196^; Oral PrEP | Treatment series | 21 | Heterosexual women receiving PrEP; Median age: 35 years; Non-Latinx Black: 29%; Latinx: 38%; Other/not documented race/ethnicity: 33% | 2015-2016 | NR | NR | NR | Retained in care (PrEP care-related clinic visit or phone note within 1 month of clinic visit): 61.1% (13/21) at 3 months, 37.5% (8/21) at 6 months
Chan, 2016^187^; Oral PrEP | Treatment series | 267 | MSM (89%), MSF (5.2%), FSM (6.7%); Mean age: 32 years; White: 44%; Black/African American: 41%; Asian: 2.8%; Other: 13%; Hispanic or Latinx: 12% | 2014 | NR | ≥4 pills in last week: 92% (106/115) at 3 months, 92% (73/79) at 6 months; 100% adherence in last week: 72% (83/115) at 3 months, 79% (64/81) at 6 months; 100% adherence in last month: 49% (56/115) at 3 months, 56% (44/79) at 6 months | NR | Retained in care 3 months after initial prescription: 73% (124/171) at 3 months, 60% (102/171) at 6 months
CDC Safety Study; Grohskopf, 2013^52^; Oral PrEP | RCT | 373 | MSM; Median age: 38 years; White: 80%; African American: 11%; Asian/Pacific Islander: 5.0%; Other race: 5.0%; Hispanic ethnicity: 8.0% | 2005-2007 | NR | NR | Medication event monitoring system: 79% (range, 60% to 92%); Pill count: 93% (range, 81% to 98%) | Temporary drug discontinuation: 42% (84/201); Overall (TDF + placebo), 17.6% (70/400) had a permanent drug discontinuation
Clement, 2021^191^; Oral PrEP | Treatment series | 271 | PrEP users at two health centers; MSM: 81%; Transgender: 5.2%; Male: 86%; Black: 47%; White: 34%; Hispanic/Latinx: 11% | 2013-2018 | NR | NR | NR | Discontinuation (missed more than 2 quarterly visits with no additional visits by the end of follow-up): 47.2% (128/271); Intermittent care (missed more than 2 quarterly visits, but at least one visit within six months by the end of the study):11.4% (31/271); Continuous care (not discontinuing PrEP and less than 6 months between all visits): 41.3% (112/271)
Coy, 2019^189^; Oral PrEP | Treatment series | 7148 | PrEP users in national pharmacy database; Male: 97%; 18 to 24 years: 11%; 25 to 29 years: 22%; 30 to 39 years: 35%; 40 to 49 years: 20%; 50+ years: 12%; Race/ethnicity: NR | Initiated in 2015 | NR | NR | NR | Persistence (at least 16 days of PrEP filled per 30-day period, for at least three-quarters of a period [9 months of a 12 month period or 18 months of a 24 month period]): 56% (4030/7148) in year 1; 41% (2951/7148) in year 2 (among those persistent in year 1, 63% [2521/4030] persistent in year 2)
Hojilla, 2021^107^; Oral PrEP | Treatment series | 13,906 | Persons linked to PrEP care in an integrated health system; Mean age not reported; 18-25 20%, 26-35 40%, 35-45 21%, >45 20%; Male 95%, female 5%; White: 49%; Latinx: 22%; Asian: 15%; Black: 7% | 2012-2019 | NR | NR | NR | Discontinued (>120 days without PrEP based on pharmacy refill records) at least once: 52.5% (95% CI 48.9% to 55.7%); Discontinued at 2 years: 38.4% (95% CI 37.2% to 39.6%); Reinitiated PreP, among those who discontinued at least once: 60.2% (95% CI 52.2% to 68.3%)
Hosek, 2017^184^; Project PrEPare, ATN 110; Oral PrEP | Treatment series | 200 | MSM; Mean age: 20 years; Latinx: 26%; Non-Latinx Black/African American: 66%; Non-Latinx White: 29% Non-Latinx other race: 5% | 2013 | Dried blood spot samples with TFV-DP level ≥700 fmol/punch; Week 4: 56%; Week 8: 58%; Week 12: 53%; Week 24: 47%; Week 36: 41%; Week 48: 34%; Any TFV-DP level detected: 92% at week 4, 69% at week 48; TFV-DP level ≥350 fmol/punch; Week 4: 78%; Week 8: 77%; Week 12: 72%; Week 24: 57%; week 36: 58%; Week 48: 49% | NR | NR | NR
Hosek, 2017^183^; Project PrEPare, ATN 113; Oral PrEP | Treatment series | 72 | MSM; Mean age: 16 years; White: 14%; Black/African American: 29%; White Hispanic: 21%; Other race/ethnicity: 33% | 2013-2014 | Dried blood spot samples with TFV-DP level ≥700 fmol/punch; Week 4: 54%; Week 8: 47%; Week 12: 49%; Week 24: 28%; Week 36: 17%; Week 48: 22%; TFV-DP level ≥350 fmol/punch; Week 4: 69%; Week 8: 66%; Week 12: 59%; Week 24: 36%; Week 36: 28%; Week 48: 26% | NR | NR | NR
Hosek, 2013^141^; Project PrEPare, ATN 082; Oral PrEP | Double-blind medication pilot RCT with third nonmedication control group | 58 | MSM, ages 18-22 years, at least 2 episodes of unprotected anal sex in past 12 months; Male: 100%; Black: 50% vs. 63% vs. 47%; Other/mixed race: 40% vs. 32% vs. 42%; Hispanic ethnicity: 35% vs. 32% vs. 53%; Unprotected anal sex with a man in past 30 days: 45% vs. 37% vs. 42% | NR | TDF-FTC arm only Proportion of patients with detectable plasma TDF:; Week 4: 63%; Week 24: 20% | TDF-FTC arm only; Mean adherence: 62% (range, 43% to 83%) | NR | NR
Huang, 2021^190^; Oral PrEP | Treatment series | 11,807 | PrEP users in a commercially insured cohort and Medicaid-insured cohort; Median age not reported; Age 25-44 years: 61% (commercial) and 63% (Medicaid); Male: 98% (commercial) and 78% (Medicaid); Black: NR (commercial) and 26% (Medicaid); White: NR (commercial) and 44% (Medicaid) | 2012-2017 | NR | NR | NR | Median persistence (no gap >30 days): 13.7 months (commercial) and 6.8 months (Medicaid); Persisted for 12 months: 54.0% (commercial) and 29.9% (Medicaid)
Krakower, 2019^194^; Oral PrEP | Treatment series | 663 | Patients prescribed PrEP at a health center specializing in healthcare for sexual and gender minorities; Male: 96%; Female: 0.5%; Transgender female or trans-feminine identifying: 3.0%; Transgender male or trans-masculine identifying: 0.6%; White (non-Hispanic): 73%; Black: 6.5%; Asian or Pacific Islander: 3.6%; Hispanic or Latinx: 6.6% | 2014-2015 | NR | NR | NR | Continuous PrEP use (no interruption in PrEP >7 days): 60%; One or more discontinuations (interruption in PrEP >7 days): 36%; Discontinuation without re-initiation: 18%
Landovitz, 2017^186^; PATH-PrEP; Oral PrEP | Treatment series | 301 | MSM and transgender women; Median age: 36 years; White: 50%; Hispanic: 28%; Black: 11%; Asian/Pacific Islander:6%; Other race: 5% | 2013-2016 | Dried bloodspot samples with TFV-DP ≥700 fmol/punch:; Week 4: 83.1%; Week 12: 83.4%; Week 24: 75.7%; Week 36: 71.6%; Week 48: 65.5% | NR | NR | NR
Liu, 2016^177^; The Demo Project; Oral PrEP | Treatment series | 557 | MSM (98%) and transgender women (1.4%); Mean age: 35 years; White: 48%; Latinx: 34%; Black: 7.2%; Asian: 4.7% | 2012-2015 | Dried blood spot samples with TFV-DP level ≥700 fmol/punch; Week 4: 86%; Week 12: 85%; Week 24: 82%; Week 36: 85%; Week 48: 80%; ≥2 dried blood spot samples meeting threshold: 62.5% (170/272); TFV-DP level ≥350 fmol/punch, ≥2 dried blood spot samples meeting threshold: 97% (264/272) | Adherence self-rated “very good” or “excellent” at 87% (1,959/2,242) of visits | Pill count: 81.6%; Medication ratio (number of dispensed pills/the number of days between visits): 85.9% | Interruption in PrEP: 15.1% (84/556); Interruption in PrEP without restarting: 13.1% (73/556)
Montgomery, 2016^185^; Oral PrEP | Treatment series | 50 | MSM (95%); Mean age: 34 years; Non-Hispanic White: 58%; Non-Hispanic Black: 26%; Hispanic or Latinx: 26% Other race: 8% | 2013-2014 | Dried blood spot samples with TFV-DP level ≥700 fmol/punch at mean of 4.4 months: 90% (19/21); TFV-DP level ≥350 fmol/punch: 95% (20/21) | Mean proportion of doses taken in last 7 days, at 3 months: 89% (6.2/7) Mean proportion of doses taken in last 30 days, at 6 months: 89% (26.8/30) | NR | Taking PrEP: 88% (38/43) at 3 months, 82% 31/38) at 6 months
Morgan, 2018^193^; Oral PrEP | Treatment series | 197 | MSM 16 to 29 years of age; Race/ethnicity: Not reported for baseline population | 2015-2017 | NR | NR | NR | Discontinued PrEP: 33.0% (65/197)
Serota, 2020^192^; Oral PrEP | Treatment series | 131 | Non-Hispanic Black; MSM 18 to 29 years of age | 2015-2017 | NR | NR | NR | Discontinuation : 69%; Final discontinuation (discontinuation without restarting): 40%
Van Epps 2018^188^; Oral PrEP | Treatment series | 1,086 | Indication for PrEP NR; Mean age NR; 39% age <35 years; 35% ages 35-49 years; 21% ages 50-64 years; 6% ages 65-79 years; 4% female 22% Black; 67% White; 6% other | 2012-2016 | NR | NR | Median proportion of days/year covered by PrEP prescription: 74% (IQR, 40% to 92%) | Discontinued PrEP in first year (defined as 120-day gap): 44% (364/825)
Zarwell, 2021^195^; Oral PrEP | Treatment series | 294 | Transgender man (80%) or woman (20%); 16 to 26 years: 29%; 27+ years: 71%; Black: 10%; White: 51%; Latinx: 18% | 2017-2018 | NR | NR | NR | Discontinued (among those ever having received PrEP): 49% (25/51)
HIV Prevention Trials Network (HPTN) 067/ADAPT; Grant 2018^136^; Event Driven Versus Daily Oral PrEP | RCT | 179 | MSM (97%), transgender women (2%), gender queer (1%); Mean age NR; 30% ages 18-24 years; 18% ages 25-29 years; 21% ages 30-39 years; 32% age ≥40 years; 70% Black; 13% White; 3% Asian; 3% Native American; 21% other; 25% Hispanic (participants could self-identify in more than one category) | 2012-2014 | TFV-DP ≥326 fmol/punch (consistent with ≥2 doses/week) on visits when sex was reported in the prior week, daily PrEP: 48%; time-driven PrEP: 31%; event-driven PrEP 17% | NR | Medication event monitoring system, daily PrEP: 62%; time-driven PrEP: 47%; event-driven PrEP: 41% Proportion with ≥90% adherence, daily PrEP: 25%; time-based PrEP: 0%; event-driven PrEP: 2% | Temporarily or permanently discontinued PrEP due to side effects: 2.2% (4/179)
DISCOVER; Mayer, 2020^121^; Ogbuagu, 2021^162^; Oral TAF-FTC Versus TDF-FTC | RCT | 5,387 (3,220 U.S.)^*^ | MSM (99%), transgender women who have sex with men (1%); Median age: 34 years; White: 84%; Black: 9%; Asian: 4%; Hispanic or Latinx: 24% | 2016-2017 | TAF-FTC vs. TDF-FTC: TFV-DP DBS level consistent with ≥4 tablets/week: 88%–96% vs. 84%–93%, primary (interim) analysis | TAF-FTC vs. TDF-FTC: 78%–82% vs. 78-82% | TAF-FTC vs. TDF-FTC: Based on pill count, median adherence 98% (IQR 93%–100%) vs. 98% (IQR 93.5% to 100%) | Did not discontinue:78.2% (2107/2694) vs. 79.8% (2150/2693)
HIV Prevention Trials Network (HPTN) 083; Landovitz, 2021^70^; Long-acting Injectable Cabotegravir Versus Daily Oral TDF-FTC | RCT | 4,570 (1,698 U.S.)^*^ | MSM (87%), transgender women who have sex with men (12%); Median age: 26 years; Race/ethnicity (US patients): 50% Black | 2016-2020 | Oral TDF-FTC (random sample); TFV concentration >40 ng/mL: 74.2%; TFV concentration >0.31 ng/mL: 86.0%; TFV-DP in DBS consistent with ≥4 doses/week: 72.3% | NR | Injectable cabotegravir; “Covered” by cabotegravir (injections with delay of <2 weeks): 91.5% of person-years | Did not permanently discontinue: 19.5% (445/2282) vs. 20.3% (463/2284)

* Adherence/persistence is not reported separately for U.S. patients.

Abbreviations: ANCHOR= Anal Cancer/HSIL Outcomes Research; CDC=Centers for Disease Control and Prevention; CI=confidence interval; DBS=dried blood spots; FSM=females who have sex with males; FTC=emtricitabine; HCV=hepatitis C virus; HPTN= HIV Prevention Trials Network; IQR=interquartile range; MSM=men who have sex with men; MSF=men who have sex with females; NR=not reported; OUD=opioid use disorder; PrEP=pre-exposure prophylaxis; RCT=randomized, controlled trial; TAF=tenofovir alafenamide; TVF-DP=tenofovir disoproxil fumarate-diphosphate; TDF-FTC=tenofovir disoproxil fumarate-emtricitabine; U.S.=United States.

Appendix D Table 2 Rates of Antiretroviral Drug Resistance in Patients Taking PrEP

Study; Author, year; Study design; Type of PrEP | PrEP regimen | Resistance mutations among persons with newly diagnosed HIV infection | Resistance mutations among persons randomized to PrEP
Bangkok Tenofovir Study; Choopanya 2013^53^; RCT; Oral PrEP | TDF daily (n=1,204) | TDF vs. placebo^*^; K65R, K70E: 0% (0/17) vs. 0% (0/35) | 0% (0/1204)
FEM-PrEP; Van Damme 2012^172^; RCT; Oral PrEP | TDF-FTC daily (n=1,024) | TDF-FTC vs. placebo^†^; K65R, K70E: 0% (0/33) vs. 0% (0/35); M184V mutation: 9.1% (3/33) vs. 2.9% (1/35); M184I mutation: 3.0% (1/33) vs. 0% (0/35) | 0.4% (4/1024)
Grohskopf, 2013^52^; RCT; Oral PrEP | TDF daily (n=201) | TDF vs. placebo; K65R: 0% (0/0) vs.0% (0/7) | 0% (0/201)
IPERGAY; Molina 2015^66^; RCT; Oral PrEP | TDF-FTC on demand (n=199) | TDF-FTC (n=2) vs. placebo (n=14); No resistance mutations identified | 0% (0/199)
iPrEx; Grant 2010^137^; RCT; Oral PrEP | TDF-FTC daily (n=1,251) | TDF-FTC vs. placebo^‡^; M184V alone: 2.6% (1/38) vs. 0% (0/72); M184I: 2.6% (1/38) vs. 0% (0/72); Multidrug resistance (M184V, T215Y, and K103N): 0% (0/38) vs. 1.4% (1/72) | 0.2% (2/1,251)
Partners PrEP; Baeten 2012^51^; RCT; Oral PrEP | A: TDF daily (n=1,572); B: TDF-FTC daily (n=1,568) | TDF vs. TDF-FTC vs. placebo^§^; K65R: 5.0% (1/20) vs. 0% (0/15) vs. 0% (0/57); K70E: 0% (0/20) vs. 0% (0/15) vs. 0% (0/57); K65N: 5.0% (1/20) vs. 0% (0/15) vs. 0% (0/57); M184I: 0% (0/20) vs. 0% (0/15) vs. 0% (0/57); M184V: 0% (0/20) vs. 6.7% (1/15) vs. 0% (0/57) | 0.1% (3/3,140) overall; 0.1% (2/1,572) TDF; 0.06% (1/1,568) TDF-FTC
PROUD; McCormack, 2016^118^; RCT; Oral PrEP | TDF-FTC daily (n=268) | TDF-FTC vs. deferred PrEP^∥^; K65R or K70G: 0% (0/5) vs. NR; M184I or M184V: 40% (2/5) vs. NR | 0.7% (2/268)
Study of TDF; Peterson 2007^55^; RCT; Oral PrEP | TDF daily (n=427) | TDF vs. placebo^¶^; No drug resistance mutations identified in 1 patient randomized to TDF (no resistance testing performed in 1 other patient randomized to TDF who became infected) | NR
TDF2; Thigpen 2012^170^; RCT; Oral PrEP | TDF-FTC daily (n=601) | TDF-FTC vs. placebo; Multidrug resistance (M184V, K65R, and A62V): 10% (1/10)^#^ vs. 0% (0/26); K65R alone: 0% (0/10) vs. 3.8% (1/26) | 0.2% (1/601)
VOICE; Marrazzo 2015^54^; RCT; Oral PrEP | A: TDF daily (n=172); B: TDF-FTC daily (n=174) | TDF vs. TDF-FTC vs. placebo^**^; K65R: 0% (0/70) vs. 0% (0/71) vs. 0% (0/69); K70E: 0% (0/70) vs. 0% (0/71) vs. 0% (0/69); M184V: 0% (0/70) vs. 4.2% (3/71) vs. 0% (0/69); M184I: 0% (0/70) vs. 1.4% (1/71) vs. 0% (0/69) | 1.2% (4/346) overall; 0% (0/172) TDF; 2.3% (4/174) TDF-FTC
iPrEx-OLE; Grant 2014^198^; Observational; Oral PrEP | TDF-FTC daily (n=1225) | M184V: 3.6% (1/28) | 0.1% (1/1,225)
Hosek 2017^184^; Project PrEPare, ATN 110; Observational; Oral PrEP | TDF-FTC daily (n=200) | Antiretroviral drug resistance (not specified): 0% (0/4) | 0% (0/200)
Hosek 2017^183^; Project PrEPare, ATN 113; Observational; Oral PrEP | TDF-FTC daily (n=78) | Antiretroviral drug resistance to TDF or FTC: 0% (0/3) | 0% (0/78)
Liu 2016^177^; Observational; Oral PrEP | TDF-FTC daily (n=383) | Antiretroviral drug resistance to TDF or FTC: 0% (0/2) | 0% (0/383)
Montgomery 2016^185^; Observational; Oral PrEP | TDF-FTC daily (n=35) | M184V, D67N, T215S, and K219Q: 100% (1/1) | 2.0% (1/50)
ASPIRE; Baeten, 2016^73^; RCT; Dapivirine Vaginal Ring | Dapivirine 25 mg vaginal ring (n=1,313) | NNRTI mutations (HIV-1 acquired after enrollment):; Overall: 12% (8/68); V90I: 2.9% (2/68); E138A: 4.4% (3/68); K101E, K103S, V106M, V108I, E138G, V179D, V179I/T, H221Y: 1.5% each (1/68) | 0.6% (8/1313)
HOPE; Baeten, 2021^112^; (ASPIRE open-label extension); Dapivirine Vaginal Ring | Dapivirine 25 mg vaginal ring (n=731) | NNRTI mutations: 20% (7/35 infections); L103A: 11.4% (4/35); A98G: 2.9% (1/35); G138A: 2.9% (1/35); V179A: 5.7% (2/35); V106M: 2.9% (1/35) | 1.4% (7/731)
Ring Study; Nel, 2016^74^; RCT; Dapivirine Vaginal Ring | A. Dapivirine ring (n=1,307) | Any HIV-1 drug resistance mutation: 39.0% (30/77); NNRTI resistance mutations (E138A, A98G, K103N, K101E, V106M, V090I, V108I, E138Q, Y181C, Y188C, H221Y): 18.2% (14/77); NRTI resistance mutation: 1.3% (1/77); Major PI resistance mutation: 2.6% (2/77); Minor PI resistance mutation: 26.0% (20/77) | Any HIV-1 drug resistance mutation: 2.3% (30/1307); NNRTI resistance mutation: 1.1% (14/1307)
DREAM; Nel, 2021^111^; Ring Study open-label extension; Dapivirine Vaginal Ring | A. Dapivirine ring (n=941) | NNRTI mutations (A98G, G138A, L101G, L103A): 29.4% (5/17); NRTI mutations: 0% (0/17); Major PI mutation: 5.9% (1/17); (Denominator was 17/22 persons with seroconversion with successful population-based HIV-1 genotyping) | 0.5% (5/941)
DISCOVER; Mayer, 2020^121^; Ogbuagu, 2021^162^; Oral TAF-FTC Versus TDF-FTC | A: TAF-FTC (n=2694); B: TDF-FTC (n=2693) | M184: 20% (4/20); all infections occurred in TDF-FTC arm in persons with suspected baseline HIV infection; (Denominator was 20 of 23 patients with HIV infection with successful genotypic resistance testing) | Overall: 0.07% (4/5387); A: TAF-FTC: 0% (0/2694); B: TDF-FTC: 1.5% (4/2693) (all suspected of having infection at baseline)
HPTN 083; Landovitz, 2021^70^; Long-acting Injectable Cabotegravir Versus Daily Oral TDF-FTC | A: Cabotegravir 600 mg in a 3 mL IM injectable every 8 weeks (n=2,282); B: Daily TDF-FTC 300 mg + 200 mg (n=2,284) | A: Cabotegravir (INSTI resistance mutation): 44.4% (4/9) among incident cases in whom resistance testing was available (1/4 cases with baseline infection had INSTI resistance mutation). Q148R (n=3), Q148K (n=1), E138K (n=2), E138A, K103N, L74I, G140A. No infections during the pharmacokinetic “tail” period.; B: TDF-FTC (K65R, M184V, M184I, or a mixture of M184V and M184I with or without NNRTI resistance mutation): 10.3% (4/39) among incident infections (2/3 cases with baseline infection had drug resistance mutation) | A: Cabotegravir (INSTI resistance mutations): 0.2% (4/2282); B: TDF-FTC: 0.2% (4/2284)
HPTN 084; Delany-Moretwle, 2022^88^; Long-acting Injectable Cabotegravir Versus Daily Oral TDF-FTC | A: Cabotegravir 600 mg in a 3 mL IM injectable every 8 weeks (n=1,592); B: Daily TDF-FTC 300 mg + 200 mg (n=1,586) | A: Cabotegravir: INSTI resistance mutations: 0% (0/4 incident infections); B: TDF-FTC: M184V: 2.8% (1/36 infections) and “several” (mainly K103N) resistance mutations occurred | A: Cabotegravir (INSTI resistance mutations): 0% (0/1592); B: TDF-FTC (M184V): 0.06% (1/1586)

* Includes two persons in placebo group who were HIV-infected at enrollment.

† Excludes one person on PrEP and four persons in placebo group who were HIV-infected at enrollment.

‡ Includes 2 persons in TDF-FTC and 8 persons in placebo group who were HIV-infected at enrollment; all cases of resistance occurred in persons who were HIV-infected at enrollment.

§ Includes 5 persons on TDF, 3 persons on FTC-TDF, and 6 persons on placebo who had HIV infection at enrollment; K65R and M184V mutations occurred in persons with HIV infection at randomization.

∥ Includes 2 persons in TDF group who were HIV-infected at enrollment or at 4-week visit; both mutations occurred in both persons.

¶ Includes 1 person in TDF-FTC group and 2 persons in placebo group who were HIV-infected at enrollment.

# HIV-infected at enrollment.

** Includes 5 patients randomized to TDF, 9 patients randomized to TDF-FTC, and 1 patient randomized to placebo who were HIV-infected at time of enrollment; two cases of M184V mutations and 1 case of M184I mutation occurred in persons who were HIV infected at time of enrollment.

Abbreviations: FEM-PrEP=Pre-Exposure Prophylaxis Trial for HIV Prevention Among African Women; FTC=emtricitabine; NR=not reported; IPERGAY=Intervention Préventive de l’Exposition aux Risques Avec et Pour les GAYs; IM=intramuscular; INSTI=integrase-strand transfer inhibitor; iPrEx=Pre-Exposure Prophylaxis Initiative; iPrEx-OLE=Pre-Exposure Prophylaxis Initiative–Open Label Extension; NNRTI=non-nucleoside reverse transcriptase inhibitors; PI=protease inhibitor; PrEP=pre-exposure prophylaxis; PROUD=Pre-Exposure Option for Reducing HIV in the UK: Immediate or Deferred; TAF=tenofovir alafenamid; TDF=tenofovir disoproxil fumarate; TDF2=Tenofovir Disoproxil Fumarate 2 Study; VOICE=Vaginal and Oral Interventions to Control the Epidemic.

Appendix D Table 3 Primary Care Interventions to Increase HIV PrEP Utilization

Author, year | Setting; Country; Recruitment | Study design | Population | Who gave intervention | Intervention | N | Findings
Chan 2021^216^ | STI clinic; US; Recruited at STI clinic | RCT | MSM at risk for HIV (≥10 on HIRI-MSM) | STI clinic counselor | Brief (15-20 min) motivational interviewing intervention followed by <10 min telephone booster session vs. treatment as usual | 86 | Participants in the intervention group vs. the treatment as usual group were significantly more likely to schedule an appointment to further discuss PrEP with a prescriber (OR 6.0, 95% CI 2.3 to 15.6), attend the prescriber appointment (OR 3.6, 95% CI 1.5 to 8.9), and receive and accept a prescription for PrEP (OR 3.6, 95% CI 1.5 to 8.9)
Desrosiers 2019^214^ | Clinic; US; Recruited online via social networking apps | RCT | Young Black MSM | Counselor and physician assistant | PrEP counseling (20-45 mins) and information vs. control (received information only) | 50 | Initiated PrEP by 3 months: 24% (6 people) in the intervention group vs. 0% control, p=0.023
Doblecki-Lewis 2019^217^ | Research site; US; Recruited from hospital outpatient clinics and online via social networking app | RCT | Persons interested in PrEP | Patient navigator | Strengths-based case management (SBCM) intervention (1 45-60 minute session and option to attend 4 additional visits and/or phone/text message contact) vs. passive referral | 61 | Initiated PrEP by 12 weeks: 40% (12 people) in the intervention group vs. 29% (9 people) control, p=0.367; Saw PrEP provider by 12 weeks: 53% (16 people) in the intervention group vs. 33% (10 people) control, p=0.096
Harawa 2020^215^ | Addiction center; US; Recruited via public venues and online | RCT | Black MSM | Various | Passport to Wellness HIV prevention full intervention vs. same intervention lacking peer support; 1) all participants received a customized wellness plan (or Passport) that included referrals to health and support services and incentives for accessing those services; 2) all participants were awarded incentives for providing documentation of completed Passport activities; 3) participants assigned to the Peer Mentor (PM) intervention arm were also paired with a trained Peer who provided support, encouragement, and navigation; and 4) individuals assigned to this arm were also given the opportunity to attend social/education group outings | 80 | Use of PrEP in the prior 6 months: Increased from 0% to 22% for participants in the full intervention arm vs. from 0% to 9% for participants in the non-peer mentor arm, p=ns
Meyer 2021^218^; OPTIONS study | Addiction treatment center; US; Recruited at addiction treatment center | Non-randomized study | Women with substance use disorders in addiction treatment | Researcher | Patient-centered PrEP decision aid vs. enhanced standard care | 164 | Likely to see a provider for PrEP: 15.7% intervention group vs. 6.2% control; p=0.05
Teixeria da Silva 2021^213^ | Clinics; US; Recruited from STI clinics and social networking apps | RCT | Black MSM and Black transgender women | Social work interventionist | Partner Services PrEP, a brief information-motivation-behavioral skills model intervention (60 mins plus up to 4 booster sessions) vs. usual services | 146 | Initiated PrEP within 3 months (EMR data): 20% (14 people) intervention group vs. 11% (7 people) control, p=0.15; Initiated PrEP within 12 months (EMR data): 37% (24 people) intervention group vs. 27% (17 people) control, p=0.25; Initiated PrEP within 3 months (self-report data): 24% (16 people) intervention group vs. 11% (7 people) control, p=0.05; Days to PrEP linkage within 12 months (EMR data): 27 days intervention group vs. 192 days control, p=0.05; Linked to PrEP within 3 months (EMR data): 24% (17 people) intervention group vs. 11% (7 people) control, p=0.04

Abbreviations: CI=confidence interval; EMR=electronic medical record; HIRI-MSM= HIV Incidence Risk Index for men who have sex with men; MSM=men who have sex with men; ns=not significant; OR=odds ratio; PM=peer mentor; PrEP=pre-exposure prophylaxis; RCT=randomized, controlled trial; SBCM=strengths-based case management; STI=sexually transmitted infection; U.S.=United States.