# Appendix A Detailed Methods

## Appendix A1 Search Strategies

### Database: Ovid MEDLINE(R) ALL

1 exp Pre-Exposure Prophylaxis/
2 ("preexposure prophylaxis" or prep or tenofovir or truvada or descovy or biktarvy or cabotegravir or dapivirine).ti,ab,kf.
3 Anti-HIV Agents/
4 (hiv or "human immunodeficiency virus").ti,ab,kf.
5 (1 or 2) and (3 or 4)
6 limit 5 to yr="2018 -Current"
7 limit 6 to english language
8 (random* or control* or trial).ti,ab,kf.
9 7 and 8
10 limit 7 to (clinical trial or comparative study or meta analysis or randomized controlled trial or "systematic review")
11 9 or 10
12 exp "Sensitivity and Specificity"/
13 (sensitivity or specificity or "AUROC" or "ROC").ti,ab,kf.
14 (risk adj2 (predict* or accura*)).ti,ab,kf.
15 (diagnos* adj2 accura*).ti,ab,kf.
16 12 or 13 or 14 or 15
17 7 and 16
18 11 or 17

### Database: EBM Reviews - Cochrane Central Register of Controlled Trials

1 "pre-exposure prophylaxis".ti,ab.
2 (prep or tenofovir or truvada or descovy or biktarvy or cabotegravir or dapivirine).ti,ab.
3 Anti-HIV Agents/
4 (hiv or "human immunodeficiency virus").ti,ab.
5 (1 or 2) and (3 or 4)
6 exp "Sensitivity and Specificity"/
7 (sensitivity or specificity or "AUROC" or "ROC").ti,ab.
8 (risk adj2 (predict* or accura*)).ti,ab.
9 (diagnos* adj2 accura*).ti,ab.
10 6 or 7 or 8 or 9
11 (random* or control* or trial).ti,ab.
12 limit 5 to (comparative study or meta analysis or randomized controlled trial)
13 5 and 11
14 12 or 13
15 5 and 10
16 13 or 14 or 15
17 limit 16 to english language
18 conference abstract.pt.
19 "journal: conference abstract".pt.
20 "journal: conference review".pt.
21 "http://.www.who.int/trialsearch* (http://www.who.int/trialsearch*)".so.
22 "https://clinicaltrials.gov*".so.
23 18 or 19 or 20 or 21 or 22
24 17 not 23
25 limit 24 to yr="2018 -Current"

### Database: EBM Reviews - Cochrane Database of Systematic Reviews >

1 "pre-exposure prophylaxis".ti,ab.
2 (prep or tenofovir or truvada or descovy or biktarvy or cabotegravir or dapivirine).ti,ab.
3 (hiv or "human immunodeficiency virus").ti,ab.
4 (1 or 2) and 3
5 (2018$ or 2019$ or 2020$ or 2021$).up.
6 4 and 5

### Database: Elsevier Embase

'pre-exposure prophylaxis'/exp OR 'pre-exposure prophylaxis' AND 'human immunodeficiency virus'/exp AND [embase]/lim NOT [medline]/lim AND ('article'/it OR 'article in press'/it OR 'conference paper'/it OR 'conference review'/it OR 'editorial'/it OR 'letter'/it OR 'review'/it OR 'short survey'/it)

## Appendix A2 Inclusion and Exclusion Criteria

| Included | Excluded
Populations | Adolescents who weigh more than35 kg (ages 13 to <18 years) and adults (age ≥18 years) without pre-existing HIV infection at increased risk of HIV acquisition^*^; Patient populations of interest defined by age, sex, gender identity, race/ethnicity, HIV risk category | Persons living with HIV, children
Interventions | KQs 1, 2, 4, 5:; Daily oral TDF-FTC or TDF; Daily oral TAF-FTC; Alternate dosing regimens (event-driven or intermittent dosing); Injectable cabotegravir; Dapivirine vaginal ring; KQ 3: Provider or patient risk assessment tools | Other PrEP regimens
Comparisons | KQs 1, 4: Placebo or no PrEP (including deferred PrEP); KQs 2, 5: TDF-FTC (for TAF-FTC or cabotegravir); KQ 3: Reference standard for HIV infection
Outcomes | KQs 1, 2, 4, 5:; Risk of HIV acquisition, quality of life, risk of other sexually transmitted infections, risk of hepatitis B and C virus infections, renal insufficiency, fracture, and pregnancy-related outcomes; for KQ 2, lipid parameters and weight gain; KQ 3: Diagnostic accuracy measures | Outcomes not listed, including condom use
Setting | Settings in which PrEP is delivered in ways applicable to U.S. primary care settings | Inpatient settings
Study design | KQs 1, 2: Randomized controlled trials for benefits and harms; controlled observational studies for harms^†^ if randomized controlled trials are not available; KQ 3: Diagnostic accuracy studies; KQs 4, 5: Randomized, controlled trials; controlled observational studies for harms^†^ if randomized controlled trials are not available

* Including pregnant and breastfeeding women.

† Study must perform statistical adjustment for potential confounders to be included.

Abbreviations: FTC=emtricitabine; KQ=key question; PrEP=pre-exposure prophylaxis; TAF=tenofovir alafenamide; TDF=tenofovir disoproxil fumarate; U.S.=United States.

## Appendix A3 Literature Flow Diagram

*The sum of the number of studies per key question (KQ) exceeds the total number of studies because some studies were applicable to multiple KQs.

Appendix A3 is a literature flow diagram depicting the search and selection of articles for the review. The diagram shows that 2,576 citations were identified through literature database searches and other sources. Two hundred and eight articles were reviewed at the full-text level after excluding 2,368 citations based on review of titles and abstracts. One hundred and forty seven full-text articles were excluded for the following reasons: wrong population (12), wrong intervention (10), wrong outcome (15), wrong comparator (7), wrong study design for key question (43), not a study (17), systematic review or meta-analysis used as a source document only to identify individual studies (9), wrong country (2), poor quality (3), wrong publication type (29). Thirty-two studies (in 61 publications) were included that provided evidence for the KQs (new studies were 6 trials, 3 publications to prior report studies, and 5 diagnostic accuracy studies [in 16 publications], and studies carried forward from the prior report were 12 trials and 7 diagnostic accuracy studies [in 45 publications]). For KQ1, there were 3 new oral PrEP publications to prior trials and 2 new dapivirine trials (in 3 publications), and 12 prior report trials of oral PrEP (in 15 publications) were carried forward. For KQ1a, there was 1 new publication to a prior oral PrEP trial and 2 new dapivirine trials (in 3 publications), and 12 oral PrEP trials (in 17 publications) were carried forward. For KQ1b, 1 new trial compared regimens, and 12 oral PrEP trials (in 14 publications) and 1 trial (in 2 publications) comparing regimens were carried forward. For KQ2, there was 1 new TAF trial (in 2 publications) and 2 new cabotegravir trials (in 2 publications). For KQ3, there were 5 new diagnostic accuracy studies (in 5 publications), and 7 prior report studies (in 7 publications) were carried forward. For KQ4, there was 1 new oral PrEP publication to a prior report trials, and 2 new dapivirine trials (in 2 publications), and 1 new trial (in 1 publication) compared regimens; 12 oral PrEP trials (in 24 publications) were carried forward. For KQ5, there was 1 new TAF trial (in 2 publications) and 2 new cabotegravir trials (in 2 publications).

## Appendix A4 Included Studies List

*New studies/publications.

1 Agot K, Taylor D, Corneli AL, Accuracy of self-report and pill-count measures of adherence in the FEM-PrEP clinical trial: implications for future HIV-prevention trials. AIDS Behav. 2015 May;19(5):743–51. doi: 10.1007/s10461-014-0859-z. PMID: 25100053.25100053
2* Antoni G, Tremblay C, Delaugerre C, On-demand pre-exposure prophylaxis with tenofovir disoproxil fumarate plus emtricitabine among men who have sex with men with less frequent sexual intercourse: a post-hoc analysis of the ANRS IPERGAY trial. Lancet HIV. 2020 02;7(2):e113–e20. doi: 10.1016/S2352-3018(19)30341-8. PMID: 31784343.31784343
3 Baeten JM, Donnell D, Ndase P, Antiretroviral prophylaxis for HIV-1 prevention in heterosexual men and women. N Engl J Med. 2012 Aug 2;367(5):399–410. doi: 10.1056/NEJMoa1108524. PMID: 22784037.22784037
4* Baeten JM, Palanee-Phillips T, Brown ER, Use of a vaginal ring containing dapivirine for HIV-1 prevention in women. N Engl J Med. 2016 Dec;375(22):2121–32. doi: 10.1056/NEJMoa1506110. PMID: 26900902.26900902
5 Bekker LG, Roux S, Sebastien E, Daily and non-daily pre-exposure prophylaxis in African women (HPTN 067/ADAPT Cape Town trial): a randomised, open-label, phase 2 trial. Lancet HIV. 2018 02;5(2):e68–e78. doi: 10.1016/S2352-3018(17)30156-X. PMID: 28986029.28986029
6 Beymer MR, Weiss RE, Sugar CA, Are Centers for Disease Control and Prevention guidelines for preexposure prophylaxis specific enough? Formulation of a personalized HIV risk score for pre-exposure prophylaxis initiation. Sex Transm Dis. 2017 Jan;44(1):48–56. doi: 10.1097/olq.0000000000000535. PMID: 27898570.27898570
7 Celum C, Morrow RA, Donnell D, Daily oral tenofovir and emtricitabine-tenofovir preexposure prophylaxis reduces herpes simplex virus type 2 acquisition among heterosexual HIV-1-uninfected men and women: a subgroup analysis of a randomized trial. Ann Intern Med. 2014 Jul 1;161(1):11–9. doi: 10.7326/M13-2471. PMID: 24979446.24979446
8* Chaix ML, Charreau I, Pintado C, Effect of on-demand oral preexposure prophylaxis with tenofovir/emtricitabine on herpes simplex virus-1/2 incidence among men who have sex with men: A substudy of the ANRS IPERGAY trial. Open Forum Infect Dis. 2018;5(11)doi: 10.1093/ofid/ofy295. PMID: 30539039.30539039
9 Chirwa LI, Johnson JA, Niska RW, CD4(+) cell count, viral load, and drug resistance patterns among heterosexual breakthrough HIV infections in a study of oral preexposure prophylaxis. AIDS. 2014 Jan 14;28(2):223–6. doi: 10.1097/QAD.0000000000000102. PMID: 24361682.24361682
10 Choopanya K, Martin M, Suntharasamai P, Antiretroviral prophylaxis for HIV infection in injecting drug users in Bangkok, Thailand (the Bangkok tenofovir study): a randomised, double-blind, placebo-controlled phase 3 trial. Lancet. 2013 Jun 15;381(9883):2083–90. doi: 10.1016/S0140-6736(13)61127-7. PMID: 23769234.23769234
11* Delany-Moretlwe S, Hughes JP, Bock P, Cabotegravir for the prevention of HIV-1 in women: results from HPTN 084, a phase 3, randomised clinical trial. Lancet. 2022 Apr 1doi: 10.1016/s0140-6736(22)00538-4. PMID: 35378077.35378077
12 Deutsch MB, Glidden DV, Sevelius J, HIV pre-exposure prophylaxis in transgender women: a subgroup analysis of the iPrEx trial. Lancet HIV. 2015 Dec;2(12):e512–9. doi: 10.1016/S2352-3018(15)00206-4. PMID: 26614965.26614965
13 Donnell D, Baeten JM, Bumpus NN, HIV protective efficacy and correlates of tenofovir blood concentrations in a clinical trial of PrEP for HIV prevention. J Acquir Immune Defic Syndr. 2014 Jul 1;66(3):340–8. doi: 10.1097/QAI.0000000000000172. PMID: 24784763.24784763
14 Grant RM, Mannheimer S, Hughes JP, Daily and nondaily oral preexposure prophylaxis in men and transgender women who have sex with men: The Human Immunodeficiency Virus Prevention Trials Network 067/ADAPT study. Clin Infect Dis. 2018 May 17;66(11):1712–21. doi: 10.1093/cid/cix1086. PMID: 29420695.29420695
15 Grant RM, Lama JR, Anderson PL, Preexposure chemoprophylaxis for HIV prevention in men who have sex with men. N Engl J Med. 2010 Dec 30;363(27):2587–99. doi: 10.1056/NEJMoa1011205. PMID: 21091279.21091279
16 Grohskopf LA, Chillag KL, Gvetadze R, Randomized trial of clinical safety of daily oral tenofovir disoproxil fumarate among HIV-uninfected men who have sex with men in the United States. J Acquir Immune Defic Syndr. 2013 Sep 1;64(1):79–86. doi: 10.1097/QAI.0b013e31828ece33. PMID: 23466649.23466649
17 Haberer JE, Baeten JM, Campbell J, Adherence to antiretroviral prophylaxis for HIV prevention: a substudy cohort within a clinical trial of serodiscordant couples in East Africa. PLoS Med. 2013;10(9):e1001511. doi: 10.1371/journal.pmed.1001511. PMID: 24058300.24058300
18 Heffron R, Mugo N, Were E, Preexposure prophylaxis is efficacious for HIV-1 prevention among women using depot medroxyprogesterone acetate for contraception. AIDS. 2014 Nov 28;28(18):2771–6. doi: 10.1097/QAD.0000000000000493. PMID: 25493602.25493602
19 Hoenigl M, Weibel N, Mehta SR, Development and validation of the San Diego early test score to predict acute and early HIV infection risk in men who have sex with men. Clin Infect Dis. 2015 Aug 1;61(3):468–75. doi: 10.1093/cid/civ335. PMID: 25904374.25904374
20 Hosek SG, Siberry G, Bell M, The acceptability and feasibility of an HIV preexposure prophylaxis (PrEP) trial with young men who have sex with men. J Acquir Immune Defic Syndr. 2013 Apr 01;62(4):447–56. doi: 10.1097/QAI.0b013e3182801081. PMID: 24135734.24135734
21 Jones J, Hoenigl M, Siegler AJ, Assessing the performance of 3 human immunodeficiency virus incidence risk scores in a cohort of black and white men who have sex with men in the South. Sex Transm Dis. 2017 May;44(5):297–302. doi: 10.1097/OLQ.0000000000000596. PMID: 28407646.28407646
22 Kibengo FM, Ruzagira E, Katende D, Safety, adherence and acceptability of intermittent tenofovir/emtricitabine as HIV pre-exposure prophylaxis (PrEP) among HIV-uninfected Ugandan volunteers living in HIV-serodiscordant relationships: a randomized, clinical trial. PLoS One. 2013;8(9):e74314. doi: 10.1371/journal.pone.0074314. PMID: 24086333.24086333
23* Krakower DS, Gruber S, Hsu K, Development and validation of an automated HIV prediction algorithm to identify candidates for pre-exposure prophylaxis: a modelling study. Lancet HIV. 2019 10;6(10):e696–e704. doi: 10.1016/S2352-3018(19)30139-0. PMID: 31285182.31285182
24* Kwan TH, Lui GC Y, Lam TT N, Comparison between daily and on-demand PrEP (pre-exposure prophylaxis) regimen in covering condomless anal intercourse for men who have sex with men in Hong Kong: A randomized, controlled, open-label, crossover trial. J Int AIDS Soc. 2021 09;24(9):e25795. doi: 10.1002/jia2.25795. PMID: 34473402.34473402
25 Lancki N, Almirol E, Alon L, Preexposure prophylaxis guidelines have low sensitivity for identifying seroconverters in a sample of young Black MSM in Chicago. AIDS. 2018 Jan 28;32(3):383–92. doi: 10.1097/qad.0000000000001710. PMID: 29194116.29194116
26* Landovitz RJ, Donnell D, Clement ME, Cabotegravir for HIV prevention in cisgender men and transgender women. N Engl J Med. 2021 08 12;385(7):595–608. doi: 10.1056/NEJMoa2101016. PMID: 34379922.34379922
27 Lehman DA, Baeten JM, McCoy CO, Risk of drug resistance among persons acquiring HIV within a randomized clinical trial of single- or dual-agent preexposure prophylaxis. J Infect Dis. 2015 Apr 15;211(8):1211–8. doi: 10.1093/infdis/jiu677. PMID: 25587020.25587020
28 Liu A, Glidden DV, Anderson PL, Patterns and correlates of PrEP drug detection among MSM and transgender women in the Global iPrEx Study. J Acquir Immune Defic Syndr. 2014 Dec 15;67(5):528–37. doi: 10.1097/QAI.0000000000000351. PMID: 25230290.25230290
29 Liu AY, Vittinghoff E, Sellmeyer DE, Bone mineral density in HIV-negative men participating in a tenofovir preexposure prophylaxis randomized clinical trial in San Francisco. PLoS One. 2011;6(8):e23688. doi: 10.1371/journal.pone.0023688. PMID: 21897852.21897852
30 Mandala J, Nanda K, Wang M, Liver and renal safety of tenofovir disoproxil fumarate in combination with emtricitabine among African women in a pre-exposure prophylaxis trial. BMC Pharmacol Toxicol. 2014;15:77. doi: 10.1186/2050-6511-15-77. PMID: 25539648.25539648
31 Marcus JL, Glidden DV, McMahan V, Daily oral emtricitabine/tenofovir preexposure prophylaxis and herpes simplex virus type 2 among men who have sex with men. PLoS One. 2014;9(3):e91513. doi: 10.1371/journal.pone.0091513. PMID: 24637511.24637511
32* Marcus JL, Hurley LB, Krakower DS, Use of electronic health record data and machine learning to identify candidates for HIV pre-exposure prophylaxis: a modelling study. Lancet HIV. 2019 10;6(10):e688–e95. doi:10.1016/S2352-3018(19)30137-7. PMID: 31285183.31285183
33 Marrazzo JM, Ramjee G, Richardson BA, Tenofovir-based preexposure prophylaxis for HIV infection among African women. N Engl J Med. 2015 Feb 5;372(6):509–18. doi: 10.1056/NEJMoa1402269. PMID: 25651245.25651245
34 Martin M, Vanichseni S, Suntharasamai P, Renal function of participants in the Bangkok tenofovir study--Thailand, 2005-2012. Clin Infect Dis. 2014 Sep 1;59(5):716–24. doi: 10.1093/cid/ciu355. PMID: 24829212.24829212
35 Martin M, Vanichseni S, Suntharasamai P, The impact of adherence to preexposure prophylaxis on the risk of HIV infection among people who inject drugs. AIDS. 2015 Apr 24;29(7):819–24. doi: 10.1097/QAD.0000000000000613. PMID: 25985403.25985403
36 Matthews LT, Heffron R, Mugo NR, High medication adherence during periconception periods among HIV-1-uninfected women participating in a clinical trial of antiretroviral pre-exposure prophylaxis. J Acquir Immune Defic Syndr. 2014 Sep 1;67(1):91–7. doi: 10.1097/QAI.0000000000000246. PMID: 25118795.25118795
37* Mayer KH, Molina JM, Thompson MA, Emtricitabine and tenofovir alafenamide vs emtricitabine and tenofovir disoproxil fumarate for HIV pre-exposure prophylaxis (DISCOVER): primary results from a randomised, double-blind, multicentre, active-controlled, phase 3, non-inferiority trial. Lancet. 2020 07 25;396(10246):239–54. doi: 10.1016/S0140-6736(20)31065-5. PMID: 32711800.32711800
38 McCormack S, Dunn DT, Desai M, Pre-exposure prophylaxis to prevent the acquisition of HIV-1 infection (PROUD): effectiveness results from the pilot phase of a pragmatic open-label randomised trial. Lancet. 2016 Jan 2;387(10013):53–60. doi: 10.1016/S0140-6736(15)00056-2. PMID: 26364263.26364263
39 Menza TW, Hughes JP, Celum CL, Prediction of HIV acquisition among men who have sex with men. Sex Transm Dis. 2009 Sep;36(9):547–55. doi: 10.1097/OLQ.0b013e3181a9cc41. PMID: 19707108.19707108
40 Mirembe BG, Kelly CW, Mgodi N, Bone mineral density changes among young, healthy African women receiving oral tenofovir for HIV preexposure prophylaxis. J Acquir Immune Defic Syndr. 2016 Mar 1;71(3):287–94. doi: 10.1097/QAI.0000000000000858. PMID: 26866954.26866954
41 Molina JM, Capitant C, Spire B, On-demand preexposure prophylaxis in men at high risk for HIV-1 Infection. N Engl J Med. 2015 Dec 3;373(23):2237–46. doi: 10.1056/NEJMoa1506273. PMID: 26624850.26624850
42 Mugo NR, Hong T, Celum C, Pregnancy incidence and outcomes among women receiving preexposure prophylaxis for HIV prevention: a randomized clinical trial. JAMA. 2014 Jul 23-30;312(4):362–71. doi: 10.1001/jama.2014.8735. PMID: 25038355.25038355
43 Mugwanya KK, Wyatt C, Celum C, Changes in glomerular kidney function among HIV-1-uninfected men and women receiving emtricitabine-tenofovir disoproxil fumarate preexposure prophylaxis: a randomized clinical trial. JAMA Intern Med. 2015 Feb;175(2):246–54. doi: 10.1001/jamainternmed.2014.6786. PMID: 25531343.25531343
44 Mulligan K, Glidden DV, Anderson PL, Effects of emtricitabine/tenofovir on bone mineral density in HIV-negative persons in a randomized, double-blind, placebo-controlled trial. Clin Infect Dis. 2015 Aug 15;61(4):572–80. doi: 10.1093/cid/civ324. PMID: 25908682.25908682
45 Murnane PM, Brown ER, Donnell D, Estimating efficacy in a randomized trial with product nonadherence: application of multiple methods to a trial of preexposure prophylaxis for HIV prevention. Am J Epidemiol. 2015 Nov 15;182(10):848–56. doi: 10.1093/aje/kwv202. PMID: 26487343.26487343
46 Murnane PM, Celum C, Mugo N, Efficacy of preexposure prophylaxis for HIV-1 prevention among high-risk heterosexuals: subgroup analyses from a randomized trial. AIDS. 2013 Aug 24;27(13):2155–60. doi: 10.1097/QAD.0b013e3283629037. PMID: 24384592.24384592
47 Mutua G, Sanders E, Mugo P, Safety and adherence to intermittent pre-exposure prophylaxis (PrEP) for HIV-1 in African men who have sex with men and female sex workers. PLoS One. 2012;7(4):e33103. doi: 10.1371/journal.pone.0033103. PMID: 22511916.22511916
48* Nel A, van Niekerk N, Kapiga S, Safety and efficacy of a dapivirine vaginal ring for HIV prevention in women. N Engl J Med. 2016;375(22):2133–43. doi: 10.1056/NEJMoa1602046. PMID: 27959766.27959766
49* Ogbuagu O, Ruane PJ, Podzamczer D, Long-term safety and efficacy of emtricitabine and tenofovir alafenamide vs emtricitabine and tenofovir disoproxil fumarate for HIV-1 pre-exposure prophylaxis: week 96 results from a randomised, double-blind, placebo-controlled, phase 3 trial. Lancet HIV. 2021 07;8(7):e397–e407. doi: 10.1016/S2352-3018(21)00071-0. PMID: 34197772.34197772
50* Peebles K, van der Straten A, Palanee-Phillips T, Brief report: anal intercourse, HIV-1 risk, and efficacy in a trial of a dapivirine vaginal ring for HIV-1 prevention. J Acquir Immune Defic Syndr. 2020 03 01;83(3):197–201. doi: 10.1097/QAI.0000000000002253. PMID: 31809308.31809308
51 Peterson L, Taylor D, Roddy R, Tenofovir disoproxil fumarate for prevention of HIV infection in women: a phase 2, double-blind, randomized, placebo-controlled trial. PLoS Clin Trials. 2007;2(5):e27. doi: 10.1371/journal.pctr.0020027. PMID: 17525796.17525796
52* Ridgway JP, Friedman EE, Bender A, Evaluation of an electronic algorithm for identifying cisgender female preexposure prophylaxis candidates. AIDS Patient Care STDs. 2021 01;35(1):5–8. doi: 10.1089/apc.2020.0231. PMID: 33400588.33400588
53* Scott H, Vittinghoff E, Irvin R, Development and validation of the personalized Sexual Health Promotion (SexPro) HIV risk prediction model for men who have sex with men in the United States. AIDS Behav. 2020 Jan;24(1):274–83. doi: 10.1007/s10461-019-02616-3. PMID: 31352633.31352633
54 Smith DK, Pals SL, Herbst JH, Development of a clinical screening index predictive of incident HIV infection among men who have sex with men in the United States. J Acquir Immune Defic Syndr. 2012 Aug 1;60(4):421–7. doi: 10.1097/QAI.0b013e318256b2f6. PMID: 22487585.22487585
55 Smith DK, Pan Y, Rose CE, A brief screening tool to assess the risk of contracting HIV infection among active injection drug users. J Addict Med. 2015 May-Jun;9(3):226–32. doi: 10.1097/ADM.0000000000000123. PMID: 25961495.25961495
56 Solomon MM, Lama JR, Glidden DV, Changes in renal function associated with oral emtricitabine/tenofovir disoproxil fumarate use for HIV pre-exposure prophylaxis. AIDS. 2014 Mar 27;28(6):851–9. doi: 10.1097/QAD.0000000000000156. PMID: 24499951.24499951
57* Solomon MM, Schechter M, Liu AY, The safety of Tenofovir-Emtricitabine for HIV pre-exposure prophylaxis (PrEP) in individuals with active Hepatitis B. J Acquir Immune Defic Syndr. 2016 Mar 1;71(3):281–6. doi: 10.1097/qai.0000000000000857. PMID: 26413853.26413853
58 Thigpen MC, Kebaabetswe PM, Paxton LA, Antiretroviral preexposure prophylaxis for heterosexual HIV transmission in Botswana. N Engl J Med. 2012 Aug 2;367(5):423–34. doi: 10.1056/NEJMoa1110711. PMID: 22784038.22784038
59* Tordoff DM, Barbee LA, Khosropour CM, Derivation and validation of an HIV risk prediction score among gay, bisexual, and other men who have sex with men to inform PrEP initiation in an STD clinic setting. J Acquir Immune Defic Syndr. 2020 11 01;85(3):263–71. doi: 10.1097/QAI.0000000000002438. PMID: 32658131.32658131
60 Van Damme L, Corneli A, Ahmed K, Preexposure prophylaxis for HIV infection among African women. N Engl J Med. 2012 Aug 2;367(5):411–22. doi: 10.1056/NEJMoa1202614. PMID: 22784040.22784040
61 Were EO, Heffron R, Mugo NR, Pre-exposure prophylaxis does not affect the fertility of HIV-1-uninfected men. AIDS. 2014 Aug 24;28(13):1977–82. doi: 10.1097/QAD.0000000000000313. PMID: 25259704.25259704

## Appendix A5 Excluded Studies List

1 Apretude (cabotegravir extended-release injectable suspension). Highlights of Prescribing INformation. 2021. https://gskpro.com/content/dam/global/hcpportal/en_US/Prescribing_Information/Apretude/pdf/APRETUDE-PI-PIL-IFU.PDF. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
2 Abdool Karim Q, Abdool Karim SS, Frohlich JA, Effectiveness and safety of tenofovir gel, an antiretroviral microbicide, for the prevention of HIV infection in women. Science. 2010 Sep 03;329(5996):1168–74. doi: 10.1126/science.1193748. PMID: 20643915. Exclusion: Ineligible intervention20643915
3 Anderson PL, Glidden DV, Liu A, Emtricitabine-tenofovir concentrations and pre-exposure prophylaxis efficacy in men who have sex with men. Sci Transl Med. 2012 Sep 12;4(151):1–8. PMID: 22972843. Exclusion: Ineligible outcome22972843
4 Antoni G. On-demand PrEP with TDF/FTC remains highly effective among MSM with infrequent sexual intercourse: a sub-study of the ANRS IPERGAY trial. 2017. http://programme.ias2017.org/Abstract/Abstract/3629. Accessed January 3, 2018. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
5 Ascher SB, Scherzer R, Estrella MM, HIV preexposure prophylaxis with tenofovir disoproxil fumarate/emtricitabine and changes in kidney function and tubular health. AIDS. 2020 04 01;34(5):699–706. doi: 10.1097/QAD.0000000000002456. PMID: 31794523. Exclusion: Ineligible study design for Key Question31794523
6 Baeten J, Palanee-Phillips T, Mgodi N, High uptake and reduced HIV-1 incidence in an open-label trial of the dapivirine ring. Top Antivir Med. 2018;26:61s. Exclusion: Wrong publication type (e.g., abstract only)
7 Baeten JM, Palanee-Phillips T, Mgodi N, High adherence and sustained impact on HIV-1 incidence: Final results of an open-label extension trial of the dapivirine vaginal ring. Journal of the International AIDS Society. 2019;22doi: 10.1002/jia2.25327. Exclusion: Wrong publication type (e.g., abstract only)
8 Baeten JM, Palanee-Phillips T, Mgodi NM, Safety, uptake, and use of a dapivirine vaginal ring for HIV-1 prevention in African women (HOPE): an open-label, extension study. Lancet HIV. 2021 Feb;8(2):e87–e95. doi: 10.1016/s2352-3018(20)30304-0. PMID: 33539762. Exclusion: Ineligible study design for Key Question33539762
9 Baker Z, Javanbakht M, Moore J, Qualitative Study on the Acceptability of and Adherence to a Vaginal Ring for HIV Prophylaxis Among Adolescent Girls. J Acquir Immune Defic Syndr. 2021 07 01;87(3):944–50. doi: 10.1097/QAI.0000000000002674. PMID: 33675614. Exclusion: Ineligible outcome33675614
10 Balkus JE, Brown E, Palanee T, An empiric HIV risk scoring tool to predict HIV-1 acquisition in African women. J Acquir Immune Defic Syndr. 2016 Jul 1;72(3):333–43. doi: 10.1097/QAI.0000000000000974. PMID: 26918545. Exclusion: Poor quality26918545
11 Balkus JE, Brown ER, Palanee-Phillips T, Performance of a Validated Risk Score to Predict HIV-1 Acquisition Among African Women Participating in a Trial of the Dapivirine Vaginal Ring. J Acquir Immune Defic Syndr. 2018 01 01;77(1):e8–e10. doi: 10.1097/QAI.0000000000001556. PMID: 28961677. Exclusion: Ineligible population28961677
12 Baranek B, Wang S, Cheung AM, The effect of tenofovir disoproxil fumarate on bone mineral density: a systematic review and meta-analysis. Antivir Ther. 2020;25(1):21–32. doi: 10.3851/IMP3346. PMID: 32077867. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies32077867
13 Bauer R, Netzer E, Pintado C, Coverage of Sex Acts by Event-Driven Pre-exposure Prophylaxis: A Sub-Study of the ANRS IPERGAY Trial. AIDS Behav. 2020 Nov;24(11):3244–51. doi: 10.1007/s10461-020-02890-6. PMID: 32350771. Exclusion: Ineligible outcome32350771
14 Baum MM, Butkyavichene I, Churchman SA, An intravaginal ring for the sustained delivery of tenofovir disoproxil fumarate. Int J Pharm. 2015 Nov 10;495(1):579–87. doi: 10.1016/j.ijpharm.2015.09.028. PMID: 26386138. Exclusion: Ineligible intervention26386138
15 Bertoni M, Kennard B, Murrell D, The effect of tenofovir alafenamide or tenofovir disoproxil fumarate on renal function of HIV-infected patients. JACCP J Am Coll Clin Pharm.. 2020;3(8):1592–3. doi: 10.1002/jac5.1351. Exclusion: Wrong publication type (e.g., abstract only)
16 Blumenthal J, Jain S, He F, Results from a prep demonstration project for at-risk cisgender women in the us. Top Antivir Med. 2020;28(1):391–2. Exclusion: Wrong publication type (e.g., abstract only)
17 Brown ER, Hendrix CW, van der Straten A, Greater dapivirine release from the dapivirine vaginal ring is correlated with lower risk of HIV-1 acquisition: a secondary analysis from a randomized, placebo-controlled trial. J Int AIDS Soc.. 2020 11;23(11):e25634. doi: 10.1002/jia2.25634. PMID: 33206462. Exclusion: Ineligible intervention33206462
18 Bunge KE, Levy L, Szydlo DW, Brief Report: Phase IIa Safety Study of a Vaginal Ring Containing Dapivirine in Adolescent Young Women. J Acquir Immune Defic Syndr. 2020 02 01;83(2):135–9. doi: 10.1097/QAI.0000000000002244. PMID: 31929401. Exclusion: Ineligible population31929401
19 Campbell T, Clarke A, Trottier B, Safety and efficacy of F/TAF and F/TDF for prep in discover participants taking F/TDF for prep at baseline. Open Forum Infect. 2020;7(SUPPL 1):S526–S7. doi: 10.1093/ofid/ofaa439.1182. Exclusion: Wrong publication type (e.g., abstract only)
20 Castillo-Mancilla JR, Searls K, Caraway P, Short communication: Tenofovir diphosphate in dried blood spots as an objective measure of adherence in HIV-infected women. AIDS Res Hum Retroviruses. 2015 Apr;31(4):428–32. doi: 10.1089/aid.2014.0229. PMID: 25328112. Exclusion: Ineligible population25328112
21 Centers for Disease Control and Prevention. HIV Risk Reduction Tool. https://hivrisk.cdc.gov/. Accessed December 3, 2021. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
22 Centers for Disease Control and Prevention, US Public Health Service. Preexposure prophylaxis for the prevention of HIV infection in the United States—2017 Update: a clinical practice guideline.https://www.cdc.gov/hiv/pdf/risk/prep/cdc-hiv-prep-guidelines-2017.pdf. 2017 Published March 2018. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
23 Centers for Disease Control and Prevention, US Public Health Service. Preexposure prophylaxis for the prevention of HIV infection in the United States—2021 Update: a clinical practice guideline. https://www.cdc.gov/hiv/pdf/risk/prep/cdc-hiv-prep-guidelines-2021.pdf. 2021. Published December 2021. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
24 Centers for Disease Control and Prevention, US Public Health Service. Preexposure prophylaxis for the prevention of HIV infection in the United States—2021 Update: clinical provider's supplement. https://www.cdc.gov/hiv/pdf/risk/prep/cdc-hiv-prep-provider-supplement-2021.pdf.; 2021. Accessed May 9 2022. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
25 Chan PA, Mena L, Patel R, Retention in care outcomes for HIV pre-exposure prophylaxis implementation programmes among men who have sex with men in three US cities. J Int AIDS Soc. 2016;19(1):20903. doi: 10.7448/IAS.19.1.20903. PMID: 27302837. Exclusion: Ineligible study design for Key Question27302837
26 Chan PA, Patel RR, Mena L, Long-term retention in pre-exposure prophylaxis care among men who have sex with men and transgender women in the United States. J Int AIDS Soc. 2019 08;22(8):e25385. doi: 10.1002/jia2.25385. PMID: 31423756. Exclusion: Ineligible study design for Key Question31423756
27 Chen BA, Zhang J, Gundacker HM, Phase 2a Safety, Pharmacokinetics, and Acceptability of Dapivirine Vaginal Rings in US Postmenopausal Women. Clin Infect Dis. 2019 03 19;68(7):1144–51. doi: 10.1093/cid/ciy654. PMID: 30289485. Exclusion: Ineligible population30289485
28 Trials Clinical. Randomized, Open Label Safety Trial of Dapivirine Vaginal Ring and Oral TRUVADA^®^ Use in Pregnancy. 2021. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
29 Cohen MS, Chen YQ, McCauley M, Prevention of HIV-1 infection with early antiretroviral therapy. N Engl J Med. 2011 Aug 11;365(6):493–505. doi: 10.1056/NEJMoa1105243. PMID: 21767103. Exclusion: Ineligible intervention21767103
30 Cohen SE, Vittinghoff E, Bacon O, High interest in preexposure prophylaxis among men who have sex with men at risk for HIV infection: baseline data from the US PrEP demonstration project. J Acquir Immune Defic Syndr. 2015 Apr 1;68(4):439–48. doi: 10.1097/QAI.0000000000000479. PMID: 25501614. Exclusion: Ineligible study design for Key Question25501614
31 Costello C, Mobley T, Arnold S, 244. Retrospective Review of High-Risk Adolescents Eligible for Pre-Exposure Prophylaxis (Prep) Therapy For HIV. J Adolesc Health. 2020;66(2):S123–S4. doi: 10.1016/j.jadohealth.2019.11.247. Exclusion: Wrong publication type (e.g., abstract only)
32 Cotte L, Veyer D, Charreau I, Prevalence and Incidence of Human Papillomavirus Infection in Men Having Sex With Men Enrolled in a Pre-exposure Prophylaxis Study: A Sub-study of the Agence Nationale de Recherches sur le SIDA et les Hepatites Virales "Intervention Preventive de l'Exposition aux Risques avec et pour les hommes Gays" Trial. Clin Infect Dis. 2021 01 23;72(1):41–9. doi: 10.1093/cid/ciaa002. PMID: 31907521. Exclusion: Ineligible study design for Key Question31907521
33 Council OD, Ruone S, Mock PA, HIV-1 genetic diversity to estimate time of infection and infer adherence to preexposure prophylaxis. AIDS. 2019 12 01;33(15):2299–307. doi: 10.1097/QAD.0000000000002390. PMID: 31764095. Exclusion: Ineligible outcome31764095
34 Cox S, Parikh U, Heaps A, Ultrasensitive HIV-1 drug-resistance analysis in the discover prep trial. Top Antivir Med. 2021;29(1):154. Exclusion: Wrong publication type (e.g., abstract only)
35 Coyer L, Prins M, Davidovich U, Trends in Sexual Behavior and Sexually Transmitted Infections After Initiating Human Immunodeficiency Virus Pre-Exposure Prophylaxis in Men Who Have Sex with Men from Amsterdam, the Netherlands: A Longitudinal Exposure-Matched Study. AIDS Patient Care STDS. 2022 Jun;36(6):208–18. doi: 10.1089/apc.2021.0219. PMID: 35687814. Exclusion: Ineligible study design for Key Question35687814
36 Cranston RD, Brown E, Bauermeister J, A Randomized, Double Blind, Placebo-Controlled, Phase 1 Safety and Pharmacokinetic Study of Dapivirine Gel (0.05%) Administered Rectally to HIV-1 Seronegative Adults (MTN-026). AIDS Res Hum Retroviruses. 2021 Sep 09;09:09. doi: 10.1089/AID.2021.0071. PMID: 34498980. Exclusion: Ineligible intervention34498980
37 Curley CM, Rosen AO, Mistler CB, Pleasure and PrEP: A Systematic Review of Studies Examining Pleasure, Sexual Satisfaction, and PrEP. J Sex Res. 2022 Sep;59(7):848–61. doi: 10.1080/00224499.2021.2012638. PMID: 35089110. Exclusion: Ineligible study design for Key Question35089110
38 De Baetselier I, Tsoumanis A, Florence E, Did Pre-exposure Prophylaxis Roll-Out Influence the Epidemic of Rectal Lymphogranuloma Venereum in Belgium? Results From the National Surveillance System. J Acquir Immune Defic Syndr. 2021 01 01;86(1):e1–e5. doi: 10.1097/QAI.0000000000002524. PMID: 33044320. Exclusion: Ineligible study design for Key Question33044320
39 Delany-Moretlwe S, Hughes J, Bock P, Long acting injectable cabotegravir is safe and effective in preventing HIV infection in cisgender women: Interim results from HPTN 084. J Int AIDS Soc. 2021;24(SUPPL 1):8. doi: 10.1002/jia2.25659. Exclusion: Wrong publication type (e.g., abstract only)
40 Delany-Moretlwe S, Lombard C, Baron D, Tenofovir 1% vaginal gel for prevention of HIV-1 infection in women in South Africa (FACTS-001): a phase 3, randomised, double-blind, placebo-controlled trial. Lancet Infect Dis. 2018 11;18(11):1241–50. doi: 10.1016/S1473-3099(18)30428-6. PMID: 30507409. Exclusion: Ineligible intervention30507409
41 Di Ciaccio M, Sagaon-Teyssier L, Mimi M, Changes in Sexual Behaviors in Men Who Have Sex with Men: A Comparison Between the Double-Blind and Open-Label Extension Phases of the ANRS-IPERGAY Trial. AIDS Behav. 2020 Nov;24(11):3093–106. doi: 10.1007/s10461-020-02864-8. PMID: 32306213. Exclusion: Ineligible outcome32306213
42 Djomand G, Bingham T, Benech I, Expansion of HIV Preexposure Prophylaxis to 35 PEPFAR-Supported Early Program Adopters, October 2016-September 2018. MMWR. 2020 Feb 28;69(8):212–5. doi: 10.15585/mmwr.mm6908a3. PMID: 32107367. Exclusion: Wrong publication type (e.g., abstract only)32107367
43 Doblecki-Lewis S, Dosekun O, Ramgopal M, Drug levels, adherence, and risks for low adherence in the discover prep study. Top Antivir Med. 2020;28(1):388. Exclusion: Wrong publication type (e.g., abstract only)
44 Drak D, McManus H, Vickers T, Renal impairment in a large-scale HIV preexposure prophylaxis implementation cohort. AIDS. 2021 Nov 15;35(14):2319–26. doi: 10.1097/QAD.0000000000003035. PMID: 34310371. Exclusion: Ineligible study design for Key Question34310371
45 Duthe JC, Bouzille G, Sylvestre E, How to Identify Potential Candidates for HIV Pre-Exposure Prophylaxis: An AI Algorithm Reusing Real-World Hospital Data. Stud Health Technol Inform. 2021 May 27;281:714–8. doi: 10.3233/SHTI210265. PMID: 34042669. Exclusion: Ineligible outcome34042669
46 E OM, Marshall L, Teljeur C, Oral pre-exposure prophylaxis (PrEP) to prevent HIV: a systematic review and meta-analysis of clinical effectiveness, safety, adherence and risk compensation in all populations. BMJ Open. 2022 May 11;12(5):e048478. doi: 10.1136/bmjopen-2020-048478. PMID: 35545381. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies35545381
47 Fonner VA, Dalglish SL, Kennedy CE, Effectiveness and safety of oral HIV preexposure prophylaxis for all populations. AIDS. 2016 Jul 31;30(12):1973–83. doi: 10.1097/QAD.0000000000001145. PMID: 27149090. Exclusion: Ineligible country27149090
48 Fredericksen RJ, Mayer KH, Gibbons LE, Development and Content Validation of a Patient-Reported Sexual Risk Measure for Use in Primary Care. J Gen Intern Med. 2018 Oct;33(10):1661–8. doi: 10.1007/s11606-018-4496-5. PMID: 29845470. Exclusion: Ineligible study design for Key Question29845470
49 Freeborn K, Portillo CJ. Does pre-exposure prophylaxis for HIV prevention in men who have sex with men change risk behaviour? A systematic review. J Clin Nurs. 2018 Sep;27(17-18):3254–65. doi: 10.1111/jocn.13990. PMID: 28771856. Exclusion: Ineligible outcome28771856
50 Gamarel KE, Chakravarty D, Neilands TB, Composite Risk for HIV: A New Approach Towards Integrating Biomedical and Behavioral Strategies in Couples-Based HIV Prevention Research. Aids Behav. 2019 Jan;23(1):283–8. doi: 10.1007/s10461-018-2229-8. PMID: 30003506. Exclusion: Ineligible study design for Key Question30003506
51 Gati Mirembe B, Cabrera MV, Cobbing M, Correlates of dapivirine vaginal ring uptake among women participating in an open label extension trial-MTN-025/ HOPE. J Int AIDS Soc. 2021;24(SUPPL 1):89. doi: 10.1002/jia2.25659. Exclusion: Wrong publication type (e.g., abstract only)
52 Gauthier TP, Toro M, Carrasquillo MZ, A PrEP Model Incorporating Clinical Pharmacist Encounters and Antimicrobial Stewardship Program Oversight May Improve Retention in Care. Clin Infect Dis. 2019 Jan 7;68(2):347–9. doi: 10.1093/cid/ciy640. PMID: 30107390. Exclusion: Wrong publication type (e.g., abstract only)30107390
53 Giguere K, Behanzin L, Guedou FA, PrEP Use Among Female Sex Workers: No Evidence for Risk Compensation. J Acquir Immune Defic Syndr. 2019 11 01;82(3):257–64. doi: 10.1097/QAI.0000000000002134. PMID: 31356468. Exclusion: Ineligible study design for Key Question31356468
54 Giler RM, Bush S, Hawkins T, Impact of prep and TASP on incidence of HIV diagnoses in 48 highest-burden us areas. Top Antivir Med. 2020;28(1):429. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
55 Gill K, Johnson L, Dietrich J, Acceptability, safety, and patterns of use of oral tenofovir disoproxil fumarate and emtricitabine for HIV pre-exposure prophylaxis in South African adolescents: an open-label single-arm phase 2 trial. Lancet Child Adolesc Health. 2020 12;4(12):875–83. doi: 10.1016/S2352-4642(20)30248-0. PMID: 33222803. Exclusion: Ineligible population33222803
56 Giovenco D, Pettifor A, MacPhail C, Assessing risk for HIV infection among adolescent girls in South Africa: an evaluation of the VOICE risk score (HPTN 068). J Int AIDS Soc. 2019 07;22(7):e25359. doi: 10.1002/jia2.25359. PMID: 31353814. Exclusion: Ineligible population31353814
57 Glidden DV, Amico KR, Liu AY, Symptoms, side effects and adherence in the iPrEx open-label extension. Clin Infect Dis. 2016 May 1;62(9):1172–7. doi: 10.1093/cid/ciw022. PMID: 26797207. Exclusion: Ineligible study design for Key Question26797207
58 Glidden DV, Mulligan K, McMahan V, Metabolic Effects of Preexposure Prophylaxis With Coformulated Tenofovir Disoproxil Fumarate and Emtricitabine. Clin Infect Dis. 2018 07 18;67(3):411–9. doi: 10.1093/cid/ciy083. PMID: 29415175. Exclusion: Ineligible outcome29415175
59 Grant RM, Anderson PL, McMahan V, Uptake of pre-exposure prophylaxis, sexual practices, and HIV incidence in men and transgender women who have sex with men: a cohort study. Lancet Infect Dis. 2014 Sep;14(9):820–9. doi: 10.1016/S1473-3099(14)70847-3. PMID: 25065857. Exclusion: Ineligible study design for Key Question25065857
60 Gruber S, Krakower D, Menchaca JT, Using electronic health records to identify candidates for human immunodeficiency virus pre-exposure prophylaxis: An application of super learning to risk prediction when the outcome is rare. Stat Med. 2020 10 15;39(23):3059–73. doi: 10.1002/sim.8591. PMID: 32578905. Exclusion: Ineligible study design for Key Question32578905
61 Gulick RM, Wilkin TJ, Chen YQ, Phase 2 study of the safety and tolerability of maraviroc-containing regimens to prevent HIV Infection in men who have sex with men (HPTN 069/ACTG A5305). J Infect Dis. 2017 Jan 15;215(2):238–46. doi: 10.1093/infdis/jiw525. PMID: 27811319. Exclusion: Ineligible intervention27811319
62 H. I. V. Prevention Trials Network. Evaluating the Safety and Efficacy of Long-Acting Injectable Cabotegravir Compared to Daily Oral TDF/FTC for Pre-Exposure Prophylaxis in HIV-Uninfected Women. 2021. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
63 H. I. V. Prevention Trials Network. Safety, Tolerability and Acceptability of Long-Acting Cabotegravir (CAB LA) for the Prevention of HIV Among Adolescent Males - A Sub-study of HPTN 083. 2021. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
64 Haberer JE, Mugo N, Baeten JM, PrEP as a Lifestyle and Investment for Adolescent Girls and Young Women in Sub-Saharan Africa. J Int Assoc Provid AIDS Care. 2019 Jan-Dec;18:2325958219831011. doi: 10.1177/2325958219831011. PMID: 30776954. Exclusion: Wrong publication type (e.g., abstract only)30776954
65 Haukoos JS, White DA E, Rowan SE, Development of a 2-step algorithm to identify emergency department patients for HIV pre-exposure prophylaxis. Am J Emerg Med. 2021 Oct 06;51:6–12. doi: 10.1016/j.ajem.2021.09.084. PMID: 34649008. Exclusion: Ineligible comparator34649008
66 Hebel S, Kahn-Woods E, Enghuus C, Disparities in prep uptake and adherence among cisgender women using a pharmacologic measure. Open Forum Infect. 2020;7(SUPPL 1):S517–S8. doi: 10.1093/ofid/ofaa439.1166. Exclusion: Wrong publication type (e.g., abstract only)
67 Heffron R, Mugo N, Hong T, Pregnancy outcomes and infant growth among babies with in-utero exposure to tenofovir-based preexposure prophylaxis for HIV prevention. AIDS. 2018 07;32(12):1707–13. doi: 10.1097/QAD.0000000000001867. PMID: 30001244. Exclusion: Ineligible study design for Key Question30001244
68 Hill S, Clark J, Simpson T, Identifying missed opportunities for HIV pre-exposure prophylaxis at an adolescent health center in the deep south. J Adolesc Health. 2018;62(2):S38. Exclusion: Wrong publication type (e.g., abstract only)
69 Hoornenborg E, Coyer L, Achterbergh RC A, Sexual behaviour and incidence of HIV and sexually transmitted infections among men who have sex with men using daily and event-driven pre-exposure prophylaxis in AMPrEP: 2 year results from a demonstration study. Lancet HIV. 2019 Jul;6(7):e447–e55. doi: 10.1016/s2352-3018(19)30136-5. PMID: 31178284. Exclusion: Ineligible study design for Key Question31178284
70 Hoornenborg E, Coyer L, Boyd A, High incidence of HCV in HIV-negative men who have sex with men using pre-exposure prophylaxis. J Hepatol. 2020 05;72(5):855–64. doi: 10.1016/j.jhep.2019.11.022. PMID: 31862485. Exclusion: Ineligible study design for Key Question31862485
71 Hosek SG, Landovitz RJ, Kapogiannis B, Safety and feasibility of antiretroviral preexposure prophylaxis for adolescent men who have sex with men aged 15 to 17 years in the United States. JAMA Pediatr. 2017 Sep 05doi: 10.1001/jamapediatrics.2017.2007. PMID: 28873128. Exclusion: Ineligible study design for Key Question28873128
72 Hosek SG, Rudy B, Landovitz R, An HIV preexposure prophylaxis demonstration project and safety study for young MSM. J Acquir Immune Defic Syndr. 2017 Jan 01;74(1):21–9. doi: 10.1097/qai.0000000000001179. PMID: 27632233. Exclusion: Ineligible study design for Key Question27632233
73 Hoth AB, Shafer C, Dillon DB, Iowa TelePrEP: A Public-Health-Partnered Telehealth Model for Human Immunodeficiency Virus Preexposure Prophylaxis Delivery in a Rural State. Sex Transm Dis. 2019;46(8):507–12. PMID: 31295217. Exclusion: Ineligible comparator31295217
74 Huang X, Hou J, Song A, Efficacy and safety of oral TDF-based pre-exposure prophylaxis for men who have sex with men: a systematic review and meta-analysis. Front Pharmacol. 2018;9:799. doi: 10.3389/fphar.2018.00799. PMID: 30233355. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies30233355
75 Huhn GD, Wilkin A, Mussini C, Week 96 subgroup analyses of the phase 3, randomized AMBER and EMERALD trials evaluating the efficacy and safety of the once daily darunavir/cobicistat/emtricitabine/tenofovir alafenamide (D/C/F/TAF) single-tablet regimen in antiretroviral treatment (ART)-naive and -experienced, virologically-suppressed adults living with HIV-1. HIV Res Clin Pract. 2020 Dec;21(6):151–67. doi: 10.1080/25787489.2020.1844520. PMID: 33528318. Exclusion: Ineligible intervention33528318
76 Irungu E, Mugwanya K, Mugo N, Integrating oral pre-exposure prophylaxis services to public HIV care clinics in Kenya: Results from a pragmatic stepped-wedge randomized trial. J Int AIDS Soc. 2021;24(SUPPL 1):138–9. doi: 10.1002/jia2.25659. Exclusion: Wrong publication type (e.g., abstract only)
77 Joseph Davey DL, Pintye J, Baeten JM, Emerging evidence from a systematic review of safety of pre-exposure prophylaxis for pregnant and postpartum women: where are we now and where are we heading? J Int AIDS Soc. 2020 01;23(1):e25426. doi: 10.1002/jia2.25426. PMID: 31912985. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies31912985
78 Kahle EM, Hughes JP, Lingappa JR, An empiric risk scoring tool for identifying high-risk heterosexual HIV-1-serodiscordant couples for targeted HIV-1 prevention. J Acquir Immune Defic Syndr. 2013 Mar 1;62(3):339–47. doi: 10.1097/QAI.0b013e31827e622d. PMID: 23187945. Exclusion: Poor quality23187945
79 Kamis K, Scott K, Gardner E, Same-day HIV pre-exposure prophylaxis (PrEP) initiation during drop-in std clinic appointments is a safe, feasible, and effective method to engage patients at risk for HIV in PrEP care. Open Forum Infect. 2018;5:S20. doi: 10.1093/ofid/ofy209.044. Exclusion: Wrong publication type (e.g., abstract only)
80 Kapadia SN, Wu C, Mayer KH, No change in health-related quality of life for at-risk U.S. women and men starting HIV pre-exposure prophylaxis (PrEP): Findings from HPTN 069/ACTG A5305. PLoS ONE [Electronic Resource]. 2018;13(12):e0206577. doi: 10.1371/journal.pone.0206577. PMID: 30586364. Exclusion: Ineligible comparator30586364
81 Keen P, Hammoud MA, Bourne A, Use of HIV Pre-exposure Prophylaxis (PrEP) Associated With Lower HIV Anxiety Among Gay and Bisexual Men in Australia Who Are at High Risk of HIV Infection: Results From the Flux Study. J Acquir Immune Defic Syndr. 2020 Feb 1;83(2):119–25. doi: 10.1097/qai.0000000000002232. PMID: 31935203. Exclusion: Ineligible study design for Key Question31935203
82 Keller MJ, Wood L, Billingsley JM, Tenofovir disoproxil fumarate intravaginal ring for HIV pre-exposure prophylaxis in sexually active women: a phase 1, single-blind, randomised, controlled trial. Lancet HIV. 2019 08;6(8):e498–e508. doi: 10.1016/S2352-3018(19)30145-6. PMID: 31320290. Exclusion: Ineligible intervention31320290
83 Koester K, Amico RK, Gilmore H, Risk, safety and sex among male PrEP users: time for a new understanding. Cult Health Sex. 2017 Dec;19(12):1301–13. doi: 10.1080/13691058.2017.1310927. PMID: 28415911. Exclusion: Ineligible study design for Key Question28415911
84 Kuo I, Olsen H, Patrick R, Willingness to use HIV pre-exposure prophylaxis among community-recruited, older people who inject drugs in Washington, DC. Drug Alcohol Depend. 2016 Jul 1;164:8–13. doi: 10.1016/j.drugalcdep.2016.02.044. PMID: 27177804. Exclusion: Ineligible outcome27177804
85 Kusemererwa S, Abaasa A, Kabarambi A, Assessment of risk compensation following use of the dapivirine vaginal ring in southwestern Uganda. Sex Transm Infect. 2021 Feb 04;04:04. doi: 10.1136/sextrans-2020-054718. PMID: 33542153. Exclusion: Ineligible study design for Key Question33542153
86 Lambert DN, Swartzendruber A. 69. Knowledge, Attitudes, and Willingness to Use Pre-Exposure Hiv Prophylaxis (PrEP) Among an Online Recruited Sample of Sexually Active Adolescent Substance Users in Southern HIV Hotspots. J Adolesc Health. 2021;68(2):S37–S8. doi: 10.1016/j.jadohealth.2020.12.078. Exclusion: Wrong publication type (e.g., abstract only)
87 Landovitz RJ, Beymer M, Kofron R, Plasma tenofovir levels to support adherence to TDF/FTC preexposure prophylaxis for HIV prevention in MSM in Los Angeles, California. J Acquir Immune Defic Syndr. 2017 Dec 15;76(5):501–11. doi: 10.1097/QAI.0000000000001538. PMID: 28902074. Exclusion: Ineligible study design for Key Question28902074
88 Landovitz RJ, Li S, Eron JJ Jr., Tail-phase safety, tolerability, and pharmacokinetics of long-acting injectable cabotegravir in HIV-uninfected adults: a secondary analysis of the HPTN 077 trial. Lancet HIV. 2020 07;7(7):e472–e81. doi: 10.1016/S2352-3018(20)30106-5. PMID: 32497491. Exclusion: Ineligible population32497491
89 Landovitz RJ, Li S, Grinsztejn B, Safety, tolerability, and pharmacokinetics of long-acting injectable cabotegravir in low-risk HIV-uninfected individuals: HPTN 077, a phase 2a randomized controlled trial. PLoS Med. 2018 11;15(11):e1002690. doi: 10.1371/journal.pmed.1002690. PMID: 30408115. Exclusion: Ineligible population30408115
90 Landovitz RJ, Zangeneh SZ, Chau G, Cabotegravir Is Not Associated With Weight Gain in Human Immunodeficiency Virus-uninfected Individuals in HPTN 077. Clin Infect Dis. 2020 01 02;70(2):319–22. doi: 10.1093/cid/ciz439. PMID: 31125395. Exclusion: Ineligible population31125395
91 Lazarus G, Wangsaputra VK, Christianto, Safety and pharmacokinetic profiles of long-acting injectable antiretroviral drugs for HIV-1 pre-exposure prophylaxis: a systematic review and meta-analysis of randomized trials. Front Pharmacol. 2021;12:664875. doi: 10.3389/fphar.2021.664875. PMID: 34305587. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies34305587
92 Liegeon G, Antoni G, Pialoux G, Changes in kidney function among men having sex with men starting on demand tenofovir disoproxil fumarate - emtricitabine for HIV pre-exposure prophylaxis. Journal of the International AIDS Soc. 2020 02;23(2):e25420. doi: 10.1002/jia2.25420. PMID: 32086878. Exclusion: Ineligible outcome32086878
93 Liu AY, Cohen SE, Vittinghoff E, Preexposure prophylaxis for HIV infection integrated with municipal- and community-based sexual health services. JAMA Intern Med. 2016 Jan;176(1):75–84. doi: 10.1001/jamainternmed.2015.4683. PMID: 26571482. Exclusion: Ineligible study design for Key Question26571482
94 Liu AY, Dominguez Islas C, Gundacker H, Phase 1 pharmacokinetics and safety study of extended duration dapivirine vaginal rings in the United States. J Int AIDS Soc. 2021 06;24(6):e25747. doi: 10.1002/jia2.25747. PMID: 34118115. Exclusion: Ineligible comparator34118115
95 Marcus JL, Levine K, Grasso C, HIV Preexposure Prophylaxis as a Gateway to Primary Care. Am J Public Health. 2018 Oct;108(10):1418–20. doi: 10.2105/ajph.2018.304561. PMID: 30024802. Exclusion: Ineligible study design for Key Question30024802
96 Markowitz M, Frank I, Grant RM, Safety and tolerability of long-acting cabotegravir injections in HIV-uninfected men (ECLAIR): a multicentre, double-blind, randomised, placebo-controlled, phase 2a trial. Lancet HIV. 2017 Aug;4(8):e331-e40. doi: 10.1016/s2352-3018(17)30068-1. PMID: 28546090. Exclusion: Ineligible population28546090
97 Martin M, Vanichseni S, Suntharasamai P, Factors associated with the uptake of and adherence to HIV pre-exposure prophylaxis in people who have injected drugs: an observational, open-label extension of the Bangkok Tenofovir Study. Lancet HIV. 2017 Feb;4(2):e59–e66. doi: 10.1016/s2352-3018(16)30207-7. PMID: 27866873. Exclusion: Ineligible study design for Key Question27866873
98 Marzinke M, Grinsztejn B, Fogel J, Laboratory analysis of HIV infections in HPTN 083: Injectable cab for prep. Top Antivir Med. 2021;29(1):45–6. Exclusion: Wrong publication type (e.g., abstract only)
99 McManus H, Grulich AE, Amin J, Comparison of Trends in Rates of Sexually Transmitted Infections Before vs After Initiation of HIV Preexposure Prophylaxis Among Men Who Have Sex With Men. JAMA Netw Open. 2020 Dec 1;3(12):e2030806. doi: 10.1001/jamanetworkopen.2020.30806. PMID: 33355675. Exclusion: Ineligible study design for Key Question33355675
100 Mizushima D, Takano M, Uemura H, Prophylactic effect of PrEP against HBV infection among MSM. Top Antivir Med. 2020;28(1):386–7. Exclusion: Wrong publication type (e.g., abstract only)
101 Montaño MA, Dombrowski JC, Dasgupta S, Changes in Sexual Behavior and STI Diagnoses Among MSM Initiating PrEP in a Clinic Setting. AIDS Behav. 2019 Feb;23(2):548–55. doi: 10.1007/s10461-018-2252-9. PMID: 30117076. Exclusion: Ineligible study design for Key Question30117076
102 Montgomery MC, Oldenburg CE, Nunn AS, Adherence to pre-exposure prophylaxis for HIV prevention in a clinical setting. PLoS One. 2016;11(6):e0157742. doi: 10.1371/journal.pone.0157742. PMID: 27333000. Exclusion: Ineligible study design for Key Question27333000
103 Moyer VA U. S. Preventive Services Task Force. Screening for HIV: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013 Jul 2;159(1):51–60. PMID: 23698354. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)23698354
104 Murewanhema G, Malisheni M, Takah NF. The effectiveness of tenofovir-based pre-exposure prophylaxis for prevention of HIV acquisition among sub-Saharan African women at high risk: a systematic review. Pan Afr Med J. 2021;38:308. doi: 10.11604/pamj.2021.38.308.26014. PMID: 34178226. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies34178226
105 Murray MI, Markowitz M, Frank I, Satisfaction and acceptability of cabotegravir long-acting injectable suspension for prevention of HIV: Patient perspectives from the ECLAIR trial. HIV Clin Trial. 2018 08;19(4):129–38. doi: 10.1080/15284336.2018.1511346. PMID: 30445896. Exclusion: Ineligible population30445896
106 Musekiwa A, Fernando NB, Abariga SA. Effectiveness of vaginal microbicides in preventing HIV transmission. Trop Med Int Health. 2020 07;25(7):790–802. doi: 10.1111/tmi.13401. PMID: 32306503. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies32306503
107 National Institute of Allergy and Infectious Diseases. Evaluating the Safety and Efficacy of Long-Acting Injectable Cabotegravir Compared to Daily Oral TDF/FTC for Pre-Exposure Prophylaxis in HIV-Uninfected Women. clinicaltrials.gov; 2017. https://clinicaltrials.gov/ct2/show/NCT03164564. Accessed February 2, 2018. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
108 Nel A, van Niekerk N, Van Baelen B, Safety, adherence, and HIV-1 seroconversion among women using the dapivirine vaginal ring (DREAM): an open-label, extension study. Lancet HIV. 2021 Feb;8(2):e77–e86. doi: 10.1016/s2352-3018(20)30300-3. PMID: 33539761. Exclusion: Ineligible study design for Key Question33539761
109 Nel A, Van Niekerk N, Van Baelen B, HIV incidence and adherence in dream: An open-label trial of dapivirine vaginal ring. Top Antivir Med. 2018;26:61s. Exclusion: Wrong publication type (e.g., abstract only)
110 Network HIVPT. A phase 3 double blind safety and efficacy study of long-acting injectable cabotegravir compared to daily oral TDF/FTC for pre-exposure prophylaxis in HIV-uninfected women. 2020. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
111 Ngure K, Thuo N, Ogello V, Dynamic Perceived HIV Risk and Sexual Behaviors Among Young Women Enrolled in a PrEP Trial in Kenya: A Qualitative Study. Front Reprod Health. 2021;3:637869. doi: 10.3389/frph.2021.637869. PMID: 36304002. Exclusion: Ineligible outcome36304002
112 Nguyen AC, Young LE, Beymer MR, Developing targeted HIV risk predictors for young black men who have sex with men: a two-city comparative study. Int J STD AIDS. 2020 03;31(4):335–44. doi: 10.1177/0956462419886472. PMID: 32089091. Exclusion: Ineligible study design for Key Question32089091
113 Nguyen VK, Greenwald ZR, Trottier H, Incidence of sexually transmitted infections before and after preexposure prophylaxis for HIV. AIDS. 2018 02 20;32(4):523–30. doi: 10.1097/QAD.0000000000001718. PMID: 29239887. Exclusion: Ineligible comparator29239887
114 Nickolas TL, Barasch J, Mugwanya KK, Kidney injury biomarkers during exposure to tenofovir-based preexposure prophylaxis. AIDS. 2021 06 01;35(7):1147–9. doi: 10.1097/QAD.0000000000002865. PMID: 33710023. Exclusion: Wrong publication type (e.g., abstract only)33710023
115 Nickolas TL, Yin MT, Hong T, Impact of Tenofovir-Based Pre-exposure Prophylaxis on Biomarkers of Bone Formation, Bone Resorption, and Bone Mineral Metabolism in HIV-Negative Adults. Open Forum Infect. 2019 Oct;6(10):ofz338. doi: 10.1093/ofid/ofz338. PMID: 31660332. Exclusion: Ineligible outcome31660332
116 Obiero J, Ogongo P, Mwethera PG, Topical microbicides for preventing sexually transmitted infections. Cochrane Database Syst Rev. 2021 03 13;3:CD007961. doi: 10.1002/14651858.CD007961.pub3. PMID: 33719075. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies33719075
117 Ogbuagu O, Podzamczer D, Salazar LC, Longer-term safety of F/TAF and F/TDF for HIV PrEP: Discover trial week-96 results. Top Antivir Med. 2020;28(1):31–2. Exclusion: Wrong publication type (e.g., abstract only)
118 Ong JJ, Baggaley RC, Wi TE, Global epidemiologic characteristics of sexually transmitted infections among individuals using preexposure prophylaxis for the prevention of HIV infection: a systematic review and meta-analysis. JAMA Netw Open. 2019 12 02;2(12):e1917134. doi: 10.1001/jamanetworkopen.2019.17134. PMID: 31825501. Exclusion: Ineligible outcome31825501
119 Parsons JT, Rendina HJ, Lassiter JM, Uptake of HIV pre-exposure prophylaxis (PrEP) in a national cohort of gay and bisexual men in the United States: The motivational PrEP cascade. J Acquir Immune Defic Syndr. 2017:285–92. doi: 10.1097/QAI.0000000000001251. PMID: 28187084. Exclusion: Ineligible outcome28187084
120 Pilkington V, Hill A, Hughes S, How safe is TDF/FTC as PrEP? A systematic review and meta-analysis of the risk of adverse events in 13 randomised trials of PrEP. J Virus Erad. 2018 Oct 01;4(4):215–24. PMID: 30515300. Exclusion: Systematic review or meta-analysis used as source document only to identify individual studies30515300
121 Pilkington V, Hughes SL, Pepperrell T, Tenofovir alafenamide vs. tenofovir disoproxil fumarate: an updated meta-analysis of 14 894 patients across 14 trials. AIDS. 2020 12 01;34(15):2259–68. doi: 10.1097/QAD.0000000000002699. PMID: 33048869. Exclusion: Ineligible intervention33048869
122 Pintye J, Drake AL, Kinuthia J, A risk assessment tool for identifying pregnant and postpartum women who may benefit from preexposure prophylaxis. Clin Infect Dis. 2017 Mar 15;64(6):751–8. doi: 10.1093/cid/ciw850. PMID: 28034882. Exclusion: Poor quality28034882
123 Post F, Spinner C, Coll P, DISCOVER in Europe: A sub-analysis of the phase 3 randomized, controlled trial of daily emtricitabine/tenofovir alafenamide (F/TAF) or emtricitabine/tenofovir disoproxil fumarate (F/TDF) for HIV pre-exposure prophylaxis (PrEP). HIV Med. 2019;20:243–4. doi: 10.1111/hiv.12815. Exclusion: Wrong publication type (e.g., abstract only)
124 Quinn KG, Christenson E, Sawkin MT, The Unanticipated Benefits of PrEP for Young Black Gay, Bisexual, and Other Men Who Have Sex with Men. AIDS Behav. 2020 May;24(5):1376–88. doi: 10.1007/s10461-019-02747-7. PMID: 31768688. Exclusion: Ineligible study design for Key Question31768688
125 Reddy K, Kelly C, Brown ER, Use of the dapivirine vaginal ring and effect on cervical cytology abnormalities. AIDS. 2020 03 15;34(4):559–67. doi: 10.1097/QAD.0000000000002451. PMID: 31764068. Exclusion: Ineligible outcome31764068
126 Refugio ON, Kimble MM, Silva CL, Brief Report: PrEPTECH: A Telehealth-Based Initiation Program for HIV Pre-exposure Prophylaxis in Young Men of Color Who Have Sex With Men. A Pilot Study of Feasibility. J Acquir Immune Defic Syndr. 2019 Jan 1;80(1):40–5. doi: 10.1097/qai.0000000000001873. PMID: 30272632. Exclusion: Ineligible comparator30272632
127 Ridgway JP, Almirol EA, Bender A, Which Patients in the Emergency Department Should Receive Preexposure Prophylaxis? Implementation of a Predictive Analytics Approach. AIDS Patient Care STDS. 2018 05;32(5):202–7. doi: 10.1089/apc.2018.0011. PMID: 29672136. Exclusion: Ineligible comparator29672136
128 Roberts ST, Haberer J, Celum C, Intimate partner violence and adherence to HIV pre-exposure prophylaxis (PrEP) in African women in HIV serodiscordant relationships: A prospective cohort study. J Acquir Immune Defic Syndr. 2016 Nov 01;73(3):313–22. doi: 10.1097/qai.0000000000001093. PMID: 27243900. Exclusion: Ineligible study design for Key Question27243900
129 Roux P, Fressard L, Suzan-Monti M, Is on-Demand HIV Pre-exposure Prophylaxis a Suitable Tool for Men Who Have Sex With Men Who Practice Chemsex? Results From a Substudy of the ANRS-IPERGAY Trial. J Acquir Immune Defic Syndr. 2018 10 01;79(2):e69–e75. doi: 10.1097/QAI.0000000000001781. PMID: 30212434. Exclusion: Ineligible population30212434
130 Sewell WC, Powell VE, Ball-Burack M, Brief Report: "I Didnť Really Have a Primary Care Provider Until I Got PrEP": Patients' Perspectives on HIV Preexposure Prophylaxis as a Gateway to Health Care. J Acquir Immune Defic Syndr. 2021 Sep 01;88(1):31–5. doi: 10.1097/QAI.0000000000002719. PMID: 34397743. Exclusion: Ineligible study design for Key Question34397743
131 Songtaweesin WN, Kawichai S, Phanuphak N, Youth-focused strategies to promote adherence to pre-exposure prophylaxis among adolescent men who have sex with men and transgender women at-risk for HIV in Thailand. J Int AIDS Soc. 2020;23(SUPPL 4)doi: 10.1002/jia2.25547. Exclusion: Wrong publication type (e.g., abstract only)
132 Thurman A, Brache V, Ouattara AL, Randomized, placebo controlled phase I trial of safety, pharmacokinetics, pharmacodynamics and acceptability of a multipurpose prevention vaginal ring containing tenofovir and levonorgestrel. J Int AIDS Soc. 2021;24(Suppl. 1):16–7. PMID: CN-02252156. Exclusion: Wrong publication type (e.g., abstract only)
133 Traeger MW, Cornelisse VJ, Asselin J, Association of HIV Preexposure Prophylaxis With Incidence of Sexually Transmitted Infections Among Individuals at High Risk of HIV Infection. JAMA. 2019 Apr 9;321(14):1380–90. doi: 10.1001/jama.2019.2947. PMID: 30964528. Exclusion: Ineligible study design for Key Question30964528
134 Traeger MW, Guy R, Asselin J, Real-world trends in incidence of bacterial sexually transmissible infections among gay and bisexual men using HIV pre-exposure prophylaxis (PrEP) in Australia following nationwide PrEP implementation: an analysis of sentinel surveillance data. Lancet Infect Dis. 2022 Aug;22(8):1231–41. doi: 10.1016/s1473-3099(22)00175-x. PMID: 35643090. Exclusion: Ineligible study design for Key Question35643090
135 Traeger MW, Schroeder SE, Wright EJ, Effects of pre-exposure prophylaxis for the prevention of HIV infection on sexual risk behavior in men who have sex with men: a systematic review and meta-analysis. Clin Infect Dis. 2018 Mar 2;67(5):676–86. doi: 10.1093/cid/ciy182. PMID: 29509889. Exclusion: Ineligible study design for Key Question29509889
136 U.S. Food & Drug Administration. FDA Approves First Injectable Treatment for HIV Pre-Exposure Prevention. December 20, 2021.; 2021. https://www.fda.gov/news-events/press-announcements/fda-approves-first-injectable-treatment-hiv-pre-exposure-prevention. Accessed December 20 2021. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
137 van Epps P, Maier M, Lund B, Medication adherence in a nationwide cohort of veterans initiating pre-exposure prophylaxis (PrEP) to prevent HIV infection. J Acquir Immune Defic Syndr. 2018 Mar 01;77(3):272–8. doi: 10.1097/QAI.0000000000001598. PMID: 29210835. Exclusion: Ineligible study design for Key Question29210835
138 Veloso VG, Vega-Ramírez EH, Hoagland B, Safety, early continuation and adherence of same day PrEP initiation among MSM and TGW in Brazil, Mexico and Peru: The ImPrEP Study. J Int AIDS Soc. 2019;22doi: 10.1002/jia2.25327. Exclusion: Wrong publication type (e.g., abstract only)
139 Volk JE, Marcus JL, Phengrasamy T, Incident hepatitis C virus infections among users of HIV preexposure prophylaxis in a clinical practice setting. Clin Infect Dis. 2015 Jun 1;60(11):1728–9. doi: 10.1093/cid/civ129. PMID: 25694649. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)25694649
140 Ware C, Sparks A, Levy M, Null effect of financial incentives or social media support on PrEP adherence in a randomized controlled trial of young men who have sex with men of colour. J Int AIDS Soc. 2021;24(SUPPL 1):131. doi: 10.1002/jia2.25659. Exclusion: Wrong publication type (e.g., abstract only)
141 Watson DL, Shaw PA, Petsis DT, Hiv prep counseling among black youth diagnosed with bacterial sti, 2014-2019. Top Antivir Med. 2021;29(1):282. Exclusion: Wrong publication type (e.g., abstract only)
142 Werner RN, Gaskins M, Nast A, Incidence of sexually transmitted infections in men who have sex with men and who are at substantial risk of HIV infection - A meta-analysis of data from trials and observational studies of HIV pre-exposure prophylaxis. PLoS ONE. 2018;13(12):e0208107. doi: 10.1371/journal.pone.0208107. PMID: 30507962. Exclusion: Ineligible study design for Key Question30507962
143 Whitfield TH F, Jones SS, Wachman M, The Impact of Pre-Exposure Prophylaxis (PrEP) Use on Sexual Anxiety, Satisfaction, and Esteem Among Gay and Bisexual Men. J Sex Res. 2019 Nov-Dec;56(9):1128–35. doi: 10.1080/00224499.2019.1572064. PMID: 30777781. Exclusion: Ineligible study design for Key Question30777781
144 Wirtz AL, Weir BW, Mon SH H, Testing the Effectiveness and Cost-Effectiveness of a Combination HIV Prevention Intervention Among Young Cisgender Men Who Have Sex With Men and Transgender Women Who Sell or Exchange Sex in Thailand: Protocol for the Combination Prevention Effectiveness Study. JMIR Res Protoc. 2020 Jan 27;9(1):e15354. doi: 10.2196/15354. PMID: 32012113. Exclusion: Ineligible study design for Key Question32012113
145 World Health Organization. WHO implementation tool for pre-exposure prophylaxis (PrEP) of HIV infection. 2017. http://www.who.int/hiv/pub/prep/prep-implementation-tool-policy/en/. Accessed 12.11.18. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
146 World Health Organization. PrEP Implementation Tool. 2021. https://www.who.int/tools/prep-implementation-tool. Accessed September 14, 2021. Exclusion: Not a study (letter, editorial, non-systematic review article, no original data)
147 Yacoub R, Nadkarni GN, Weikum D, Elevations in serum creatinine with tenofovir-based HIV pre-exposure prophylaxis: A meta-analysis of randomized placebo-controlled trials. J Acquir Immune Defic Syndr. 2016 Apr 1;71(4):e115–8. doi: 10.1097/QAI.0000000000000906. PMID: 26627105. Exclusion: Ineligible country26627105

## Appendix A6 Criteria for Assessing Internal Validity of Individual Studies

### Systematic Reviews

Criteria:

- Comprehensiveness of sources considered/search strategy used
- Standard appraisal of included studies
- Validity of conclusions
- Recency and relevance (especially important for systematic reviews)

Definition of ratings based on above criteria:

Good: Recent, relevant review with comprehensive sources and search strategies; explicit and relevant selection criteria; standard appraisal of included studies; and valid conclusions

Fair: Recent, relevant review that is not clearly biased but lacks comprehensive sources and search strategies

Poor: Outdated, irrelevant, or biased review without systematic search for studies, explicit selection criteria, or standard appraisal of studies

### Case-Control Studies

Criteria:

- Accurate ascertainment of cases
- Nonbiased selection of cases/controls, with exclusion criteria applied equally to both
- Response rate
- Diagnostic testing procedures applied equally to each group
- Measurement of exposure accurate and applied equally to each group
- Appropriate attention to potential confounding variables

Definition of ratings based on above criteria:

Good: Appropriate ascertainment of cases and nonbiased selection of case and control participants; exclusion criteria applied equally to cases and controls; response rate equal to or greater than 80 percent; accurate diagnostic procedures and measurements applied equally to cases and controls; and appropriate attention to confounding variables

Fair: Recent, relevant, and without major apparent selection or diagnostic workup bias, but response rate less than 80 percent or attention to some but not all important confounding variables

Poor: Major selection or diagnostic workup bias, response rate less than 50 percent, or inattention to confounding variables

### RCTs and Cohort Studies

Criteria:

- Initial assembly of comparable groups:
  ○ For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: adjustment for potential confounders for cohort studies or intention-to treat analysis for RCTs

Definition of ratings based on above criteria:

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.

Poor: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of ratings based on above criteria:

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease

Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients

Poor: Has a fatal flaw, such as: Uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients

Source: U.S. Preventive Services Task Force Procedure Manual. Accessed at https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual/procedure-manual-appendix-vi-criteria-assessing-internal-validity-individual-studies

## Appendix A7 Expert Reviewers of the Draft Report

Susan Buchbinder, MD, Director, HIV Prevention Research, San Francisco Department of Public Health Clinical Professor of Medicine, Epidemiology and Biostatistics, University of California San Francisco

Jessica Haberer, MD, MS, Director, Global Health Research, Massachusetts General Hospital; Associate Professor, Harvard Medical School

Sybil Hosek, PhD, Clinical Adolescent Psychologist, Stroger Hospital of Cook County; Assistant Professor, Division of Infectious Disease, Rush University, Chicago

Douglas Krakower, MD, Faculty, Division of Infectious Diseases at Beth Israel Deaconess Medical Center; Research Scientist, The Fenway Institute Assistant Professor, Medicine and Population Medicine at Harvard Medical School

Anonymous Reviewer

Federal Partner Representatives from the Centers for Disease Control and Prevention, National Institutes of Health Sexual & Gender Minority Research Office, National Institute of Allergy and Infectious Diseases, National Institute of Child Health and Human Development