# References

1 American College of Obstetrician and Gynecologists. Gestational Hypertension and Preeclampsia: ACOG Practice Bulletin Summary, Number 222. Obstetrics and gynecology. 2020;135(6):1492–5. PMID: 32443077. 10.1097/aog.0000000000003892 32443077
2 Hutcheon JA, Lisonkova S, Joseph KS. Epidemiology of pre-eclampsia and the other hypertensive disorders of pregnancy. Best Pract Res Clin Obstet Gynaecol. 2011;25(4):391–403.21333604
3 Hoyert DL. Maternal mortality rates in the United States, 2019.
4 Centers for Disease Control and Prevention. Pregnancy Mortality Surveillance System. https://www.cdc.gov/reproductivehealth/maternal-mortality/pregnancy-mortality-surveillance-system.htm. Accessed: January 17, 2023.
5 DeSisto CL, Robbins CL, Ritchey MD, . Hypertension at delivery hospitalization - United States, 2016-2017. Pregnancy hypertension. 2021;26:65–8. 10.1016/j.preghy.2021.09.002 34537460
6 Ananth CV, Brandt JS, Hill J, . Historical and Recent Changes in Maternal Mortality Due to Hypertensive Disorders in the United States, 1979 to 2018. Hypertension. 2021;78(5):1414–22. 10.1161/HYPERTENSIONAHA.121.17661 34510912
7 Petersen EE, Davis NL, Goodman D, . Vital signs: pregnancy-related deaths, United States, 2011–2015, and strategies for prevention, 13 states, 2013–2017. Morbidity and Mortality Weekly Report. 2019;68(18):423.31071074
8 Hitti J, Sienas L, Walker S, . Contribution of hypertension to severe maternal morbidity. Am J Obstet Gynecol. 2018;219(4):405.e1–.e7. 10.1016/j.ajog.2018.07.002
9 Admon LK, Winkelman TNA, Zivin K, . Racial and Ethnic Disparities in the Incidence of Severe Maternal Morbidity in the United States, 2012-2015. Obstetrics and gynecology. 2018;132(5):1158–66. 10.1097/aog.0000000000002937 30303912
10 Liese KL, Mogos M, Abboud S, . Racial and Ethnic Disparities in Severe Maternal Morbidity in the United States. J Racial Ethn Health Disparities. 2019;6(4):790–8. 10.1007/s40615-019-00577-w 30877505
11 Palatnik A, McGee P, Bailit J, . The association of race and ethnicity with severe maternal morbidity among individuals diagnosed with hypertensive disorders of pregnancy. Am J Perinatol. 2022. 10.1055/a-1886-5404
12 Chew LC, Verma RP. Fetal Growth Restriction. 2020.
13 Ananth CV, Vintzileos AM. Maternal-fetal conditions necessitating a medical intervention resulting in preterm birth. Am J Obstet Gynecol. 2006;195(6):1557–63. 10.1016/j.ajog.2006.05.021 17014813
14 Bryant AS, Worjoloh A, Caughey AB, . Racial/ethnic disparities in obstetric outcomes and care: prevalence and determinants. Am J Obstet Gynecol. 2010;202(4):335–43. 10.1016/j.ajog.2009.10.864 20060513
15 Centers for Disease Control and Prevention. Pregnancy-Related Deaths: Data from 14 U.S. Maternal Mortality Review Committees, 2008-2017. https://www.cdc.gov/reproductivehealth/maternal-mortality/erase-mm/mmr-data-brief.html. Accessed: 2021.
16 Petersen EE, Davis NL, Goodman D, . Racial/Ethnic Disparities in Pregnancy-Related Deaths - United States, 2007-2016. MMWR Morb Mortal Wkly Rep. 2019;68(35):762–5. PMID: 31487273. 10.15585/mmwr.mm6835a3 31487273
17 Grobman WA, Parker CB, Willinger M, . Racial disparities in adverse pregnancy outcomes and psychosocial stress. Obstetrics and gynecology. 2018;131(2):328.29324613
18 Gyamfi-Bannerman C, Pandita A, Miller EC, . Preeclampsia outcomes at delivery and race. J Matern Fetal Neonatal Med. 2020;33(21):3619–26. PMID: 30786794. 10.1080/14767058.2019.1581522 30786794
19 Fingar KR M-HI, Ngo-Metzger Q, . Delivery Hospitalizations Involving Preeclampsia and Eclampsia, 2005–2014: Statistical Brief #2222017 [cited Writing; Healthcare Cost and Utilization Project (HCUP) Statistical Briefs [Internet]: Available from: https://www.ncbi.nlm.nih.gov/books/NBK442039/.
20 Esakoff TF, Rad S, Burwick RM, . Predictors of eclampsia in California. J Matern Fetal Neonatal Med. 2016;29(10):1531–5. PMID: 26212587. 10.3109/14767058.2015.1057489 26212587
21 MacDorman MF, Thoma M, Declcerq E, . Racial and Ethnic Disparities in Maternal Mortality in the United States Using Enhanced Vital Records, 2016–2017. American Journal of Public Health. 2021;111(9):1673–81. 10.2105/ajph.2021.306375 34383557
22 Creanga AA, Syverson C, Seed K, . Pregnancy-Related Mortality in the United States, 2011-2013. Obstetrics and gynecology. 2017;130(2):366–73. PMID: 28697109. 10.1097/aog.0000000000002114 28697109
23 Heck JL, Jones EJ, Bohn D, . Maternal Mortality Among American Indian/Alaska Native Women: A Scoping Review. J Womens Health (Larchmt). 2021;30(2):220–9. 10.1089/jwh.2020.8890 33211616
24 Ghosh G, Grewal J, Männistö T, . Racial/ethnic differences in pregnancy-related hypertensive disease in nulliparous women. Ethn Dis. 2014;24(3):283–9.25065068
25 Dongarwar D, Tahseen D, Wang L, . Trends and predictors of eclampsia among singleton and multiple gestations in the United States, 1989-2018. Pregnancy hypertension. 2021;25:56–61. 10.1016/j.preghy.2021.05.013 34058700
26 Fasanya HO, Hsiao CJ, Armstrong-Sylvester KR, . A Critical Review on the Use of Race in Understanding Racial Disparities in Preeclampsia. J Appl Lab Med. 2021;6(1):247–56. PMID: 33227139. 10.1093/jalm/jfaa149 33227139
27 Miller EC, Zambrano Espinoza MD, Huang Y, . Maternal Race/Ethnicity, Hypertension, and Risk for Stroke During Delivery Admission. J Am Heart Assoc. 2020;9(3):e014775. PMID: 31973601. 10.1161/JAHA.119.014775 31973601
28 Esplin MS, Fausett MB, Fraser A, . Paternal and maternal components of the predisposition to preeclampsia. New England Journal of Medicine. 2001;344(12):867–72.11259719
29 Roberts JM. The perplexing pregnancy disorder preeclampsia: what next? Physiological Genomics. 2018;50(6):459–67. PMID: 29602298. 10.1152/physiolgenomics.00017.2018 29602298
30 Rana S, Lemoine E, Granger JP, . Preeclampsia: Pathophysiology, Challenges, and Perspectives. Circulation Research. 2019;124(7):1094–112. PMID: 30920918. 10.1161/CIRCRESAHA.118.313276 30920918
31 Gabbe SG. Obstetrics : normal and problem pregnancies. 2017.
32 Steegers EA, von DP, Duvekot JJ, . Pre-eclampsia. Lancet. 2010;376(9741):631–44.20598363
33 Stevens W, Shih T, Incerti D, . Short-term costs of preeclampsia to the United States health care system. Am J Obstet Gynecol. 2017;217(3):237–48 e16. 10.1016/j.ajog.2017.04.032 28708975
34 Ghulmiyyah L, Sibai B. Maternal mortality from preeclampsia/eclampsia. Seminars in perinatology. 2012;36(1):56–9. 10.1053/j.semperi.2011.09.011 22280867
35 Lisonkova S, Joseph KS. Incidence of preeclampsia: risk factors and outcomes associated with early- versus late-onset disease. Am J Obstet Gynecol. 2013;209(6):544-. PMID: 23973398.23973398
36 Giorgione V, Ridder A, Kalafat E, . Incidence of postpartum hypertension within 2 years of a pregnancy complicated by pre-eclampsia: a systematic review and meta-analysis. Bjog. 2021;128(3):495–503. 10.1111/1471-0528.16545 32981216
37 Honigberg MC, Zekavat SM, Aragam K, . Long-Term Cardiovascular Risk in Women With Hypertension During Pregnancy. Journal of the American College of Cardiology. 2019;74(22):2743–54. PMID: 31727424. 10.1016/j.jacc.2019.09.052 31727424
38 Melamed N, Ray JG, Hladunewich M, . Gestational hypertension and preeclampsia: are they the same disease? Journal of obstetrics and gynaecology Canada : JOGC = Journal d’obstetrique et gynecologie du Canada : JOGC. 2014;36(7):642–7. 10.1016/S1701-2163(15)30545-4
39 Brouwers L, van der Meiden-van Roest AJ, Savelkoul C, . Recurrence of pre-eclampsia and the risk of future hypertension and cardiovascular disease: a systematic review and meta-analysis. Bjog. 2018;125(13):1642–54. 10.1111/1471-0528.15394 29978553
40 Ackerman-Banks CM, Grechukhina O, Spatz E, . Seizing the Window of Opportunity Within 1 Year Postpartum: Early Cardiovascular Screening. J Am Heart Assoc. 2022;11(8):e024443. doi:10.1161/JAHA.121.024443 35411781
41 Haas DM, Parker CB, Marsh DJ, . Association of Adverse Pregnancy Outcomes With Hypertension 2 to 7 Years Postpartum. J Am Heart Assoc. 2019;8(19):e013092. PMID: 31564189. 10.1161/JAHA.119.013092 31564189
42 Behrens I, Basit S, Melbye M, . Risk of post-pregnancy hypertension in women with a history of hypertensive disorders of pregnancy: nationwide cohort study. Bmj. 2017;358:j3078. PMID: 28701333. 10.1136/bmj.j3078 28701333
43 Wu R, Wang T, Gu R, . Hypertensive Disorders of Pregnancy and Risk of Cardiovascular Disease-Related Morbidity and Mortality: A Systematic Review and Meta-Analysis. Cardiology. 2020;145(10):633–47. 10.1159/000508036 32841945
44 Wu P, Haththotuwa R, Kwok CS, . Preeclampsia and Future Cardiovascular Health: A Systematic Review and Meta-Analysis. Circ Cardiovasc Qual Outcomes. 2017;10(2). 10.1161/CIRCOUTCOMES.116.003497
45 Leon LJ, McCarthy FP, Direk K, . Preeclampsia and Cardiovascular Disease in a Large UK Pregnancy Cohort of Linked Electronic Health Records: A CALIBER Study. Circulation. 2019;140(13):1050–60. PMID: 31545680. 10.1161/CIRCULATIONAHA.118.038080 31545680
46 Bartsch E, Medcalf KE, Park AL, . Clinical risk factors for pre-eclampsia determined in early pregnancy: systematic review and meta-analysis of large cohort studies. Bmj. 2016;353:i1753. 10.1136/bmj.i1753 27094586
47 Shen M, Smith GN, Rodger M, . Comparison of risk factors and outcomes of gestational hypertension and pre-eclampsia. PloS one. 2017;12(4):e0175914–e. 10.1371/journal.pone.0175914 28437461
48 Dongarwar D, Tahseen D, Wang L, . Temporal trends in preterm birth phenotypes by plurality: Black-White disparity over half a century. Journal of perinatology : official journal of the California Perinatal Association. 2021;41(2):204–11. 10.1038/s41372-020-00912-8 33452419
49 Wright D, Tan MY, O’Gorman N, . Predictive performance of the competing risk model in screening for preeclampsia. Am J Obstet Gynecol. 2019;220(2):199.e1–.e13. PMID: 30447210. 10.1016/j.ajog.2018.11.1087 30447210
50 Henderson JT, Vesco KK, Senger CA, . Aspirin Use to Prevent Preeclampsia and Related Morbidity and Mortality: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. Jama. 2021;326(12):1192–206. 10.1001/jama.2021.8551 34581730
51 Davidson KW, Barry MJ, Mangione CM, . Aspirin Use to Prevent Preeclampsia and Related Morbidity and Mortality: US Preventive Services Task Force Recommendation Statement. Jama. 2021;326(12):1186–91. 10.1001/jama.2021.14781 34581729
52 Henderson JT, Thompson JH, Burda BU, . Preeclampsia Screening: Evidence Report and Systematic Review for the US Preventive Services Task Force. Jama. 2017;317(16):1668–83. PMID: 28444285. 10.1001/jama.2016.18315 28444285
53 American College of Obstetricians and Gynecologists (ACOG). Hypertension in pregnancy. Report of the American College of Obstetricians and Gynecologists’ Task Force on Hypertension in Pregnancy. Obstetrics and gynecology. 2013;122(5):1122–31. 10.1097/01.Aog.0000437382.03963.88 24150027
54 U. S. Preventive Services Task Force, Bibbins-Domingo K, Grossman DC, . Screening for Preeclampsia: US Preventive Services Task Force Recommendation Statement. Jama. 2017;317(16):1661–7. PMID: 28444286. 10.1001/jama.2017.3439 28444286
55 National Collaborating Centre for Ws, Children’s H. National Institute for Health and Clinical Excellence: Guidance. Hypertension in Pregnancy: The Management of Hypertensive Disorders During Pregnancy. London: RCOG Press Copyright © 2011, Royal College of Obstetricians and Gynaecologists.; 2010.
56 Bailey ZD, Feldman JM, Bassett MT. How Structural Racism Works - Racist Policies as a Root Cause of U.S. Racial Health Inequities. N Engl J Med. 2021;384(8):768–73. 10.1056/NEJMms2025396 33326717
57 Davidson KW, Mangione CM, Barry MJ, . Actions to Transform US Preventive Services Task Force Methods to Mitigate Systemic Racism in Clinical Preventive Services. Jama. 2021. 10.1001/jama.2021.17594
58 Lin JS, Hoffman L, Bean SI, . Addressing Racism in Preventive Services: Methods Report to Support the US Preventive Services Task Force. Jama. 2021. 10.1001/jama.2021.17579
59 Scott KA, Britton L, McLemore MR. The Ethics of Perinatal Care for Black Women: Dismantling the Structural Racism in “Mother Blame” Narratives. J Perinat Neonatal Nurs. 2019;33(2):108–15. 10.1097/JPN.0000000000000394 31021935
60 National Institute on Minority Health and Health Disparities. NIMHD Research Framework. https://www.nimhd.nih.gov/about/overview/research-framework.html. Accessed: November 19, 2021.
61 Alvidrez J, Castille D, Laude-Sharp M, . The National Institute on Minority Health and Health Disparities Research Framework. Am J Public Health. 2019;109(S1):S16–s20. 10.2105/ajph.2018.304883 30699025
62 Williams DR, Priest N, Anderson NB. Understanding associations among race, socioeconomic status, and health: Patterns and prospects. Health Psychol. 2016;35(4):407–11. 10.1037/hea0000242 27018733
63 Bailey ZD, Krieger N, Agénor M, . Structural racism and health inequities in the USA: evidence and interventions. Lancet. 2017;389(10077):1453–63. 10.1016/s0140-6736(17)30569-x 28402827
64 Howell EA. Reducing Disparities in Severe Maternal Morbidity and Mortality. Clin Obstet Gynecol. 2018;61(2):387–99. PMID: 29346121. 10.1097/GRF.0000000000000349 29346121
65 Centers for Disease Control and Prevention. Hypertension cascade: Hypertension prevalence, treatment and control estimates among us adults aged 18 years and older applying the criteria from the american college of cardiology and American Heart Association’s 2017 hypertension guideline-NHANES 2013-2016. Centers for Disease Control and Prevention. 2019.
66 National Toxicology P. NTP monograph on the systematic review of traffic-related air pollution and hypertensive disorders of pregnancy. NTP monogr. 2019;7. PMID: 33560269. 10.22427/NTP-MGRAPH-7 33560269
67 Morgan N, Christensen K, Skedros G, . Life stressors, hypertensive disorders of pregnancy, and preterm birth. Journal of Psychosomatic Obstetrics & Gynecology. 2020:1–9. PMID: 32567962. 10.1080/0167482X.2020.1778666 32567962
68 Padula AM, Ma C, Huang H, . Drinking water contaminants in California and hypertensive disorders in pregnancy. Environ Epidemiol. 2021;5(2):e149. PMID: 33870020. 10.1097/EE9.0000000000000149 33870020
69 Mayne SL, Yellayi D, Pool LR, . Racial Residential Segregation and Hypertensive Disorder of Pregnancy Among Women in Chicago: Analysis of Electronic Health Record Data. American Journal of Hypertension. 2018;31(11):1221–7. PMID: 30010764. 10.1093/ajh/hpy112 30010764
70 Stanhope KK, Adeyemi DI, Li T, . The relationship between the neighborhood built and social environment and hypertensive disorders of pregnancy: A scoping review. Ann Epidemiol. 2021;64:67–75. 10.1016/j.annepidem.2021.09.005 34547447
71 Duffy B, Pentieva K, Ward M, . Impact of riboflavin status on haemoglobin and risk of anaemia in pregnancy. Proc Nutr Soc [serial on the Internet]. 2021 [cited Bridge search - Cochrane; 80(Oce1): Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-02288009/full.
72 Office of Disease Prevention and Health Promotion. Healthy People 2030. https://health.gov/healthypeople/objectives-and-data/browse-objectives/pregnancy-and-childbirth/increase-proportion-pregnant-women-who-receive-early-and-adequate-prenatal-care-mich-08. Accessed: November 29, 2021, 2021.
73 Vidaeff AC, Saade GR, Sibai BM. Preeclampsia: The Need for a Biological Definition and Diagnosis. American Journal of Perinatology. 2020;27:27. PMID: 31986536. 10.1055/s-0039-1701023 31986536
74 Whelton PK, Carey RM, Aronow WS, . 2017 ACC/AHA/AAPA/ABC/ACPM/AGS/APhA/ASH/ASPC/NMA/PCNA Guideline for the Prevention, Detection, Evaluation, and Management of High Blood Pressure in Adults: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Hypertension. 2018;71(6):e13–e115. PMID: 29133356. 10.1161/hyp.0000000000000065 29133356
75 Elliott WJ, Lawton WJ. Normal blood pressure control and the evaluation of hypertension. Comprehensive Clinical Nephrology. 2018:396.
76 U. S. Preventive Services Task Force. Screening for Hypertension in Adults: US Preventive Services Task Force Reaffirmation Recommendation Statement. Jama. 2021;325(16):1650–6. 10.1001/jama.2021.4987 33904861
77 Hurrell A, Webster L, Chappell LC, . The assessment of blood pressure in pregnant women: pitfalls and novel approaches. Am J Obstet Gynecol. 2020;20:20. PMID: 33514455. 10.1016/j.ajog.2020.10.026 33514455
78 Bello NA, Woolley JJ, Cleary KL, . Accuracy of Blood Pressure Measurement Devices in Pregnancy: A Systematic Review of Validation Studies. Hypertension. 2018;71(2):326–35. 10.1161/HYPERTENSIONAHA.117.10295 29229741
79 Ashworth DC, Maule SP, Stewart F, . Setting and techniques for monitoring blood pressure during pregnancy. Cochrane Database of Systematic Reviews. 2020(8).
80 Fishel Bartal M, Lindheimer M, Sibai B. Proteinuria during pregnancy: definition, pathophysiology, methodology, and clinical significance. American Journal of Obstetrics and Gynecology. 2020.
81 Morris R, Riley R, Doug M, . Diagnostic accuracy of spot urinary protein and albumin to creatinine ratios for detection of significant proteinuria or adverse pregnancy outcome in patients with suspected pre-eclampsia: systematic review and meta-analysis. Bmj. 2012;345.
82 Daw JR, Sommers BD. Association of the Affordable Care Act Dependent Coverage Provision With Prenatal Care Use and Birth Outcomes. Jama. 2018;319(6):579–87. 10.1001/jama.2018.0030 29450525
83 Price SM, Caughey AB. The impact of prenatal care on pregnancy outcomes in women with depression. J Matern Fetal Neonatal Med. 2020:1–7. 10.1080/14767058.2020.1844655 29804488
84 Magpie Trial Follow-Up Study Collaborative Group. The Magpie Trial: a randomised trial comparing magnesium sulphate with placebo for pre-eclampsia. Outcome for children at 18 months. Bjog. 2007;114(3):289–99. 10.1111/j.1471-0528.2006.01165.x 17166221
85 Koopmans CM, Bijlenga D, Groen H, . Induction of labour versus expectant monitoring for gestational hypertension or mild pre-eclampsia after 36 weeks’ gestation (HYPITAT): a multicentre, open-label randomised controlled trial. Lancet. 2009;374(9694):979–88. 10.1016/s0140-6736(09)60736-4 19656558
86 Hofmeyr GJ, Lawrie TA, Atallah AN, . Calcium supplementation during pregnancy for preventing hypertensive disorders and related problems. Cochrane Database of Systematic Reviews. 2018;10:CD001059. PMID: 30277579. 10.1002/14651858.CD001059.pub5 30277579
87 Magro-Malosso ER, Saccone G, Di Tommaso M, . Exercise during pregnancy and risk of gestational hypertensive disorders: a systematic review and meta-analysis. Acta Obstetricia et Gynecologica Scandinavica. 2017;96(8):921–31. 10.1111/aogs.13151 28401531
88 Community Preventive Services Task Force. Pregnancy Health: Exercise Programs to Prevent Gestational Hypertension. 2019.
89 Syngelaki A, Sequeira Campos M, Roberge S, . Diet and exercise for preeclampsia prevention in overweight and obese pregnant women: systematic review and meta-analysis. The Journal of Maternal-Fetal & Neonatal Medicine. 2019;32(20):3495–501. 10.1080/14767058.2018.1481037 29792061
90 Davenport MH, Ruchat SM, Poitras VJ, . Prenatal exercise for the prevention of gestational diabetes mellitus and hypertensive disorders of pregnancy: a systematic review and meta-analysis. Br J Sports Med. 2018;52(21):1367–75. 10.1136/bjsports-2018-099355 30337463
91 AAP Committee on Fetus and Newborn, ACOG Committee on Obstetric Practice. Guidelines for Perinatal Care, 8th Edition. Kilpatrick SJPL-AMGA, editor: American Academy of Pediatrics; 2017.
92 United Nations Development Programme. Human Development Report. New York, NY: United Nations; 2020.
93 Berkman ND, Lohr KN, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville (MD): Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID: None.
94 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
95 Rhode MA, Shapiro H, Jones OW, III. Indicated vs. routine prenatal urine chemical reagent strip testing. J Reprod Med. 2007;52(3):214–9. PMID: 17465289.17465289
96 McDuffie RS, Jr., Beck A, Bischoff K, . Effect of frequency of prenatal care visits on perinatal outcome among low-risk women. A randomized controlled trial. Jama. 1996;275(11):847–51. PMID: 8596222.8596222
97 Ross-McGill H, Hewison J, Hirst J, . Antenatal home blood pressure monitoring: a pilot randomised controlled trial. Bjog. 2000;107(2):217–21. PMID: 10688505.10688505
98 Sikorski J, Wilson J, Clement S, . A randomised controlled trial comparing two schedules of antenatal visits: the antenatal care project. Bmj. 1996;312(7030):546–53. PMID: 8595286.8595286
99 Walker DS, Koniak-Griffin D. Evaluation of a reduced-frequency prenatal visit schedule for low-risk women at a free-standing birthing center. J Nurse Midwifery. 1997;42(4):295–303. 10.1016/s0091-2182(97)00027-x 9277060
100 Clement S, Candy B, Sikorski J, . Does reducing the frequency of routine antenatal visits have long term effects? Follow up of participants in a randomised controlled trial. Bjog. 1999;106(4):367–70.
101 Henderson J, Roberts T, Sikorski J, . An economic evaluation comparing two schedules of antenatal visits. Journal of health services research & policy. 2000;5(2):69–75.10947550
102 Mcduffie Jr RS, Bischoff KJ, Beck A, . Does reducing the number of prenatal office visits for low-risk women result in increased use of other medical services? Obstet Gynecol. 1997;90(1):68–70.9207816
103 McDuffie R, Bischoff K, Cross J, . An evaluation of risk-based prenatal care: a randomized controlled trial. American Journal of Obstetrics and Gynecology. 1995;172:270.
104 Tucker KL, Mort S, Yu L-M, . Effect of Self-monitoring of Blood Pressure on Diagnosis of Hypertension During Higher-Risk Pregnancy: The BUMP 1 Randomized Clinical Trial. Jama. 2022;327(17):1656–65. 10.1001/jama.2022.4712 35503346
105 van den Heuvel JFM, Lely AT, Huisman JJ, . SAFE@HOME: Digital health platform facilitating a new care path for women at increased risk of preeclampsia - A case-control study. Pregnancy Hypertens. 2020;22:30–6. PMID: 32717653. 10.1016/j.preghy.2020.07.006 32717653
106 Berglund AC, Lindmark GC. Health services effects of a reduced routine programme for antenatal care: An area-based study. European Journal of Obstetrics & Gynecology and Reproductive Biology. 1998;77(2):193–9. 10.1016/S0301-2115(97)00270-4 9578278
107 Ward N, Bayer S, Ballard M, . Impact of prenatal care with reduced frequency of visits in a residency teaching program. J Reprod Med. 1999;44(10):849–52.10554744
108 Dougall G, Franssen M, Tucker KL, . Blood pressure monitoring in high-risk pregnancy to improve the detection and monitoring of hypertension (the BUMP 1 and 2 trials): protocol for two linked randomised controlled trials. BMJ Open. 2020;10(1):e034593. PMID: 31980512. 10.1136/bmjopen-2019-034593 31980512
109 van der Bij AK, de Weerd S, Cikot RJ, . Validation of the dutch short form of the state scale of the Spielberger State-Trait Anxiety Inventory: considerations for usage in screening outcomes. Community Genet. 2003;6(2):84–7. 10.1159/000073003 14560068
110 Spielberger CD. Manual for the State-Trait Anxietry, Inventory. Consulting Psychologist. 1970.
111 Balk EM, Konnyu KJ, Cao W, . Schedule of Visits and Televisits for Routine Antenatal Care: A Systematic Review. 2022.
112 Peahl AF, Howell JD. The evolution of prenatal care delivery guidelines in the United States. Am J Obstet Gynecol. 2021;224(4):339–47. 10.1016/j.ajog.2020.12.016 33316276
113 Hinton L, Tucker KL, Greenfield SM, . Blood pressure self-monitoring in pregnancy (BuMP) feasibility study; a qualitative analysis of women’s experiences of self-monitoring. BMC Pregnancy & Childbirth. 2017;17(1):427. PMID: 29258469. 10.1186/s12884-017-1592-1 29258469
114 Tran K, Padwal R, Khan N, . Home blood pressure monitoring in the diagnosis and treatment of hypertension in pregnancy: a systematic review and meta-analysis. CMAJ Open. 2021;9(2):E642–E50. 10.9778/cmajo.20200099
115 Tucker KL, Bankhead C, Hodgkinson J, . How Do Home and Clinic Blood Pressure Readings Compare in Pregnancy? Hypertension. 2018;72(3):686–94. PMID: 30354754. 10.1161/HYPERTENSIONAHA.118.10917 30354754
116 Kalafat E, Benlioglu C, Thilaganathan B, . Home blood pressure monitoring in the antenatal and postpartum period: A systematic review meta-analysis. Pregnancy Hypertens. 2020;19:44–51. PMID: 31901652. 10.1016/j.preghy.2019.12.001 31901652
117 Pealing LM, Tucker KL, Mackillop LH, . A randomised controlled trial of blood pressure self-monitoring in the management of hypertensive pregnancy. OPTIMUM-BP: A feasibility trial. Pregnancy Hypertens. 2019;18:141–9. PMID: 31618706. 10.1016/j.preghy.2019.09.018 31618706
118 Hirshberg A, Downes K, Srinivas S. Comparing standard office-based follow-up with text-based remote monitoring in the management of postpartum hypertension: a randomised clinical trial. BMJ Qual Saf. 2018;27(11):871–7. PMID: 29703800. 10.1136/bmjqs-2018-007837 29703800
119 Hirshberg A, Sammel MD, Srinivas SK. Text message remote monitoring reduced racial disparities in postpartum blood pressure ascertainment. Am J Obstet Gynecol. 2019;221(3):283–5. PMID: 31121137. 10.1016/j.ajog.2019.05.011 31121137
120 Hoppe KK, Thomas N, Zernick M, . Telehealth with remote blood pressure monitoring compared with standard care for postpartum hypertension. Am J Obstet Gynecol. 2020;223(4):585–8. PMID: 32439388. 10.1016/j.ajog.2020.05.027 32439388
121 Janssen MK, Demers S, Srinivas SK, . Implementation of a text-based postpartum blood pressure monitoring program at 3 different academic sites. Am J Obstet Gynecol MFM. 2021;3(6):100446. 10.1016/j.ajogmf.2021.100446 34329800
122 Hauspurg A, Lemon LS, Quinn BA, . A Postpartum Remote Hypertension Monitoring Protocol Implemented at the Hospital Level. Obstet Gynecol. 2019;134(4):685–91. PMID: 31503166. 10.1097/AOG.0000000000003479 31503166
123 DeNicola N, Grossman D, Marko K, . Telehealth Interventions to Improve Obstetric and Gynecologic Health Outcomes: A Systematic Review. Obstetrics and gynecology. 2020;135(2):371–82. 10.1097/aog.0000000000003646 31977782
124 Cantor A, Nelson HD, Pappas M, . Effectiveness of Telehealth for Women’s Preventive Services. 2022.
125 Barrera CM, Powell AR, Biermann CR, . A Review of Prenatal Care Delivery to Inform the Michigan Plan for Appropriate Tailored Healthcare in Pregnancy Panel. Obstet Gynecol. 2021;138(4):603–15. 10.1097/AOG.0000000000004535 34352841
126 Johnson JD, Louis JM. Does race or ethnicity play a role in the origin, pathophysiology, and outcomes of preeclampsia? An expert review of the literature. Am J Obstet Gynecol. 2020. 10.1016/j.ajog.2020.07.038
127 Stanhope KK, Picon M, Schlusser C, . Chronic Stress and Preconception Health Among Latina Women in Metro Atlanta. Matern Child Health J. 2021;25(7):1147–55. 10.1007/s10995-021-03164-w 33909207
128 Hollenbach SJ, Thornburg LL, Glantz JC, . Associations Between Historically Redlined Districts and Racial Disparities in Current Obstetric Outcomes. JAMA Netw Open. 2021;4(9):e2126707. 10.1001/jamanetworkopen.2021.26707 34591104
129 Nguemeni Tiako MJ, South E, Shannon MM, . Urban residential tree canopy and perceived stress among pregnant women. Environ Res. 2021;201:111620. 10.1016/j.envres.2021.111620 34216611
130 National Academies of Sciences E, Medicine, Health, . In: McHugh K, Martinez RM, Alper J, editors. Advancing Maternal Health Equity and Reducing Maternal Morbidity and Mortality: Proceedings of a Workshop. Washington (DC): National Academies Press (US) Copyright 2021 by the National Academy of Sciences. All rights reserved.; 2021.
131 National Quality Forum. Maternal Morbidity and Mortality Measurement Recommendations Report. Washington, DC: 2021.
132 Office of the Surgeon G. Publications and Reports of the Surgeon General. The Surgeon General’s Call to Action to Improve Maternal Health. Washington (DC): US Department of Health and Human Services; 2020.
133 Butler Tobah YS, LeBlanc A, Branda ME, . Randomized comparison of a reduced-visit prenatal care model enhanced with remote monitoring. Am J Obstet Gynecol. 2019;221(6):638.e1–.e8. 10.1016/j.ajog.2019.06.034
134 Rayment-Jones H, Dalrymple K, Harris J, . Project20: Does continuity of care and community-based antenatal care improve maternal and neonatal birth outcomes for women with social risk factors? A prospective, observational study. PLoS One. 2021;16(5):e0250947. 10.1371/journal.pone.0250947 33945565
135 Ahn R, Gonzalez GP, Anderson B, . Initiatives to Reduce Maternal Mortality and Severe Maternal Morbidity in the United States : A Narrative Review. Ann Intern Med. 2020;173(11 Suppl):S3–s10. 10.7326/m19-3258 33253021
136 Minehart RD, Bryant AS, Jackson J, . Racial/Ethnic Inequities in Pregnancy-Related Morbidity and Mortality. Obstet Gynecol Clin North Am. 2021;48(1):31–51. 10.1016/j.ogc.2020.11.005 33573789
137 D’Alton ME, Friedman AM, Bernstein PS, . Putting the “M” back in maternal-fetal medicine: A 5-year report card on a collaborative effort to address maternal morbidity and mortality in the United States. Am J Obstet Gynecol. 2019;221(4):311–7.e1. 10.1016/j.ajog.2019.02.055 30849353
138 Morton CH, Seacrist MJ, VanOtterloo LR, . Quality Improvement Opportunities Identified Through Case Review of Pregnancy-Related Deaths From Preeclampsia/Eclampsia. JOGNN - Journal of Obstetric, Gynecologic, & Neonatal Nursing. 2019;48(3):275–87. PMID: 30980787. 10.1016/j.jogn.2019.02.008 30980787
139 Peahl AF, Zahn CM, Turrentine M, . The Michigan Plan for Appropriate Tailored Healthcare in Pregnancy Prenatal Care Recommendations. Obstetrics and gynecology. 2021;138(4):593–602. 10.1097/aog.0000000000004531 34352810
140 Phillips-Bell G, Holicky A, Macdonald M, . Collaboration Between Maternal and Child Health and Chronic Disease Epidemiologists to Identify Strategies to Reduce Hypertension-Related Severe Maternal Morbidity. Prev Chronic Dis. 2019;16:E162. PMID: 31831105. 10.5888/pcd16.190045 31831105
141 Redman EK, Hauspurg A, Hubel CA, . Clinical Course, Associated Factors, and Blood Pressure Profile of Delayed-Onset Postpartum Preeclampsia. Obstet Gynecol. 2019;134(5):995–1001. PMID: 31599846. 10.1097/AOG.0000000000003508 31599846
142 Smithson SD, Greene NH, Esakoff TF. Risk factors for re-presentation for postpartum hypertension in patients without a history of hypertension or preeclampsia. Am J Obstet Gynecol MFM. 2021;3(2):100297. PMID: 33516136. 10.1016/j.ajogmf.2020.100297 33516136
143 Chornock R, Iqbal SN, Kawakita T. Racial Disparity in Postpartum Readmission due to Hypertension among Women with Pregnancy-Associated Hypertension. American Journal of Perinatology. 2020;02:02. PMID: 32485755. 10.1055/s-0040-1712530 32485755
144 Sibai BM. Etiology and management of postpartum hypertension-preeclampsia. Am J Obstet Gynecol. 2012;206(6):470–5. 10.1016/j.ajog.2011.09.002 21963308
145 Lewey J, Levine LD, Yang L, . Patterns of Postpartum Ambulatory Care Follow-up Care Among Women With Hypertensive Disorders of Pregnancy. J Am Heart Assoc. 2020;9(17):e016357. PMID: 32851901. 10.1161/JAHA.120.016357 32851901
146 Hauspurg A, Lemon L, Cabrera C, . Racial Differences in Postpartum Blood Pressure Trajectories Among Women After a Hypertensive Disorder of Pregnancy. JAMA Network Open. 2020;3(12):e2030815. PMID: 33351087. 10.1001/jamanetworkopen.2020.30815 33351087
147 Jones EJ, Hernandez TL, Edmonds JK, . Continued Disparities in Postpartum Follow-Up and Screening Among Women With Gestational Diabetes and Hypertensive Disorders of Pregnancy: A Systematic Review. J Perinat Neonatal Nurs. 2019;33(2):136–48. PMID: 31021939. 10.1097/JPN.0000000000000399 31021939
148 Hirshberg A. Race Differences in Blood Pressure Trajectory After Delivery-A Window Into Opportunities to Decrease Racial Disparities in Maternal Morbidity and Mortality. JAMA Network Open. 2020;3(12):e2031122. PMID: 33351081. 10.1001/jamanetworkopen.2020.31122 33351081
149 American College of Obstetrician and Gynecologists. ACOG Committee Opinion No. 736 Summary: Optimizing Postpartum Care. Obstetrics and gynecology. 2018;131(5):949–51. 10.1097/aog.0000000000002628 29683906
150 Essien UR, Molina RL, Lasser KE. Strengthening the postpartum transition of care to address racial disparities in maternal health. J Natl Med Assoc. 2019;111(4):349–51. 10.1016/j.jnma.2018.10.016 30503575
151 Wu P, Park K, Gulati M. The Fourth Trimester: Pregnancy as a Predictor of Cardiovascular Disease. Eur Cardiol. 2021;16:e31. 10.15420/ecr.2021.18 34603511
152 Effective Health Care Program AfHRaQ. Research Protocol: Postpartum Care for Women Up to One Year After Pregnancy. https://effectivehealthcare.ahrq.gov/products/postpartum-care-one-year/protocol. Accessed: August 16, 2022.
153 Arnett DK, Blumenthal RS, Albert MA, . 2019 ACC/AHA Guideline on the Primary Prevention of Cardiovascular Disease: A Report of the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines. Circulation. 2019;140(11):e596–e646. 10.1161/cir.0000000000000678 30879355
154 Elder P, Sharma G, Gulati M, . Identification of female-specific risk enhancers throughout the lifespan of women to improve cardiovascular disease prevention. American Journal of Preventive Cardiology. 2020;2:100028. 10.1016/j.ajpc.2020.100028 34327455
155 Hauspurg A, Countouris ME, Catov JM. Hypertensive Disorders of Pregnancy and Future Maternal Health: How Can the Evidence Guide Postpartum Management? Current hypertension reports. 2019;21(12):96. PMID: 31776692. 10.1007/s11906-019-0999-7 31776692
156 Escouto DC, Green A, Kurlak L, . Postpartum evaluation of cardiovascular disease risk for women with pregnancies complicated by hypertension. Pregnancy Hypertens. 2018;13:218–24. PMID: 30177055. 10.1016/j.preghy.2018.06.019 30177055
157 Capriglione S, Plotti F, Terranova C, . Preeclampsia and the challenge of early prediction: reality or utopia? State of art and critical review of literature. J Matern Fetal Neonatal Med. 2020;33(4):677–86. PMID: 29954233. 10.1080/14767058.2018.1495191 29954233
158 Townsend R, Khalil A, Premakumar Y, . Prediction of pre-eclampsia: review of reviews. Ultrasound in Obstetrics & Gynecology. 2019;54(1):16–27. PMID: 30267475. 10.1002/uog.20117 30267475
159 Allotey J, Snell KI, Smuk M, . Validation and development of models using clinical, biochemical and ultrasound markers for predicting pre-eclampsia: an individual participant data meta-analysis. Health Technology Assessment (Winchester, England). 2020;24(72):1–252. PMID: 33336645. 10.3310/hta24720 33336645
160 Palmer KR, Tanner M, Davies-Tuck M, . Widespread implementation of a low-cost telehealth service in the delivery of antenatal care during the COVID-19 pandemic: an interrupted time-series analysis. Lancet. 2021;398(10294):41–52. 10.1016/s0140-6736(21)00668-1 34217399
161 Duryea EL, Adhikari EH, Ambia A, . Comparison Between In-Person and Audio-Only Virtual Prenatal Visits and Perinatal Outcomes. JAMA Netw Open. 2021;4(4):e215854. 10.1001/jamanetworkopen.2021.5854 33852002
162 Reddy M, Fenn S, Rolnik DL, . The impact of the definition of preeclampsia on disease diagnosis and outcomes: a retrospective cohort study. Am J Obstet Gynecol. 2021;224(2):217.e1–.e11. PMID: 32795430. 10.1016/j.ajog.2020.08.019 32795430
163 Shinar S, Melamed N, Abdulaziz KE, . Changes in rate of preterm birth and adverse pregnancy outcomes attributed to preeclampsia after introduction of a refined definition of preeclampsia: a population-based study. Acta Obstetricia et Gynecologica Scandinavica. 2021;27:27. PMID: 34043808. 10.1111/aogs.14199 34043808
164 Magee LA, Singer J, Lee T, . The impact of pre-eclampsia definitions on the identification of adverse outcome risk in hypertensive pregnancy - analyses from the CHIPS trial (Control of Hypertension in Pregnancy Study). Bjog. 2020;23:23. PMID: 33230924. 10.1111/1471-0528.16602 33230924
165 Loerup L, Pullon RM, Birks J, . Trends of blood pressure and heart rate in normal pregnancies: a systematic review and meta-analysis. BMC Med. 2019;17(1):167. PMID: 31506067. 10.1186/s12916-019-1399-1 31506067
166 Celi AC, Seely EW, Wang P, . Caring for Women After Hypertensive Pregnancies and Beyond: Implementation and Integration of a Postpartum Transition Clinic. Matern Child Health J. 2019;23(11):1459–66. PMID: 31257555. 10.1007/s10995-019-02768-7 31257555
167 Triebwasser JE, Janssen MK, Hirshberg A, . Successful implementation of text-based blood pressure monitoring for postpartum hypertension. Pregnancy Hypertens. 2020;22:156–9. PMID: 32980623. 10.1016/j.preghy.2020.09.001 32980623
168 Bello NA, Miller E, Cleary K, . Out of Office Blood Pressure Measurement in Pregnancy and the Postpartum Period. Current hypertension reports. 2018;20(12):101. PMID: 30361886. 10.1007/s11906-018-0901-z 30361886
169 Henderson JT, Webber EM, Bean SI. Screening for Asymptomatic Bacteriuria in Adults: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. Jama. 2019;322(12):1195–205. 10.1001/jama.2019.10060 31550037
170 U. S. Preventive Services Task Force. Screening for Asymptomatic Bacteriuria in Adults: US Preventive Services Task Force Recommendation Statement. Jama. 2019;322(12):1188–94. 10.1001/jama.2019.13069 31550038