# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Iris R. Mabry-Hernandez, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Centers for Disease Control and Prevention, the National Heart, Lung, and Blood Institute, and the National Institutes of Health Office of Research on Women’s Health for providing federal partner review of the draft report; Kimberly D. Gregory, MD, MPH, Laura A. Magee, MD, Alex Friedman Peahl, MD, MS, and Katherine Tucker, PhD, who provided expert review of the draft report; Jennifer S. Lin, MD, for mentoring and project oversight; and Sarah I. Bean, MPH, Neon Brooks, PhD, and Melinda Davies, MAIS, for technical and editorial assistance at the Kaiser Permanente Center for Health Research, Northwest.