# Chapter 4 Discussion

## Summary of Evidence

This review of the comparative effectiveness of screening strategies for hypertensive disorders of pregnancy included six studies, three conducted in the United States and three in the United Kingdom. Two RCTs tested interventions involving home blood pressure measurement as a supplement or replacement for prenatal care visits,^97,^ ^104^ three RCTs evaluated reduced prenatal visit schedules for individuals at low risk for complications,^96,^ ^98,^ ^99^ and one NRSI with a historical control compared indicated urine screening with routine screening at all prenatal visits.^95^ The evidence was insufficient or low for concluding that there was not a difference between the interventions studied and control conditions for a range of health outcomes (Table 7). All included studies were determined to have some risk of bias due to factors such as baseline group imbalances, potential confounding, or loss to followup. Additionally, the confidence intervals estimated for the most serious, but rare, pregnancy outcomes reported were too wide to rule out differences between study groups. The applicability of the evidence was limited for the RCTs of reduced visit schedules and for the study of indicated urine testing because they were conducted in settings that are not representative of the demographic composition of the US population and apply to screening only among individuals at low risk of pregnancy complications. One study, evaluating home blood pressure measurement as a supplement to usual care, enrolled a population selected based on risk factors for preeclampsia. None of the studies were conducted to evaluate interventions among the US populations with the highest rates of hypertensive disorders of pregnancy, Black and AI/AN people; these populations made up few or none of the participants in the included studies. The NRSI with historical control provided very limited evidence on the effects of indicated urine screening compared to routine screening for US pregnant populations due to risk of bias inherent to the study design and because it was narrowly focused on just one important population, mostly consisting of Hispanic individuals who had public health insurance or were uninsured.

Table 7 Summary of the Evidence

Intervention | Studies (K), Design; Number of Observ-ations (N); Country | Summary of Findings | Outcome(s) | Consistency and Precision | Overall Strength of Evidence | Body of Evidence Limitations | Applicability
KQ1
Home blood pressure measurement | K = 1 fair-quality RCT; N = 2,441; UK | Fewer than 2% of participants experienced serious HDP complications. The difference between groups was not statistically significant (RR 0.79 [95% CI, 0.40 to 1.55]).; Estimated risk of SGA/IUGR (RR 1.15 [95% CI 0.87 to 1.53]) was not statistically significant, with slightly more cases in the home measurement group (8.3% vs 7.0%) | Maternal morbidity and mortality | NA, imprecise | Insufficient | Underpowered for precise estimation of small differences and rare outcomes; Single study in one setting, lack of replication; Slight imbalance in baseline characteristics not accounted for in analysis | Individuals attending prenatal care by 16 to 24 weeks of gestation (in the UK) at increased risk for preeclampsia based on established clinical risk factors
Home blood pressure measurement | K = 1 fair-quality RCT; N = 2,441; UK | | Neonatal morbidity and mortality | NA, imprecise | Insufficient | Underpowered for precise estimation of small differences and rare outcomes; Single study in one setting, lack of replication; Slight imbalance in baseline characteristics not accounted for in analysis | Individuals attending prenatal care by 16 to 24 weeks of gestation (in the UK) at increased risk for preeclampsia based on established clinical risk factors
Home blood pressure measurement | K = 1 fair-quality RCT; N = 2,441; UK | | SGA/IUGR | NA, imprecise | Insufficient | Underpowered for precise estimation of small differences and rare outcomes; Single study in one setting, lack of replication; Slight imbalance in baseline characteristics not accounted for in analysis | Individuals attending prenatal care by 16 to 24 weeks of gestation (in the UK) at increased risk for preeclampsia based on established clinical risk factors
Reduced prenatal screening visit schedule | K = 3 fair-quality RCTs; (N = 5,203); US, UK | Few cases of perinatal mortality, risk lower or the same in large trials (RR 0.72 and 1.00) with wide 95% confidence intervals.; Similar proportions with preterm delivery, SGA/IUGR, and low birthweight in two large trials (RRs ranged from 0.94 to 1.13); 95% confidence intervals contained null.; Placental abruption rarely occurred and was similar between groups in one large trial; confidence intervals contained null. The risk for postpartum hemorrhage was the same or reduced with fewer visits (RR 1.01 and RR 0.94). | Postpartum hemorrhage | Reasonably consistent, reasonably precise | Low for no difference | Heterogeneous outcomes reported; Modest risk of bias mostly related to absent information on long-term followup, but attrition low; Two larger trials underpowered to detect small differences in rare, serious outcomes; one small trial had too few events to estimate effects with any precision | US and UK populations of people at low risk for pregnancy complications; Change to number of blood pressure measurements resulted from a change in number of prenatal visits.; Confounding of blood pressure measurement with other clinical interventions that occur during prenatal visits limits conclusions
Reduced prenatal screening visit schedule | K = 3 fair-quality RCTs; (N = 5,203); US, UK | | Placental abruption | NA, reasonably precise | Insufficient
Reduced prenatal screening visit schedule | K = 3 fair-quality RCTs; (N = 5,203); US, UK | | Perinatal mortality | Reasonably consistent, imprecise | Insufficient
Reduced prenatal screening visit schedule | K = 3 fair-quality RCTs; (N = 5,203); US, UK | | Miscarriage, fetal loss | NA, imprecise | Insufficient
Reduced prenatal screening visit schedule | K = 3 fair-quality RCTs; (N = 5,203); US, UK | | Neonatal sepsis, respiratory distress | NA, imprecise | Insufficient
Reduced prenatal screening visit schedule | K = 3 fair-quality RCTs; (N = 5,203); US, UK | | Preterm delivery | Reasonably consistent, imprecise | Insufficient
Reduced prenatal screening visit schedule | K = 3 fair-quality RCTs; (N = 5,203); US, UK | | Low birth weight | NA, reasonably precise | Insufficient
Reduced prenatal screening visit schedule | K = 3 fair-quality RCTs; (N = 5,203); US, UK | | SGA/IUGR | Inconsistent, reasonably precise | Insufficient
Indicated rather than routine urine screening | K = 1 fair-quality NRSI, historical control; (N = 2,441); US | Risk of preterm delivery was reduced with indicated urine screening (4.9%) compared with routine urine screening (7.7%); RR 0.64 (95% CI, 0.45 to 0.90) | Preterm delivery | NA, reasonably precise | Insufficient | Only one health outcome reported, possible selective reporting; Analysis unadjusted; increase in Medicaid health insurance eligibility and decrease in self-pay in indicated screening period compared with routine; Observational study design with inherent risk of concurrent changes (history) | U.S. population obtaining prenatal care in safety-net settings serving Medicaid-eligible populations, especially pregnant people reporting Hispanic ethnicity
KQ2
Home blood pressure measurement | K = 1 fair-quality RCT; (N = 2,441) | No statistical difference in days to detection of HDP (mean days −1.58 [95% CI, −8.10 to 4.94]).; No difference in HDP diagnoses (RR 0.98 [95% CI, 0.81 to 1.18]).; Slightly higher incidence of severe hypertension in home measurement group (6.0% vs. 4.8%), but not statistically different (RR 1.22 [95% CI, 0.87 to 1.70]) | HDP detection | NA, reasonably precise | Insufficient | Low risk of bias for health outcomes collected from medical record, minor group imbalance at baseline could bias toward null; Single study in one setting; Underpowered for precise estimation of small differences and rare outcomes | Individuals attending prenatal care by 16 to 24 weeks of gestation (in the UK) at increased risk for preeclampsia based on established clinical risk factors
Reduced prenatal screening visit schedule | K = 3 fair-quality RCTS; (N = 5,203) | No differences in diagnoses of HDP.; A large US trial showed a trend toward fewer individuals diagnosed with preeclampsia and more with gestational hypertension, but equal diagnoses of preeclampsia with severe features (RR 1.01 [95% CI, 0.68 to 1.62]) | HDP detection | Reasonably consistent, reasonably precise | Low for no difference | Differences between the intervention and control schedules were smaller than planned (difference between arms ranged from 2.2 to 3.2 visits) | US and UK populations at low risk for pregnancy complications of people attending prenatal care; Change to number of blood pressure measurements resulted from a change in number of prenatal visits.; Confounding of blood pressure measurement with other clinical interventions that occur during prenatal visits limits conclusions
Indicated rather than routine urine screening | K = 1 fair-quality NRSI, historical control; (N = 2,441) | Fewer diagnoses of preeclampsia (RR 0.58 [95% CI, 0.35 to 0.98)] and a trend toward more with gestational hypertension; no difference in diagnoses of HDP overall (RR 1.00 [95% CI, 0.74 to 1.36]) | HDP detection | NA, reasonably precise | Insufficient | Analyses unadjusted; increase in Medicaid health insurance eligibility and decrease in self-pay in indicated screening period compared with routine | U.S. populations obtaining prenatal care in safety-net settings serving Medicaid eligible populations, especially pregnant people reporting Hispanic ethnicity
KQ3
Home blood pressure measurement | K = 2 fair-quality RCTs; (N = 2,521) | One large trial reported similar rates of induction of labor and cesarean delivery for hypertension related complications (RR 1.09 [95% CI, 0.82 to 1.44]) and similar rates of emergency cesarean delivery (RR 0.89 [95% CI, 0.76 to 1.03]); Two trials reported no difference in anxiety (STAI) during pregnancy or postpartum | Delivery outcomes | NA, reasonably precise | Insufficient | Risk of bias higher for anxiety outcome measures due to high loss to followup and missing data; Single study in one setting, lack of replication | Individuals attending prenatal care by 16 to 24 weeks of gestation (in the UK) at increased risk for preeclampsia based on established clinical risk factors
Home blood pressure measurement | K = 2 fair-quality RCTs; (N = 2,521) | | Mental health/HRQoL | Reasonably consistent, reasonably precise | Insufficient | Risk of bias higher for anxiety outcome measures due to high loss to followup and missing data; Single study in one setting, lack of replication | Individuals attending prenatal care by 16 to 24 weeks of gestation (in the UK) at increased risk for preeclampsia based on established clinical risk factors
Reduced prenatal screening visit schedule | K = 3 fair-quality RCTS; (N = 5,203) | Two large trials reported similar levels of Cesarean delivery or induction of labor for any reason and for reasons related to hypertension or fetal distress (between-group differences ≤1.5%, RRs 0.81 to 1.06). A small trial had too few cases to test differences in Cesarean delivery.; None of the trials found differences in anxiety or postnatal depression between study groups; different measures and time points reported. | Delivery outcomes | Inconsistent, reasonably precise | Insufficient | Risk of bias higher for anxiety outcomes due to higher loss to followup and incomplete data | US and UK populations at low risk for pregnancy complications of people attending prenatal care; Change to number of blood pressure measurements resulted from a change in number of prenatal visits.; Confounding of blood pressure measurement with other clinical interventions that occur during prenatal visits limits conclusions
Reduced prenatal screening visit schedule | K = 3 fair-quality RCTS; (N = 5,203) | | Mental health/HRQoL | NA, reasonably precise | Insufficient | Risk of bias higher for anxiety outcomes due to higher loss to followup and incomplete data
Indicated rather than routine urine screening | K = 1 fair-quality NRSI, historical control; (N = 2,441) | Similar risk for cesarean delivery (RR 0.96 [95% CI, 0.79 to 1.16]) | Delivery outcomes | NA, reasonably precise | Insufficient | Analyses unadjusted; increase in Medicaid health insurance eligibility and decrease in self-pay in indicated screening period compared with routine; Reason for cesarean delivery not provided | U.S. populations obtaining prenatal care in safety-net settings serving Medicaid-eligible populations, especially pregnant people reporting Hispanic ethnicity

Abbreviations: CI = Confidence interval; HDP = Hypertensive disorders of pregnancy; HRQoL = Health-related quality of life; NA = Not applicable; NRSI = Non-randomized study of an intervention; RCT = Randomized controlled trial; RR = Relative risk; SGA/IUGR = Small for gestational age/intrauterine growth restriction; STAI = State component of the State-Trait Anxiety Inventory; UK = United Kingdom; US = United States.

A 2022 literature review with a broader scope included evidence on different prenatal care programs and in including qualitative studies.^111^ The findings were similar to ours with regard to the limited evidence available for comparing different schedules and virtual care approaches for antenatal health care and their effects on health outcomes. When comparing different antenatal screening schedules and telehealth interventions evidence on health outcomes was insufficient for drawing conclusions. Additionally, the review identified themes from studies on patient and provider perspectives; potential barriers to access and reduced health care quality were seen for some prenatal schedules and telehealth interventions. Overall, the review also pointed to the limited evidence base and need for further research.^111^

## Current Clinical Context of Screening for Hypertensive Disorders of Pregnancy in Prenatal Care

Overall, this review highlights the limited resources that have been devoted to clinical research on antenatal screening practices that have been standard of care for decades.^112^ Blood pressure measurement during pregnancy has long been recognized as important for screening for signs of complications that can pose serious maternal and infant health risks. Sustained high blood pressure is a key diagnostic criterion for preeclampsia, and routine measurement of blood pressure over the course of pregnancy serves to establish baseline values and to identify the emergence of new-onset hypertension. Office-based blood pressure measurement at prenatal care visits is standard practice, conducted following schedules historically established through expert consensus.^112^ There are hints from newer research, including a trial identified in this review, that innovations in prenatal care practice are emerging. These innovations include changes to standard prenatal visit schedules, the use of virtual visits and home blood pressure measurements that should be further tested in prenatal and post-partum care for individuals with different levels of risk for developing hypertensive disorders of pregnancy. The impact of these changes on health outcomes and potential harms is unclear, as a body of high-quality research evidence is lacking.

### Home Blood Pressure Monitors and Telehealth Practices

#### Home Blood Pressure Measurement

The option of having patients monitor their blood pressure at home through routine home blood pressure measurement is appealing for multiple reasons, including allowing for increased frequency of surveillance outside of the office setting (particularly for individuals at increased risk of developing a hypertensive disorder of pregnancy); to address concerns about white coat or masked hypertension; and for use in conjunction with telehealth visits or a reduced prenatal visit schedule. Potential health benefits of home blood pressure measurement include earlier detection of hypertension and less under- or over-diagnosis of hypertension. Qualitative research performed in preparation for the BUMP trial also suggests that home blood pressure monitoring may help reduce an individual’s anxiety about their health during pregnancy, as well provide reassurance and a sense of empowerment, especially among those with a prior history of hypertensive disorder during pregnancy.^113^ Potential risks include inaccurate readings, missed opportunities for intervention on severe-range blood pressure, and patient anxiety about performing the measures themselves. Existing systematic reviews have identified that studies comparing home and office measurements of blood pressure during pregnancy have significant heterogeneity,^114,^ ^115^ with many studies utilizing devices not clinically validated for use in pregnancy.^78,^ ^114^ An individual patient data meta-analysis published in 2018 included 8 studies of home blood pressure measurement during pregnancy, only 2 of which used validated blood pressure cuffs.^115^ Pooled data for 7 studies showed no significant mean differences between home and office blood pressure readings in early or late pregnancy, but there was substantial variability among the studies, with some suggesting higher and some suggesting lower readings for home measurements compared to office measurements. Further, the mean differences between home and office readings were greater for women with a diagnosis of hypertension than for normotensive women. A more recent systematic review published in 2021 identified a greater number of studies enlisting validated home blood pressure devices. In the 2021 review, pooled data from 7 studies that utilized validated home monitors to compare home and office blood pressure assessments indicated that home blood pressure measures were lower on average than office values (mean difference −4mmHg [95% CI, −7 to −2]) for both systolic and diastolic blood pressure.^114^

A trial identified in this review, the BUMP1 trial, randomized participants at increased risk for hypertensive disorders of pregnancy to home blood pressure measurements in addition to usual care or to usual care only.^104^ The trial incorporated the use of a portable blood pressure cuff validated for use in pregnancy along with a mobile-phone-based application that provided feedback to the patient about their blood pressure readings. The study was not technically a telehealth intervention since there was no transmission of blood pressure readings to clinical care providers. Instead, participants were instructed to contact their health care provider if elevated home blood pressure readings were recorded. Based on the lack of differences in maternal and neonatal outcomes seen in this trial, including lack of earlier detection of hypertensive disorders of pregnancy in the blood pressure self-measurement in the intervention group, one could argue that there is no benefit associated with the added burden of home blood pressure checks. However, there was also no increased risk to the mother or neonate, and, like the study by Ross-McGill et al,^97^ the authors did not find increased in anxiety associated with ongoing home blood pressure measurements. These findings may support the safe use of this technique in the future for reporting blood pressures to providers in a virtual visit setting. Future research is needed to determine the value of telehealth and home blood pressure self-measurement for individuals with and without risk factors for hypertensive disorders of pregnancy.

While beyond the scope of the current review, home blood pressure monitors and self-measurement have been employed as part of ongoing monitoring for individuals diagnosed with hypertensive disorders of pregnancy. However, existing reviews have highlighted the need for more high-quality studies examining the safety and efficacy of home blood pressure monitoring in this context as well.^114,^ ^116^ One completed feasibility trial (OPTIMUM-BP) of 154 pregnant individuals with chronic or gestational hypertension found no differences in blood pressure or antihypertensive medication use and similar maternal and perinatal outcomes between those utilizing home blood pressure monitoring versus usual clinic monitoring.^117^ Similarly, the BUMP2 randomized trial also examined the use of home blood pressure monitoring in individuals diagnosed with chronic or gestational hypertension and did not find a difference in blood pressure control between the study groups.^104^ Other studies have also focused on the use of postpartum monitoring of individuals identified with hypertensive disorders of pregnancy at or prior to delivery. One randomized trial (N = 206) of postpartum text-messaged based monitoring of home blood pressure readings found greater ascertainment of postpartum blood pressure measurements than in the office-based follow control group.^118^ In addition, while Black participants (N =141) in the usual care (office-based) arm were half as likely to receive office-based blood pressure checks compared with participants of other races (33% versus 70%), this difference was not seen in the text-messaging based arm (91% versus 93%).^119^ Other nonrandomized studies have similarly found that remote blood pressure monitoring can improve postpartum monitoring among individuals with a hypertensive disorder of pregnancy.^120–122^

#### Telehealth Interventions for Screening for Hypertensive Disorders of Pregnancy

Technology-enhanced health care allows health care providers to reach patients outside the office setting using a variety of tools that leverage web and mobile phone capabilities for live audio-visual communication. These can include mobile phone applications (apps) and text messaging, and Bluetooth enabled devices. The term “telehealth” refers to health care delivery enhanced by telecommunication; telehealth and can be used to assist in remote patient assessments (e.g., blood pressure, weight, and capillary blood glucose measures) and clinical diagnosis, as well as in patient education and training.^123^ Telehealth is increasingly recognized as a potential tool for improving maternal health outcomes, and is touted as a possible solution to problems of access to high-quality prenatal care problems experienced by individuals living in rural or medically historically and intentionally disinvested areas. Evidence on the use of telehealth for screening for hypertensive disorders of pregnancy is limited, as highlighted by our current review and others,^111,^ ^123,^ ^124^ and future research could assess its value in prenatal and postpartum care.

A broadly scoped rapid literature review conducted in 2021 provided an overview of several aspects of prenatal care delivery across a range of health conditions.^125^ The review included 53 studies evaluating different components of prenatal care delivery also found limited evidence related to the best approaches to screening for hypertensive disorders of pregnancy. This review identified no differences in health outcomes for patients without a preexisting medical conditions between those who received telehealth visits for routine prenatal care and those who received usual office-based care.^125^ In addition, the review also assessed the accuracy, feasibility, and health effects of home blood pressure measurement in patients with chronic medical conditions, such as diabetes and hypertension. The review supported the conclusion that telemedicine in pregnancy to manage higher-risk patients is promising, but that more evidence is needed.

## Screening for Hypertensive Disorders of Pregnancy in the Context of Racial Inequities in Pregnancy Outcomes in the United States

As discussed, race and ethnicity are social rather than biological designations, but are powerful predictors of health risk. Many social conditions that contribute to worse general health status, including poverty, lack of health insurance, rural residence, and other social and structural determinants of health, are associated with poor birth outcomes regardless of a person’s race or ethnicity. However, Black and AI/AN individuals face particularly high risks for hypertensive disorders of pregnancy and increased risk of morbidity and mortality, even when controlling for a range of other demographic characteristics and comorbidities (see Background section on Health Inequities); accordingly, we focus on Black and AI/AN individuals in this report.^26,^ ^126^ Various structural conditions that contribute to the distribution of health and health care resources in society underlie observed health inequities. The concept of systemic or structural racism refers to the policies and practices that lead to racial inequities in the conditions of living, including housing options,^69^ safety, education, nutrition, and stress levels^63,^ ^126,^ ^127^ and ultimately to inequities in health and well-being.^128^ There is also emerging evidence that exposure to certain contaminants in drinking water,^68^ poor air quality (often due to traffic),^66^ and other historical and persistent features of the built environment^129^ may contribute to the risk of developing hypertensive disorders of pregnancy and related health complications. In addition to structural factors that shape the conditions of life, overt interpersonal racism and implicit bias can lead to mistreatment in health care settings.^57,^ ^58,^ ^130^

### Multilevel and Structural Interventions to Address Inequities in Incidence of Hypertensive Disorders of Pregnancy and Related Morbidity and Mortality

Given the racial and ethnic inequities in the incidence and severity of hypertensive disorders of pregnancy, and the resulting inequal outcomes of pregnancy, there is a need for health care programs to better support Black people in pregnancy and birth, as well as other at-risk populations, including AI/AN people and specific subpopulations within the broader Asian and Hispanic/Latino race/ethnicity categories. Several important projects have been undertaken in recent years to highlight inequities and point toward interventions to address profound inequities in maternal health outcomes for Black and AI/AN people in the United States. First, the National Academies of Sciences, Engineering, and Medicine (NASEM) convened a workshop on advancing maternal health equity and published a report on the proceedings (2021).^130^ Second, the National Quality Forum, funded by the Centers for Medicare and Medicaid Services, published a report on maternal morbidity and mortality measurement (2021).^131^ Finally, and perhaps most comprehensively, the Surgeon General’s Call to Action to Improve Maternal Health (2020) outlines a range of actions that health care professionals, public health institutions, health systems, hospitals, birthing facilities, employers, payors, researchers, states, tribes, and communities should undertake to improve and address inequities in maternal health in the United States.^132^ These reports, and several additional publications providing additional context, were used to define the scope of the problem of racial inequities in hypertensive disorders of pregnancy and related complications.

Given the complex factors that contribute to health inequities,^14,^ ^130,^ ^132^ multilevel interventions are needed to address them. Inequities in chronic conditions that increase the risk for hypertensive disorders of pregnancy for those entering pregnancy must be addressed through interventions that change health trajectories in childhood and early adulthood.^126^ For example, changes to school nutritional programs and development of open spaces for recreation are likely essential to improving health in communities experiencing food insecurity and unsafe neighborhoods, but cannot be addressed at the level of clinical care. The availability of prenatal care services that are accessible and affordable is also likely critical to addressing these inequities but cannot be wholly addressed by individual clinicians or health systems.

### Clinical Interventions to Address Inequities in Incidence of Hypertensive Disorders of Pregnancy and Related Morbidity and Mortality

Screening for hypertensive disorders of pregnancy is a necessary but not sufficient intervention to improve inequities in health outcomes given existing barriers to accessing early and adequate prenatal care. In the absence of interventions to improve preconception health and remove barriers to prenatal care, interventions to change clinical practice will have only partial potential to reduce inequities. Clinicians are at a disadvantage in serving their patients if they are not able to screen for hypertensive disorders of pregnancy until late in pregnancy; this results in missed opportunities to take a clinical history, address patient concerns, and partner with other organizations to offer service supports when needed. In some communities, health care resources are not robust, and healthcare is unaffordable or difficult to access. This makes it difficult to establish ongoing, culturally humble and competent relationships that precede pregnancy and continue across the life course.^126^ Studies of new models of care hold promise for providing patients with better links to clinicians, other pregnant people, and community resources.^133,^ ^134^ Where health care and other community resources are limited, particularly in rural areas, the Surgeon General’s Call to Action to Improve Maternal Health has recommended increases in the number of health care providers and expansion of public insurance eligibility.^132^ Beyond strengthening access to health care, additional interventions applicable to clinical care could be consequential for reducing adverse outcomes.^132,^ ^135^

#### Awareness of HDP Risk

One possible intervention would be to increase clinician awareness of groups with elevated risk of hypertensive disorders of pregnancy and adverse outcomes, such as preeclampsia risks in Black and AI/AN populations, in order to improve dissemination of preventive measures. The USPSTF has recommended that all pregnant Black individuals should be considered for low-dose aspirin to prevent preeclampsia, with aspirin use recommended in those with at least one other moderate risk factor.^51^ Clinicians should also be aware of increased adverse outcome risks of hypertensive disorders of pregnancy for specific populations, such as a two times higher risk of stroke with hypertensive disorders of pregnancy among Black and Hispanic/Latino people compared with White people;^27^ this could encourage clinicians to focus clinical energy and resources to those most likely to suffer morbidity or mortality. Newer initiatives, such as the Maternal Vulnerability Index (https://mvi.surgoventures.org/), may help clinicians access and interpret data on inequities in risk. Local and regional data could also help clinicians focus on the risks to their birthing populations and develop appropriate interventions addressing the local issues driving inequities.^135^

#### Improved Surveillance and Disease Management

Once a hypertensive disorder of pregnancy is detected through screening, ongoing monitoring and evidence-based management of severe hypertension and preeclampsia reduces the risk of adverse pregnancy outcomes.^1^ Race and ethnicity have been found to be associated the likelihood of receiving some recommended treatments.^64,^ ^136^ This likely contributes to the risks for adverse outcomes cited above. Best practices for managing hypertensive disorders of pregnancy can be implemented with clear and standardized clinical bundles, which can help ensure that individuals receive appropriate anti-hypertensive medication, ongoing clinical evaluation of the safety of expectant management or induction of labor, and magnesium sulfate to prevent eclampsia and stroke when indicated.^137,138,139,^ ^140^ Studies of different programs for monitoring people with chronic hypertension or diagnosed with HDP are also important for ensuring the timely delivery of interventions that reduce complication risks. Programs focused on the populations at greatest risk for morbidity and mortality from HDP are particularly important for reducing the burden of disease.

#### Enhanced Attention to Health Risks Emerging Postpartum

Black people and (in fewer studies) Hispanic/Latino people are seen to have increased risk of a hypertension-related hospital readmissions after delivery, due to new-onset or worsening existing hypertension and other complications.^141–143^ Patient presentation is more likely to be symptomatic (e.g., headache, shortness of breath, swelling) and emergent among Black and Hispanic/Latino patients than White patients.^141,^ ^144^ The observed increased risk of postpartum preeclampsia and admissions for hypertensive disorders of pregnancy for Black and Hispanic/Latino individuals warrant consideration of screening and blood pressure monitoring protocols that extend into the postpartum period.^145,^ ^146^ A 2019 systematic review that included 9 observational studies on postpartum monitoring screening for hypertensive disorders of pregnancy and gestational diabetes reported a pattern of lower rates of followup for Black and Hispanic people than White people in the 6 weeks after delivery.^147^ Screening, monitoring, and risk assessment during the postpartum period could be important for reducing health inequities. There is evidence that Black individuals experience a less rapid decrease in blood pressure during the postpartum period than White individuals,^148^ contributing to their risk for readmission.^147^ Despite the evidence that hypertensive disorders of pregnancy can worsen or newly present in the weeks following birth, opportunities to be screened may be diminished due to health provider and insurance transitions, a focus on the neonate, and reduced continuity of support, particularly for populations at greater risk for complications.^147,^ ^149,^ ^150^

Screening for hypertensive disorders of pregnancy has historically been viewed as a focus of prenatal health since delivery usually resolves the condition. The emerging conceptualization of a “fourth trimester” of pregnancy is important for reducing health inequities,^149^ given inequities in postpartum complications and risks of cardiovascular disease following pregnancy that are associated with hypertensive disorders of pregnancy.^130,^ ^151^ Screening and monitoring by a range of providers (nurse midwives, nurses, pediatricians, and lactation consultants), could help prevent serious adverse events and emergencies in the postpartum period.^59^ Policy and practice innovations aimed at improving access to high-quality postpartum care have been identified as important for addressing inequities in maternal morbidity and mortality related to hypertensive disorders of pregnancy.^148,^ ^149^ An ongoing systematic review will address the healthcare strategies for postpartum individuals. Specifically, the review will address the (comparative) benefits and harms of alternative strategies for postpartum healthcare delivery and the extension of postpartum healthcare or health insurance coverage.^152^

#### Attention to Future Cardiovascular Health Risks Associated With HDP

The risk of mortality from cardiovascular disease is also higher among non-Hispanic Black women. As noted in the Background, HDP is a risk factor for the development of cardiovascular disease. To address long term risks associated with hypertensive disorders of pregnancy it is important to educate clinicians who provide primary care about the increased risk of hypertension and cardiovascular disease associated with a history of hypertensive disorder of pregnancy. According to the 2019 American College of Cardiology (ACC)/American Heart Association (AHA) Guideline for primary prevention of cardiovascular disease, history of HDP is now a recognized female-specific risk enhancing factor that should be assessed and utilized to modify the 10-year atherosclerotic cardiovascular disease (ASCVD) clinical risk estimate for adults at borderline (5% to <7.5%) and intermediate (≥7.5% to <20%) ASCVD risk.^153,^ ^154^ Preterm birth is also recognized as an independent predictor of CVD,^154^ and as previously noted, the risk of CVD after HDP is higher among individuals who also experienced a preterm birth. The ACC/AHA emphasizes the importance of lifelong monitoring of cardiovascular risk factors, such as blood pressure and diabetes, among individuals with a history of HDP; early identification of individuals at high risk for cardiovascular events; and the prioritization of patient education about lifestyle modification to reduce risk.^154^ To accurately assess CVD risk, clinicians should incorporate questions regarding their patients’ reproductive history into their preventive health care, including questions about history of hypertensive disorders and preterm birth.

## Limitations of Our Approach

The review scope was developed following USPSTF procedures for evaluating the effectiveness of screening, and thus focused somewhat narrowly on evidence that could isolate the contribution of different screening strategies to the detection of hypertensive disorders of pregnancy, the prevention of adverse health outcomes associated with hypertensive disorders of pregnancy, and potential screening harms. The primary screening test for hypertensive disorders of pregnancy is office-based blood pressure measurement provided at every prenatal care visit, amidst a bundle of other services that can influence health outcomes for hypertensive disorders of pregnancy and other obstetric complications. It is therefore challenging to disentangle the effects of blood pressure screening from other prenatal care co-interventions. We excluded several studies testing prenatal care model interventions that incorporated changes to approaches to screening for hypertensive disorders of pregnancy alongside other care delivery alterations intended to improve pregnancy outcomes (Appendix C). For example, we excluded an RCT evaluating the OB Nest model of care involving a reduced prenatal visit schedule, remote blood pressure measurements, telehealth, nurse support, and an online prenatal community.^133^ Experiments aimed at improving the patient experience of prenatal care, and to ensure ongoing support and recommended screening during pregnancy, may lead to improved outcomes across a range of health conditions that can occur in pregnancy. The condition-specific focus of this clinical evidence review does not allow for more comprehensive consideration of studies examining the effectiveness of different ways of delivering comprehensive prenatal care services which include changes in screening for hypertensive disorders of pregnancy. The literature on monitoring for pregnant individuals with chronic hypertension or those diagnosed with a hypertensive disorder of pregnancy was also outside the scope of this review. The implementation of these interventions may result in a larger impact on maternal and child health than interventions related to initial screening.

## Limitations of the Evidence

There is a mismatch between the small amount of available evidence and the need for improved approaches to screening for hypertensive disorders of pregnancy. We identified very few studies evaluating different strategies for screening. The included evidence was mostly from nearly 20 years ago, some in settings that may not be applicable to the full range of US clinical settings providing primary care in pregnancy and the postpartum period. As presented in the background section of this report, there are stark differences in the risk of hypertensive disorders of pregnancy, and morbidity and mortality related to severe manifestations of these disorders, between Black and AI/AN people and White people, and the available evidence did not provide insight into reducing these inequities. None of the include evidence focused on US Black and AI/AN US populations. In addition, limited public health surveillance data on specific subpopulations within broadly defined racial and ethnic groups (e.g., South Asian and Filipino populations) limits the development of research including or focusing on other groups that may also be at increased risk of hypertensive disorders of pregnancy.

A considerable body of research on hypertensive disorders of pregnancy addresses the clinical pathway after a diagnosis has been made, including the work highlighting the importance of evaluating and monitoring individuals diagnosed with HDP during pregnancy and in the postpartum period.^155,^ ^156^ A much smaller body of evidence has examined different approaches to screening, and no studies have focused on screening in the postpartum period.

The literature we searched included a large body of evidence focused on markers and multivariable models that could be used in early pregnancy to identify people likely to develop preeclampsia.^157^ Many of these studies are referred to in the literature as “screening” investigations, but, strictly speaking, screening tools are used to identify individuals that have a condition, whereas prediction and risk assessment tools are generally used to identify a group of individuals with a greater chance of developing a condition who might benefit from prophylaxis or enhanced screening. To date, there is no good evidence that existing validated prediction models have strong performance across the full range of clinical populations in the United States,^158,^ ^159^ and the potential role of these models in screening for hypertensive disorders of pregnancy has not been established.

## Future Research Needs and Emerging Issues

The bulk of clinical research on hypertensive disorders of pregnancy has focused on prevention and treatment interventions to reduce morbidity and mortality. These efforts are critically important given only a few interventions are available to reduce, but not eliminate, the risk for adverse outcomes from preeclampsia and gestational hypertension. Considerable research has also been devoted to developing and testing risk prediction algorithms, with the aim of determining early in pregnancy who might be most at risk for poor outcomes related to preeclampsia. These algorithms could help to focus clinical attention on patients at high risk. Research on prevention, treatment and risk prediction is more developed, but screening for HDP is remains a key step in the clinical pathway to interventions needed to reduce risks for poor health outcomes. Research and interventions to address health inequities were addressed above. The broader research needs outlined below should be subject to priority setting that would identify areas from above, and from the following list that would be most important for addressing health inequities. Any studies taken to further the science on HDP would be most beneficial to population health if studies enrolled enough participants to be statistically powered to assess important health outcomes and to comparisons among groups with different risk levels, and especially Black and AI/AN individuals who face the highest mortality risk from HDP.

Research on barriers to health care before and during pregnancy is important for increasing the proportion of people entering pregnancy with baseline blood pressure measurements, preeclampsia risk assessment, and low dose aspirin prophylaxis if indicated. Since screening can only improve outcomes if it is used to identify HDP early in its course, before progression to severe features, patients that enter prenatal care at the time of delivery or late in pregnancy are at increased risk for complications.

The development and evaluation of complex interventions for individuals at greatest risk of morbidity and mortality from HDP is needed. Many people enter pregnancy care late and with existing clinical and demographic risk factors/markers of risk for hypertensive disorders. We identified one ongoing trial (Appendix E), informed by a social and structural determinants of health framework, that aims to prevent complications from hypertensive disorders of pregnancy by providing access to resources and supports to reduce social risks and stress (Social Risks-Focused Lifestyle Intervention to Reduce Preeclampsia [SAIL]) in pregnancy. Most behavioral interventions in pregnancy to reduce risks for hypertensive disorders of pregnancy focus on lifestyle factors related to diet and physical activity, and as discussed in the background have not yielded consistent evidence of effectiveness. More broadly framed intervention studies are needed, especially to address health inequities, that incorporate access to health care and preconception health, early prenatal care and community supports during pregnancy, as well as blood pressure screening as part of comprehensive antenatal care.

Studies are needed to help identify optimal, adaptive screening schedules, such that pregnant individuals are not under constant surveillance but are brought into a higher level of care when complications emerge. Hypertensive disorders of pregnancy can emerge unexpectedly and either remain stable or quickly lead to serious health risks. Many clinical practices in obstetrics and prenatal care are based on longstanding historical precedent, founded in clinical observation and trial and error but not necessarily evaluated or updated.^112^ Pregnancy poses unique challenges and opportunities in preventive care and screening since it is time limited and evolves constantly. New experiments like the BUMP study that integrated home blood pressure measurement into prenatal care are needed to identify whether virtual health approaches could strengthen connections between patients and clinical care.

Telehealth interventions have the potential to improve access to care and the opportunity for more ongoing contact over the course of pregnancy, but there is very little evidence available to assess whether specific innovations involving telehealth might improve outcomes or lead to adverse or unintended consequences. Whether telehealth can help to address inequities in health, or will further exacerbate these inequities, also remains to be seen. Natural experiments in telehealth-delivered prenatal care visits during the COVID-19 pandemic may stimulate further research and innovation. Indeed, some ongoing studies may inform the use of telehealth or additional measurements to screen for hypertensive disorders of pregnancy.^160,^ ^161^ We did not include these studies given the number of other changes to health and health care occurring during the pandemic that would introduce confounding.

Research on the basic science of HDP and potential multigenerational effects is ongoing and important to better understand the placenta, signaling pathways, and inflammatory processes remain important in the search for risk markers and treatments.^126^ The complex factors contributing to higher risks for disease among Black and AI/AN people are also important to investigate to inform intervention development. Investigations into the effects of multilevel interventions to improve child and adolescent health on future pregnancy are also needed, given the roles of type II diabetes mellitus, obesity, and chronic hypertension in increasing risk for hypertensive disorders of pregnancy.

Further research on recent changes to the diagnostic criteria of hypertension and preeclampsia is needed to determine whether health outcomes have been improved as a result. Changes to the diagnostic criteria for preeclampsia such that proteinuria is no longer a necessary indicator will change the incidence of preeclampsia. Initial research suggests that while the total number of diagnoses will rise, the increase will be in mild cases,^162^ potentially leading to modest improvements in neonatal outcomes^163^ and improved identification of women with adverse outcomes from the condition that would not have been previously recognized.^164^ Ongoing efforts to evaluate how trends in blood pressure and other measures differ in normal and hypertensive pregnancies are important for establishing meaningful diagnostic thresholds.^165^

Research is needed to evaluate postpartum screening for new onset HDP to ascertain whether this practice could prevent serious complications and mortality from rare but dangerous cases that manifest late. Currently screening for new onset HDP is not usually conducted in the postpartum period, nevertheless the scope of this review was defined such that studies of screening during pregnancy and extending into the postpartum period would have been included. However, while we identified several studies of postpartum monitoring among individuals diagnosed with a hypertensive disorder of pregnancy,^118,^ ^166,^ ^167^ we did not identify any studies of screening among individuals without a diagnosis.^168^ Postpartum preeclampsia cases have been identified as contributing to maternal morbidity and mortality, and the racial inequities discussed above. Research to evaluate screening programs designed to extend beyond the delivery hospitalization would be informative to clinical practice. Innovative approaches to postpartum blood pressure measurement, including home health visits that could include other services or the use of home blood pressure monitoring devices, deserve study.

Studies to further clarify the value and role of proteinuria assessment in prenatal care would potentially contribute to improvements in evidence-based practices. Routine urinalysis using point of care dipstick testing is a common prenatal care practice that has traditionally been used to screen for proteinuria and bacteriuria. The clinical benefits of this practice have not been supported, in part because previous reviews have shown that test accuracy is modest (below 80%).^52,^ ^80,^ ^169^ A urine culture test is recommended to screen for asymptomatic bacteriuria in pregnancy (B recommendation)^170^ and the test performance of routine proteinuria screening has been previously reviewed^52^ and its value in clinical practice questioned.^80^ Only one included study compared routine screening to indicated screening using a non-randomized study with a historical control design.^95^ The study highlights important questions that deserve further study using lower risk of bias study designs, reporting more relevant outcomes, and enrolling a range of diverse patient populations, including large representative samples. Given that the clinical management of gestational hypertension and preeclampsia is similar, leading to heightened surveillance, treatment of severe high blood pressure, induced delivery when indicated, and administration of magnesium sulfate, further research is needed into the screening protocols and diagnostic pathways that are most important for improving clinical outcomes.

Research on the best approaches for blood pressure monitoring for people with chronic hypertension or diagnosed with HDP during pregnancy and postpartum would contribute to the literature on managing the condition and could identify areas for improving outcomes among those at greatest risk for complications. Although beyond the scope of this review, the next step in the clinical pathway from detection and diagnosis of HDP involves monitoring, and actions taken during that phase of disease management affect the health outcomes of screening.

## Conclusions

Screening using blood pressure during pregnancy at every prenatal encounter is a long-standing standard clinical practice that identifies hypertensive disorders of pregnancy; however, morbidity and mortality related to these conditions persists. There is limited evidence available to evaluate different strategies for screening that might ensure more timely identification of hypertensive disorders of pregnancy. Once hypertension is diagnosed, additional surveillance and testing inform the provision of interventions that can reduce the risk of adverse outcomes related to severe hypertension and preeclampsia. None of the studies included in this review identified clear differences in the benefits or harms of different screening strategies or schedules involving home blood pressure measurement, or the approach to urine screening for proteinuria. Large studies are needed to ascertain whether different screening approaches have detectable effects on rare but serious pregnancy outcomes that can develop in people with hypertensive disorders of pregnancy. Individuals with limited access to health care or poor-quality health care, with comorbid health conditions, exposed to toxic environmental or working conditions, and affected by structural racism are at increased risk for complications related to hypertensive disorders of pregnancy, and are also at risk of not being diagnosed, monitored, and intervened upon. Most pregnant people have their blood pressure taken at some point during pregnancy, and for many, a hypertensive disorder of pregnancy is first diagnosed at the time of delivery. Diagnoses made late offer less time for evaluation and stabilization and may limit intervention options. Future implementation research is needed to improve access to regular blood pressure measurement earlier in pregnancy and possibly continuing in the weeks following delivery.