# Chapter 3 Results

## Literature Search

We reviewed 6,316 abstracts and assessed 82 full-text articles for inclusion (Appendix A Figure 1). Overall, we identified six studies (reported in 10 articles)^95–104^ that met our inclusion criteria. A list of included and excluded studies (with reasons for exclusion) are available in Appendix B and Appendix C. Of the six included studies, two were included in the previous review.^95,^ ^96^ We excluded 19 studies that were included in the previous review^52^ because the current review did not include a key question on the test accuracy of urine screening for detecting proteinuria nor did it include a key question on the test performance of preeclampsia predictive models. (See explanation in Methods: Scope and Purpose).

Among the included studies, five met the criteria for KQ1 (perinatal and maternal health outcomes of screening) and KQ2 (preeclampsia or gestational hypertension diagnosis),^95,^ ^96,^ ^98,^ ^99,^ ^104^ and all six met the criteria for KQ3 (harms of screening).^95–99,^ ^104^ Five of the included studies were fair-quality RCTs and one was a fair-quality NRSI with a historical control. Descriptive information on study populations, setting, design, and intervention characteristics for the included studies are provided in Table 1 and Table 2. Three included studies were conducted in the US and three in the UK. Two studies included fewer than 100 participants each, and the others included more than 2000 individuals each.

Table 1 Characteristics of Included Studies, by Intervention Category and Year

Intervention Category | Author, Year; Quality | Country | Design | N | Brief Population Description | Study Years | Screening Intervention | Screening Control
Home blood pressure measurement | Tucker, 2022^104^; Fair | UK | RCT | 2,441 | Pregnant individuals at higher risk of preeclampsia^*^, enrolled at 16 to 24 weeks of gestation | 2018 to 2019 | Standard prenatal visit schedule plus home blood pressure measurement 3 times a week with automated feedback via a mobile-phone application | Standard prenatal visit schedule with blood pressure measurement by usual antenatal care team
Home blood pressure measurement | Ross-McGill, 2000^97^; Fair | UK | RCT | 80 | Low-risk pregnant individuals, enrolled at 24 to 28 weeks of gestation | 1996 to 1997^†^ | Reduced prenatal visit schedule in second half of pregnancy (3 visits) with home blood pressure measurement | Standard visit schedule in the second half of pregnancy (every 2 weeks from 28 to 36 weeks of gestation and weekly thereafter until delivery)
Reduced prenatal visit schedule | Walker, 1997^99^; Fair | US | RCT | 81 | Low-risk pregnant individuals, entered prenatal care before 26 weeks of gestation | 1993 to 1994 | Reduced prenatal visit schedule (8 visits) | Standard prenatal visit schedule (every four weeks until 28 weeks of gestation, every two weeks from 28 to 36 weeks of gestation, weekly thereafter until delivery)
Reduced prenatal visit schedule | McDuffie, 1996^96^; Fair | US | RCT | 2,328 | Low-risk pregnant individuals assessed in first trimester | 1992 to 1994 | Reduced prenatal visit schedule (9 visits) | Standard prenatal visit schedule (14 visits)
Reduced prenatal visit schedule | Sikorski, 1996^98^; Fair | UK | RCT | 2,794 | Low-risk pregnant individuals attending prenatal care by 24 weeks of gestation | 1993 to 1994 | Reduced prenatal visit schedule (7 visits for nullipara, 6 visits for multipara) | Standard prenatal visit schedule (13 visits)
Indicated vs. routine urinary screening | Rhode, 2007^95^; Fair | US | NRSI, historical control | 2,441 | General population accessing prenatal care | 2000 to 2004 | Urinary screening only if preestablished criteria were present^‡^ | Routine urine screening at every prenatal visit

* Age 40 years or older, nulliparity, pregnancy interval of more than 10 years, family history of preeclampsia, previous history of preeclampsia or gestational hypertension, body mass index 30 kg/m^2^ or above at booking for pregnancy care, chronic kidney disease, twin pregnancy, pre-pregnancy diabetes (type 1 or 2), or autoimmune disease (e.g., systemic lupus erythematosus or anti-phospholipid disease).

† https://www.isrctn.com/ISRCTN20643323

‡ First prenatal visit; symptoms of urinary tract infection (dysuria, frequency, pain, fever, etc.); vaginitis symptoms; severe vomiting; weight loss of ≥0.9 kg since previous visit; systolic blood pressure elevated (≥140 mm Hg); diastolic blood pressure elevated (≥90 mm Hg); or any pregnancy requiring periodic urine testing (e.g., chronic hypertension, renal disease).

Abbreviations: NRSI = Non-randomized study of an intervention; RCT = Randomized controlled trial; UK = United Kingdom; US = United States.

Table 2 Population Characteristics, by Intervention Category and Year

Intervention Category | Author, Year | Mean Age | Study-Described Race/Ethnicity | SES Descriptors | History of Hypertensive Disorders of Pregnancy | Pre-Pregnancy Hypertension | Nulli-parous | Multi-fetal Gestation
Home blood pressure measurement | Tucker, 2022^104^ | 32.9 | White (British, Irish, Other): 74%; Asian or Asian British: 10%; Black or Black British: 8%; Other/Mixed: 7% | UK index of multiple deprivation decile: 6.1^*^ | 17% | 0% | 61% | 6%^†^
Home blood pressure measurement | Ross-McGill, 2000^97^ | 28.5 | “Member of an ethnic minority”: 7.5%^‡^ | Employed: 84%; Married: 68% | 0% | 0% | 33% | 0%
Reduced prenatal visit schedule | Walker, 1997^99^ | 25.3 | White: 22%; Hispanic: 74%; Asian American: 1.2% | Born outside United States: 76%; Speak only Spanish: 56%; Employed: 31%; Married: 58%; Insurance: Medicaid (82%), private (10%), uninsured (3%) | 0% | 0% | NR | 0%
Reduced prenatal visit schedule | McDuffie, 1996^96^ | 28.5 | White: 81%; Hispanic: 12%; Black: 4%; Other: 2%^¶^ | Mean years of education: 14.0 | 0%^§^ | 0%^ǁ^ | 49% | 1%
Reduced prenatal visit schedule | Sikorski, 1996^98^ | 28.0 | “Member of an ethnic minority”: 32% | Finished full time education in 16 years: 35%; Living with partner: 81% | 0% | 0% | NR^**^ | 0%
Indicated vs. routine urinary screening | Rhode, 2007^95^ | 24.7 | Hispanic: 75%; White: 19%; Black: 9%; Other: 6%^¶^ | Married: 41%; Single: 56%; Insurance: Medicaid (89%), Uninsured (5%), private (6%) | NR | NR | NR | NR

* Deprivation deciles are the official measure of relative deprivation, with decile 1 representing the most deprived and decile 10 representing the least deprived.

† Twins.

‡ 12.5% in intervention group and 2.5% in control group.

§ History of severe preeclampsia.

ǁ Chronic hypertension at baseline.

¶ No other details reported.

** Mean parity intervention group: 0.9, control group: 0.8.

Abbreviations: NR = Not reported; SES = socioeconomic status; US = United States.

The sources of bias that were most often encountered in the RCT evidence related to group imbalances at baseline, loss to followup, and lack of accounting for these potential sources of bias with appropriate statistical analyses (e.g., adjustment for confounding, imputation). In the historical control NRSI, risk of bias from missing outcome data and loss to followup could not be ascertained due to absent reporting on reasons for missing data or loss to followup by study group, and there was no adjustment for potential confounding.^95^ Studies with historical control designs are also inherently subject to bias from concurrent changes in the environment over time that could affect outcomes.

Three newly identified studies otherwise eligible for inclusion were excluded from the review based on poor quality ratings in risk of bias assessment.^105–107^ One excluded study (SAFE@HOME) conducted in The Netherlands used a case-control design to evaluate home blood pressure and symptom measurement supported by a digital health platform.^105^ It was assessed to have high risk of bias due to confounding, selection, and high attrition in the control group–adjustment for sources of confounding and differences in the characteristics of the case and control populations was not conducted. Two NRSI with historical controls of a change in prenatal care schedule were excluded for risk of bias due to considerable confounding and a lack of information on intervention fidelity–several other changes in practice occurred at the same time as the change in the prenatal visit schedule, limiting the ability to attribute outcomes to the intervention.^106,^ ^107^

The interventions evaluated in the studies were of three general types: the use of screening with home blood pressure measurement to supplement or replace office-based blood pressure measurement in prenatal care (2 RCTs–one included only for harms), reduced prenatal screening visit schedules resulting in fewer blood pressure measurements over the course of pregnancy (3 RCTs), and indicated rather than routine urine screening to detect proteinuria (1 NRSI with a historical control) (Table 1, Appendix D Table 1). These three intervention types will be discussed separately going forward.

## KQ1 How Effective Are Different Screening Programs Used to Identify Hypertensive Disorders of Pregnancy for Reducing Maternal and Perinatal Morbidity and Mortality?

### Summary of Results

A single trial (N = 2,411) of home blood pressure measurement as a supplement to routine prenatal care for pregnant individuals at increased risk for hypertensive disorders of pregnancy did not find differences in the risk of serious maternal or infant health outcomes. One small trial (N = 81) and two larger trials (N = 2,328, N = 2,794) evaluated the effects of having fewer prenatal care visits for low-risk pregnancies, providing limited evidence of the effects of having fewer office-based blood pressure screening tests throughout pregnancy. None of the trials reported statistically significant differences across a range of health outcomes. Estimates from these trials were not precise due to inadequate power, particularly for rare, serious health outcomes. A NRSI study using a historical control to evaluate the implementation of a new program of indicated urine screening reported fewer cases of preterm birth following implementation of the indicated testing intervention but confounding related to the study design limits the interpretation of these results. Both studies of home blood pressure measurement were conducted in the UK, the largest primarily among predominantly White (British, Irish, Other) participants (74%) at increased risk for hypertensive disorders of pregnancy. The study population in the large US trial of reduced prenatal visit schedules was described as predominantly White (81%) and Hispanic (12%). The study of indicated urine screening was predominantly Hispanic (75%) and White (19%) and was conducted in a setting with risks related to social and structural determinants of health (majority public insurance or uninsured, lower income). The available evidence precludes conclusions about the effects these interventions would have for Black and AI/AN populations, which face the greatest risk for hypertensive disorders of pregnancy and adverse outcomes in the US.

### Included Studies

#### Home Blood Pressure Screening

One fair-quality RCT conducted in the UK evaluated home blood pressure measurement three times a week to supplement routine prenatal care among individuals at increased risk for preeclampsia.^104,^ ^108^ The Blood Pressure Monitoring in High Risk Pregnancy to Improve the Detection and Monitoring of Hypertension (BUMP) trial enrolled 2,441 pregnant people at increased risk of a hypertensive disorder of pregnancy based on common clinical risk factors (e.g., nulliparity, age, pregnancy, family history, previous preeclampsia, BMI ≥ 30kg/m^2^, twin pregnancy, diabetes, etc.). The trial (conducted from 2018 to 2019) evaluated an intervention of home blood pressure measurement three times a week supported by a telemonitoring mobile-phone-based application that generated automated feedback; this intervention supplemented the standard British office-based prenatal care visit schedule. Participants were randomized 1:1 to the intervention or a comparison arm that received standard prenatal care consisting entirely of the standard office-based prenatal care schedule. In addition to receiving materials and training for home blood pressure measurement, intervention participants were provided with the mobile-phone-based telemonitoring application. The application was used to record blood pressure measurements and transmit them to a central database which generated automated feedback, reminders, requests for additional readings to be submitted, or instructions to contact their health care provider in cases where persistently low (110-134/70-84mmHg) or high (≥135/85mmHg) readings occurred.^104^

Participants were enrolled between 16 and 24 weeks of gestation.^104^ Almost two-thirds of participants were nulliparous (61%), but a substantial percentage were multiparous and also had a history of a hypertensive disorder of pregnancy (~17%). Over five percent of participants were carrying a multifetal pregnancy. This trial was also comprised mostly of White (British, Irish, Other) participants (74%); it included smaller percentages of participants identifying as Asian or Asian British (10%), Black or Black British (8%), or selecting “Other” or “Mixed” race or ethnicity (7%, not further specified in the study report). Participants were described as having on average a middle-level socioeconomic position based on UK index of multiple deprivation decile; the mean age of participants was 33 years. Adherence with blood pressure self-measurement in the intervention group was nearly 77 percent.^104^

#### Reduced Prenatal Screening Visit Schedules

Three fair-quality RCTs, all conducted over 20 years ago, aimed to evaluate the effect of fewer prenatal visits for individuals considered to be at low risk for pregnancy complications. These studies provide limited evidence on the potential effect of having fewer blood pressure measurements over the course of pregnancy, since the reduced visit schedule also reduced opportunities for participants to obtain other prenatal care visit evaluations and counseling. One trial assessed pregnancy risk and study eligibility in the first trimester,^96^ and the other two trials included eligible individuals entering prenatal care by week 24^98^ and week 26^99^ of gestation. A small US-based trial (N = 81) aimed to assess an eight-visit prenatal care schedule,^99^ and a larger US-based trial (N = 2,328) evaluated the effects of a nine-visit prenatal care schedule; both were compared with a standard visit schedule that would result in approximately 14 visits (depending on the timing of delivery).^96^ A UK trial (N = 2,794) compared a reduced visit schedule consisting of 7 visits for nullipara and 6 visits for multipara to a standard prenatal care schedule of approximately 13 visits.^98^

The small US-based RCT included primarily Hispanic (74%) and White (22%) participants.^99^ Over half of the study population (56%) spoke only Spanish and most had Medicaid health insurance (82%). Study participants were assessed to be at low risk for pregnancy complications when entering prenatal care prior to 26 weeks of gestation. The larger US trial enrolled primarily White participants (81%) and smaller percentages of Hispanic (12%), Black (4%), and unspecified “Other” (2%) participants.^96^ The included participants were assessed to be at low for risk of pregnancy complications during the “first trimester” of pregnancy. About half of study participants were nulliparous (49%). There was limited information on measures of socioeconomic status; the population had on average 14 years of education.

The large UK trial (N = 2,794) enrolled participants at low risk for pregnancy complications that were receiving prenatal care by 24 weeks of gestation.^98^ The study provided very little information to describe the study population. One-third of participants (32%) were described as “ethnic minority,” approximately one-third (35%) had “finished a full-time education in 16 years”, and most (81%) were living with a partner.

In all three of these trials, the difference in the overall number of visits between arms was smaller than intended by the trials design. The difference in the number of visits between groups ranged from 2.2^98^ to 3.2.^99^

#### Indicated Rather Than Routine Urine Screening for Proteinuria

One fair-quality non-randomized study (N = 2,441) conducted in the United States enrolled pregnant individuals obtaining prenatal care before and after implementation of a change in clinical practice at a hospital-based midwifery practice. From November 2000 to August 15, 2002, prenatal care included routine urine screening at every visit. Beginning on August 15, 2002 and continuing through March 2004, these same clinical sites implemented a program of indicated urine screening. During the period of indicated screening, urine tests were conducted at the first prenatal visit, and at subsequent visits for a range of indications, including patient complaint of urinary tract infection symptoms, severe vomiting or weight loss, or elevated blood pressure (see Appendix D Table 2 for further details). Race and/or ethnicity data were self-reported by patients at the first prenatal visit. Three-quarters of the study population identified as Hispanic (75%), the remaining quarter identified as either White (19%), Black (9%), or “other” (6%, not described in further detail). Over half of the population was described as “Single” (56%) and the remainder as “Married” (41%). Most included patients had Medicaid health insurance (89%) or no health insurance (5%). The mean (SD) number of urine dipstick tests patients received was 7.8 (3.4) in the routine screening period was and 1.4 (1.3) in the indicated screening period. The range of tests received was 0 to 19 for the routine screening group and 0 to 16 for the indicated screening group. The most frequently reported reasons for indicated screening were elevated blood pressure or preeclampsia related symptoms (36%) and urinary tract infection or vaginitis symptoms (32%).

### Detailed Results by Intervention

#### Home Blood Pressure Measurement Interventions

Relevant outcomes for KQ1 reported in the BUMP trial (N = 2,441) were maternal mortality, maternal health complications related to hypertensive disorders of pregnancy (i.e., eclampsia, transient ischemic attack, stroke, HELLP syndrome, pulmonary edema), early neonatal mortality, stillbirth, and IUGR/SGA. The rarity of the most serious outcomes (e.g., mortality, stroke) prevented inferences regarding the absence or presence of intervention effects because of limited statistical power. (Table 3). There were slightly fewer maternal complications related to hypertensive disorders of pregnancy in the home measurement group (15/1209; 1.2%) than in the usual care group (19/1209; 1.6%). However, the confidence interval for this modest estimated effect crossed null (RR 0.79 [95% CI, 0.40 to 1.55]). More cases of IUGR/SGA occurred in the intervention group (104/1249, 8.3%) than in the control group (87/1235, 7.0%), but the confidence interval again spanned null in the study-reported adjusted analysis (adjusted RR 1.15 [95% CI, 0.87 to 1.53]).

Table 3 KQ1: Health Outcomes, by Intervention Category

Intervention Category | Author, Year | Outcome | IG Events (%) | CG Events (%) | IG vs. CG
Home blood pressure measurement | Tucker, 2022^104^ | Maternal mortality | 0/1171 (0%) | 0/1175 (0%) | NA
Home blood pressure measurement | Tucker, 2022^104^ | One or more serious maternal health complications related to HDP^*^ | 15/1209 (1.2%) | 19/1209 (1.6%) | RR: 0.79 (95% CI, 0.40 to 1.55)^†^
Home blood pressure measurement | Tucker, 2022^104^ | Neonatal mortality | 2/1248 (0.2%) | 0/1240 (0%) | NA
Home blood pressure measurement | Tucker, 2022^104^ | Stillbirth | 5/1260 (0.4%) | 3/1248 (0.2%) | RR: 1.65 (95% CI, 0.40 to 6.89)^†^
Home blood pressure measurement | Tucker, 2022^104^ | IUGR/SGA (<10^th^ percentile) | 104/1249 (8.3%) | 87/1235 (7.0%) | Adj RR: 1.15 (95% CI, 0.87 to 1.53)^‡^
Reduced prenatal visit schedule | Walker, 1997^99^ | Miscarriage/fetal loss (<20 weeks of gestation) | 0/61 (0.0%) | 4/61 (6.6%) | NA
Reduced prenatal visit schedule | Walker, 1997^99^ | Preterm delivery (<37 weeks of gestation) | 5/43 (11.6%) | 2/38 (5.3%) | RR: 2.21 (95% CI, 0.45 to 10.7)^†^
Reduced prenatal visit schedule | Walker, 1997^99^ | Neonatal sepsis | 1/43 (2.3%) | 0/38 (0.0%) | NA
Reduced prenatal visit schedule | Walker, 1997^99^ | Neonatal respiratory distress | 3/43 (7.0%) | 0/38 (0.0%) | NA
Reduced prenatal visit schedule | Walker, 1997^99^ | IUGR/SGA (<10^th^ percentile) | 0/43 (0.0%) | 1/38 (2.6%) | NA
Reduced prenatal visit schedule | McDuffie, 1996^96^ | Postpartum hemorrhage^§^ | 34/1165 (2.9%) | 36/1163 (3.1%) | RR: 0.94 (95% CI, 0.59 to 1.50)^†^
Reduced prenatal visit schedule | McDuffie, 1996^96^ | Placental abruption | 17/1165 (1.5%) | 11/1163 (0.9%) | RR: 1.21 (95% CI, 0.90 to 1.64)
Reduced prenatal visit schedule | McDuffie, 1996^96^ | Stillbirth/neonatal mortality | 5/1175 (0.4%) | 5/1176 (0.4%) | RR: 1.00 (95% CI, 0.54 to 1.86)
Reduced prenatal visit schedule | McDuffie, 1996^96^ | Early preterm delivery (<32 weeks) | 10/1165 (0.9%) | 8/1163 (0.7%) | RR: 1.11 (95% CI, 0.73 to 1.68)
Reduced prenatal visit schedule | McDuffie, 1996^96^ | Preterm delivery (<37 weeks) | 73/1165 (6.3%) | 63/1163 (5.4%) | RR: 1.08 (95% CI, 0.92 to 1.27)
Reduced prenatal visit schedule | McDuffie, 1996^96^ | Very low birth weight (<1500g) | 7/1175 (0.3%) | 6/1176 (0.3%) | RR: 1.08 (95% CI, 0.65 to 1.79)
Reduced prenatal visit schedule | McDuffie, 1996^96^ | Low birth weight (<2500g) | 64/1175 (5.4%) | 72/1176 (6.1%) | RR: 0.94 (95% CI, 0.78 to 1.12)
Reduced prenatal visit schedule | McDuffie, 1996^96^ | IUGR/SGA (<10^th^ percentile) | 36/1175 (3.1%) | 28/1176 (2.4%) | RR: 1.13 (95% CI, 0.91 to 1.41)
Reduced prenatal visit schedule | Sikorski, 1996^98^ | Maternal mortality | 1/1359 (0.1%) | 0/1396 (0.0%) | NA
Reduced prenatal visit schedule | Sikorski, 1996^98^ | Postpartum hemorrhage | 135/1358 (9.9%) | 137/1390 (9.9%) | RR: 1.01 (95% CI, 0.80 to 1.26)^†^
Reduced prenatal visit schedule | Sikorski, 1996^98^ | Antepartum hemorrhage | 70/1360 (5.1%) | 74/1391 (5.3%) | RR: 0.97 (95% CI, 0.70 to 1.33)^†^
Reduced prenatal visit schedule | Sikorski, 1996^98^ | Stillbirth/neonatal mortality | 7/1361 (0.5%) | 10/1396 (0.7%) | RR: 0.72 (95% CI, 0.27 to 1.88)^†^
Reduced prenatal visit schedule | Sikorski, 1996^98^ | IUGR/SGA (<3^rd^ percentile) | 94/1355 (6.9%) | 113/1393 (8.1%) | RR: 0.86 (95% CI, 0.66 to 1.11)^†^
Reduced prenatal visit schedule | Sikorski, 1996^98^ | IUGR/SGA (<10^th^ percentile) | 277/1355 (20.4%) | 302/1393 (21.7%) | RR: 0.94 (95% CI, 0.82 to 1.09)^†^
Indicated vs. routine urinary screening | Rhode, 2007^95^ | Preterm delivery^ǁ^ | 50/1019 (4.9%) | 72/933 (7.7%) | RR: 0.64 (95% CI, 0.45 to 0.90)^†^

* Eclampsia, transient ischemic attack, or stroke, HELLP syndrome, liver involvement (ALT or AST >70 U/L), pulmonary edema, renal involvement (creatinine ≥90 mmol), or hematological involvement (platelets <x100^9/L).

† Calculated.

‡ Adjusted for group, parity, and site.

§ Defined as >750 mL for vaginal birth and >1500 mL for cesarean birth.

ǁ p-value for equivalence = 0.14 (A p-value <0.05 indicates that rates are equivalent at a statistically significant level.)

Abbreviations: CG = Control group; CI = Confidence interval; HDP = Hypertensive disorders of pregnancy; IG = Intervention group; IUGR/SGA = Intrauterine growth restriction/small for gestational age; NA = Not applicable; RR = Relative risk.

#### Reduced Prenatal Screening Visit Schedules

The three included trials of reduced prenatal visits schedules did not report a consistent set of health outcomes. The large UK trial (N =2,794) was the only trial to report maternal mortality, with one case occurring in the reduced visit schedule study arm (1/1359; 0.1%) and no cases occurring in the control arm.^98^ The case was a multiparous woman with a postnatal cerebrovascular event who had attended 20 antenatal visits. Measures of perinatal mortality were reported in all three studies but were defined differently across studies as miscarriage or fetal loss;^99^ stillbirth or neonatal mortality after 20 weeks of gestation;^96^ and stillbirth or perinatal mortality.^98^ No cases of miscarriage or fetal loss occurred in the intervention group and four cases (4/61; 6.6%) occurred in the routine care group in the small US trial (N = 81). In the large US trial (N=2,328), five cases of stillbirth or neonatal mortality were reported in each study group (RR 1.00 [95% CI, 0.54 to 1.86]). In the large UK trial, there was a similar incidence of stillbirth/perinatal mortality in the reduced visit group (7/1361; 0.5%) and the routine visit group (10/1396; 0.7%) and the confidence interval contained null, though the study was underpowered for this rare outcome (RR 0.72 [95% CI, 0.27 to 1.88]).^98^

Preterm delivery was reported in the two US trials. The larger trial (N = 2,328) reported slightly more cases of preterm delivery (<37 weeks of gestation) in the reduced visit intervention (73/1165; 6.3%) than in the routine visit control group (63/1163; 5.4%) but the confidence interval for the estimated relative risk crossed null (RR 1.08 [96% CI 0.92 to 1.27]).^96^ Due to limited power, the small US trial (N = 81) did not support effect inferences.^99^

In the large US trial, the risk of IUGR/SGA (<10^th^ percentile) was not statistically different between study groups (RR 1.13 [95% CI, 0.91 to 1.41]) but there were more cases in the reduced visit intervention (36/1175; 3.1%) than the routine visit control group (28/1176; 2.4%).^96^ The large UK trial also reported IUGR/SGA (<10^th^ percentile) and also reported no statistically significant difference (RR 0.94 [95% CI, 0.82 to 1.09]), but with slightly fewer cases in the reduced visit intervention group (277/1355; 20.4%) than the routine visit control group (302/1393; 21.7%).^98^ The risk for low birthweight (<2500 grams) was reported in the US trial and was similar between groups (RR 0.94 [95% CI, 0.78 to 1.12]), with a few more cases occurring in the reduced visit intervention group (64/1175; 5.4%) than the routine visit control group (72/1176; 6.1%).^96^ Other infant health outcomes reported in the small US trial were rare, and differences in risk could not be estimated with any statistical precision.^99^

Placental abruption was reported in the large US trial. Similar to other rare outcomes, differences between groups were small and not statistically significant (RR 1.21 [95% CI, 0.90 to 1.64]),^96^ with events slightly more common in the reduced visit group (17/1165; 1.5%) than the routine visit control group (11/1163; 0.9%). The risk of postpartum hemorrhage was similar in the two large trials, with estimates close to null: rates of postpartum hemorrhage were numerically lower with the reduced visit schedule in the US study (RR 0.94 [95% CI, 0.59 to 1.50])^96^ and nearly the same across groups in the UK study (RR 1.01 [95% CI, 0.80 to 1.26]).^98^

#### Indicated Rather Than Routine Urine Screening for Proteinuria

The NRSI with a historical control (N=2,441) of indicated versus routine urine screening reported on preterm delivery rates, but not other health outcomes. Preterm delivery rates were lower for births occurring in the period with indicated urine screening (50/1019; 4.9%) than the routine urine screening period (72/933; 7.7%) and the 95 percent confidence interval for the relative risk of preterm delivery ranged from a 55 percent reduction to a 10 percent reduction in risk (RR 0.64 [95% CI, 0.45 to 0.90]). The study was designed and analyzed to test for non-inferiority between groups; the one-sided test showed that preterm birth was not equivalent between groups and was not worse with indicated screening. Given the risk of bias inherent to historically controlled studies, however, these results may be due to factors other than the change in screening approach.

## KQ2 How Effective Are Different Screening Programs for Identifying People With Hypertensive Disorders of Pregnancy?

### Summary of Results

The large trial (N = 2,441) of home blood pressure measurement in addition to usual prenatal care for individuals at increased risk for preeclampsia reported similar rates of gestational hypertension and preeclampsia in the intervention arm than the usual care only arm. More cases of preeclampsia with severe features were diagnosed in the home blood pressure measurement group than the control group, but the difference in risks was not statistically significant. The three trials that assigned participants to reduced prenatal care visit schedules did not identify differences between groups in the proportion of participants receiving a diagnosis of preeclampsia, although only one of the US trials (N = 2,328) reported adequate numbers of participants and events for estimation of effects with reasonable precision. For preeclampsia with severe features, the large US trial reported similar proportions diagnosed across arms (<1%), but confidence intervals were wide for this rare outcome. The NRSI with a historical control did not find a difference in the incidence of hypertensive disorders of pregnancy during the time periods with indicated versus routine urine screening. Overall, the different screening programs did not reduce or increase diagnoses of hypertensive disorders of pregnancy. Presumably, all cases were detected by the end of pregnancy; only one study compared the timing of diagnosis between study arms, it did not find a clinically important difference. It is unclear whether these results are discordant or concordant with the results for health outcomes, given a lack of precision for the most serious outcomes, which are rare.

### Included Studies

Key question 2 included the same 5 studies described in Key Question 1.^95,^ ^96,^ ^98,^ ^99,^ ^104^

### Detailed Results by Intervention

#### Home Blood Pressure Measurement Interventions

The BUMP trial (N = 2,441) reported rates of hypertension, severe hypertension, and preeclampsia (Table 4). The proportion of participants developing hypertension during pregnancy was approximately the same in the intervention group (15.3%) and the control group (15.7%) and the proportion of diagnoses of preeclampsia was the same in both groups (4.2%). Confidence intervals for the estimation of no difference between groups for these outcomes contained null, and the study was not powered to detect small differences. Despite the addition of home blood pressure measurements, there was no evidence for a clinically meaningful difference in the mean days to clinical detection of a hypertensive disorder of pregnancy between the intervention (104.3 days) and control group (106.2 days; mean difference −1.58 days [95% CI, −8.10 to 4.94]). Time to diagnosis was the primary outcome of this study since a screening intervention was not expected to change the overall prevalence of hypertensive disorders of pregnancy. There was not a statistical difference in the incidence of severe hypertension in the intervention group (6.0%) and the control group (4.9%), and the estimated relative risk was imprecise with a wide confidence interval spanning null (RR 1.22 [95% CI, 0.87 to 1.70]).

Table 4 KQ2: Intermediate Outcomes, by Intervention Category

Intervention Category | Author, Year | Outcome | IG Events (%) or Mean (SD) | CG Events (%) or Mean (SD) | IG vs. CG
Home blood pressure measurement | Tucker, 2022^104^ | HDP^*^ | 179/1171 (15.3%) | 184/1175 (15.7%) | RR 0.98 (95% CI, 0.81 to 1.18)^†^
Home blood pressure measurement | Tucker, 2022^104^ | Days to detection of HDP | 104.3 (32.6) | 106.2 (32.0) | Mean difference: −1.58 (95% CI, −8.10 to 4.94), p= 0.64^‡^
Home blood pressure measurement | Tucker, 2022^104^ | Preeclampsia | 51/1209 (4.2%) | 51/1209 (4.2%) | RR 1.00 (95% CI, 0.66 to 1.51)
Home blood pressure measurement | Tucker, 2022^104^ | Severe hypertension^§^ (professionally measured) | 69/1171 (6.0%) | 57/1175 (4.9%) | RR 1.22 (95% CI, 0.87 to 1.70)
Reduced prenatal visit schedule | Walker, 1997^99^ | Preeclampsia | NR | NR | NS
Reduced prenatal visit schedule | Walker, 1997^99^ | Gestational hypertension | 2/43 (4.7%) | 1/38 (2.6%) | RR 1.77 (95% CI, 0.17 to 18.7)^ǁ^
Reduced prenatal visit schedule | McDuffie, 1996^96^ | Preeclampsia^¶^ | 59/1165 (5.1%) | 66/1163 (5.7%) | RR 0.94 (95% CI, 0.78 to 1.14)
Reduced prenatal visit schedule | McDuffie, 1996^96^ | Preeclampsia with severe features^**^ | 10/1165 (0.9%) | 9/1163 (0.8%) | RR 1.05 (95% CI, 0.68 to 1.62)
Reduced prenatal visit schedule | Sikorski, 1996^98^ | Preeclampsia^††^ | 9/1240 (0.7%) | 11/1286 (0.9%) | RR 0.85 (95% CI, 0.35 to 2.04)^ǁ^
Indicated vs. routine urinary screening | Rhode, 2007^95^ | HDP | 81/1019 (7.9%) | 74/933 (7.9%) | RR 1.00 (95% CI, 0.74 to 1.36)^ǁ^
Indicated vs. routine urinary screening | Rhode, 2007^95^ | Preeclampsia^‡‡^ | 23/1019 (2.3%) | 36/933 (3.8%) | RR 0.58 (95% CI, 0.35 to 0.98)^§§^
Indicated vs. routine urinary screening | Rhode, 2007^95^ | Gestational hypertension^ǁǁ^ | 58/1019 (5.7%) | 38/933 (4.1%) | RR 1.40 (95% CI, 0.94 to 2.08)^ǁ¶¶^

* Defined as sustained high blood pressure (2+ readings within 1 week) recorded in the clinical record, a recorded diagnosis of hypertension (including preeclampsia or gestational hypertension), or prescription of antihypertensive medication for raised blood pressure.

† Calculated RR. Study-reported adjusted (site, parity) hurdle effect: −0.02 (95% CI, −0.15 to 0.10). Difference in probability: 0.00 (95% CI, −0.03 to 0.02); p=0.751.

‡ Adjusted for group, parity (0 or ≥1), and site as fixed effects.

§ Systolic blood pressure ≥160 mm Hg and/or diastolic blood pressure ≥110 mm Hg.

ǁ Calculated.

¶ Mild preeclampsia was defined as a blood pressure measurement of 140/90 mm Hg or a blood pressure rise of 30/15 mm Hg over first-trimester levels accompanied by significant proteinuria (>300 mg/24 h) or edema (weight gain, >2.25 kg in 1 week).

** Blood pressure measurement of 160/110 mm Hg, more than 5 g of urinary protein in 24 hours, oliguria, thrombocytopenia, or elevated liver function test findings.

†† Defined according to the criteria of the International Society for the Study of Hypertension in Pregnancy.

‡‡ Defined by at least 1 elevated blood pressure (>140/90 mm Hg) and proteinuria of any type, a discharge diagnosis of preeclampsia, or received magnesium sulfate during labor for preeclampsia-related signs or symptoms.

§§ Study-reported test for group equivalence: p = 0.0011. A p-value <0.05 indicates that rates are equivalent at a statistically significant level.

ǁǁ Gestational hypertension was defined by only 1 elevated blood pressure (>140/90 mm Hg). Confirmation of return to normal blood pressure by 12 weeks postpartum was not possible within the study.

¶¶ Study-reported test for group equivalence: p < 0.0001. A p-value <0.05 indicates that rates are equivalent at a statistically significant level.

Abbreviations: CI = Confidence interval; CG = Control group; HDP = Hypertensive disorders of pregnancy; IG = Intervention group; RR = Relative risk; SD = Standard deviation.

#### Reduced Prenatal Screening Visit Schedules

The small US RCT (N = 81) lacked statistical power to estimate group differences.^99^ The large US RCT (N = 2,328) reported similar proportions of preeclampsia cases in the reduced visit intervention group (59/1165; 5.1%) and the usual care control group (66/1163; 5.7%).^96^ The confidence interval for the relative risk of preeclampsia contained null and ranged from a 22 percent reduced risk to a 14 percent increased risk of detection (RR 0.94 [95% CI, 0.78 to 1.14]). Cases of preeclampsia with severe features were more uncommon overall, and a similar number occurred in the intervention (10/1165, 0.9%) and control groups (9/1163, 0.8%). The estimate of relative risk suggested a null effect, but the confidence interval was wide for this rare outcome (RR 1.05 [95% CI, 0.68 to 1.62]).^96^ The large UK trial (N = 2,794) reported preeclampsia diagnoses, but rates were very low in the study population, with fewer than one percent of participants having the outcome, and the intervention effect was imprecisely estimated (RR 0.85 [95% CI, 0.35 to 2.04]).^98^

#### Indicated Rather Than Routine Urine Screening for Proteinuria

There was no difference in the proportion of individuals diagnosed with a hypertensive disorder of pregnancy following the implementation of indicated urine screening (RR 1.00 [95% CI, 0.74 to 1.36]), but there was a trend toward fewer diagnoses of preeclampsia (RR 0.58 [95% CI, 0.35 to 0.98] and more diagnoses of gestational hypertension (RR 1.40 [95% CI, 0.94 to 2.08]) following implementation. Given the risk of bias inherent to historically controlled studies, however, these results may be due to factors other than the change in screening approach.

## KQ3 What Are the Harms of Different Screening Programs Used to Identify Hypertensive Disorders of Pregnancy?

### Summary of Results

The screening programs assessed for harms in this review are non-invasive, but new screening programs could result in unforeseen consequences related to the identification and management of hypertensive disorders of pregnancy or changes to the patient experience during pregnancy that could influence mental health outcomes such as anxiety or depression. Mode of delivery (Cesarean, induction) was included as a potential harm given the hypothetical risk that new screening programs could result in different medical decisions. Interpretation of these outcomes, however, is not straightforward since Cesarean delivery and induction of labor in some cases would reflect appropriate case management that would reduce risks for other adverse outcomes. Thus, these outcomes cannot be interpreted in isolation. Two home blood pressure measurement screening studies reported on harms: one trial reported emergency Cesarean delivery and both trials reported anxiety. Results were not suggestive of harms associated with the intervention. No differences in reported Cesarean delivery or anxiety and depression during or after pregnancy were reported in three trials testing interventions of reduced prenatal care visits. The NRSI historical control study of indicated urine screening also did not find different rates of Cesarean delivery following the change in practice from routine screening. Overall, there was no evidence that different strategies for screening for hypertensive disorders of pregnancy resulted in serious or significant harms. Trials included for evaluating harms, however, included few participants belonging to the populations at greatest risk for adverse consequences of hypertensive disorders of pregnancy in the US.

### Included Studies

Key question 3 included the same 5 studies described in Key Question 1^95,^ ^96,^ ^98,^ ^99,^ ^104^ and one additional study (Tables 5 and 6). The additional study was a fair-quality study of home blood pressure measurement^97^ conducted in the UK, which enrolled 80 participants at low risk for hypertensive disorders of pregnancy between 24 and 28 weeks of gestation and randomly assigned them to an intervention that reduced the number of prenatal visits in the second half of pregnancy (3 visits) but provided participants with training and instructions to conduct weekly home blood pressure screening, or a comparison group that received care according to a standard care prenatal visit schedule that involved more frequent office visits in the second half of pregnancy. The number of pregnancy-related visits to the general practitioner or midwife clinics was reduced in the intervention group (3.2 vs 5.6). Due to home measurement of blood pressure, the intervention group received blood pressure screens in more weeks overall (8.9 weeks vs 6.9 weeks).

Table 5 KQ3: Delivery Outcomes, by Intervention Type

Intervention Category | Author, Year | Outcome | IG | CG | IG vs. CG
Home blood pressure measurement | Tucker, 2022^104^ | Induction or cesarean delivery for hypertension-related complication | 92/1187 (7.8%) | 84/1181 (7.1%) | RR 1.09 (95% CI, 0.82 to 1.45)^*^
Home blood pressure measurement | Tucker, 2022^104^ | Emergency cesarean delivery | 250/1259 (19.9%) | 278/1244 (22.3%) | RR 0.89 (95% CI, 0.76 to 1.03)^*^
Reduced prenatal visit schedule | Walker, 1997^99^ | Cesarean delivery | 0/43 (0%) | 3/38 (7.9%) | NA
Reduced prenatal visit schedule | McDuffie, 1996^96^ | Cesarean delivery | 151/1165 (13.0%) | 140/1163 (12.0%) | RR 1.04 (95% CI, 0.93 to 1.17)
Reduced prenatal visit schedule | McDuffie, 1996^96^ | Cesarean delivery for fetal distress | 23/1165 (2.0%) | 26/1163 (2.2%) | RR 0.94 (95%: 0.69 to 1.27)
Reduced prenatal visit schedule | Sikorski, 1996^98^ | Induction related to pregnancy-related hypertension | 33/1358 (2.4%) | 37/1395 (2.7%) | RR 0.92 (95% CI, 0.58 to 1.46)^*^
Reduced prenatal visit schedule | Sikorski, 1996^98^ | Cesarean delivery for pregnancy-related hypertension | 11/1359 (0.8%) | 14/1396 (1.0%) | RR 0.81 to (95% CI, 0.37 to 1.77)^*^
Reduced prenatal visit schedule | Sikorski, 1996^98^ | Induction of labor for any reason | 244/1359 (18.0%) | 236/1395 (16.9%) | RR 1.06 (95% CI, 0.90 to 1.25)^*^
Reduced prenatal visit schedule | Sikorski, 1996^98^ | Cesarean delivery for any reason | 189/1360 (13.9%) | 215/1396 (15.4%) | RR 0.90 (95% CI, 0.75 to 1.08)^*^
Indicated vs. routine urinary screening | Rhode, 2007^95^ | Cesarean delivery | 181/1019 (17.8%) | 173/933 (18.5%) | RR 0.96 (95% CI, 0.79 to 1.16)^*^,^†^

* Calculated.

† Study-reported test for group equivalence: p = 0.029. A p-value <0.05 indicates that rates are equivalent at a statistically significant level.

Abbreviations: CI = Confidence interval; CG = Control group; HDP = Hypertensive disorders of pregnancy; IG = Intervention group; NA = Not applicable; RR = Relative risk.

Table 6 KQ3: Mental Health and Quality-of-Life-Related Screening Harms, by Intervention Type

Inter-vention category | Author, Year | Outcome | Time Point | IG N | IG Mean (SD or 95% CI) | CG N | CG Mean (SD or 95% CI) | IG vs. CG
Home blood pressure measurement | Tucker, 2022^104^ | Anxiety (STAI-6 short form)^*^ | Baseline | 1,203 | 23.4 (18.18) | 1,191 | 23.2 (18.00) | NA
Home blood pressure measurement | Tucker, 2022^104^ | Anxiety (STAI-6 short form)^*^ | 30 weeks of gestation | 884 | 25.5 (18.49) | 881 | 27.0 (20.11) | Adjusted Mean Difference: −1.45 (95% CI, −3.11 to 0.22)^†^
Home blood pressure measurement | Tucker, 2022^104^ | Anxiety (STAI-6 short form)^*^ | Postpartum (12 months after baseline) | 672 | 23.3 (19.93) | 688 | 24.6 (20.96) | Adjusted Mean Difference: −1.37 (95% CI, −3.25 to 0.51)^‡^
Home blood pressure measurement | Tucker, 2022^104^ | HRQoL measured by EQ-5D-5L^§ǁ^ | Baseline | 1,202 | 0.870 (0.148) | 1,194 | 0.862 (0.148) | NA
Home blood pressure measurement | Tucker, 2022^104^ | HRQoL measured by EQ-5D-5L^§ǁ^ | 30 weeks of gestation | 875 | 0.783 (0.166) | 897 | 0.767 (0.184) | Adjusted Mean Difference: 0.012 (95% CI, −0.002 to 0.026)^¶^
Home blood pressure measurement | Tucker, 2022^104^ | HRQoL measured by EQ-5D-5L^§ǁ^ | Postpartum (12 months after baseline) | 660 | 0.859 (0.158) | 669 | 0.853 (0.160) | Adjusted Mean Difference: 0.004 (95% CI, −0.011 to 0.019)^**^
Home blood pressure measurement | Ross-McGill, 2000^97^ | Anxiety (STAI)^††^ | 28 weeks of gestation | 40 | 37 (95% CI, 34 to 40) | 39 | 37 (95% CI, 34 to 40) | Mean Difference: 0 (95% CI, −4.31 to 4.31)^‡‡^
Home blood pressure measurement | Ross-McGill, 2000^97^ | Anxiety (STAI)^††^ | 34 weeks of gestation | 32 | 36 (95% CI, 32 to 40) | 28 | 37 (95% CI, 33 to 41) | Mean Difference: −1 (95% CI, −6.5 to 4.5)^‡‡^
Home blood pressure measurement | Ross-McGill, 2000^97^ | Anxiety (STAI)^††^ | 38 weeks of gestation | 24 | 38 (95% CI, 34 to 42) | 23 | 38 (95% CI, 33 to 43) | Mean Difference: 0 (95% CI, −5.8 to 5.8)^‡‡^
Home blood pressure measurement | Ross-McGill, 2000^97^ | Anxiety (STAI)^††^ | 6 weeks postpartum | 40 | 35 (95% CI, 32 to 38) | 38 | 35 (95% CI, 32 to 38) | Mean Difference: 0 (95% CI, −3.9 to 3.9)^‡‡^
Reduced prenatal visit schedule | Walker, 1997^99^ | Anxiety (STAI)^§§^ | 36 weeks of gestation | 43 | NR | 38 | NR | NS^ǁǁ^
Reduced prenatal visit schedule | Sikorski, 1996^98^ | Antenatal/postnatal depression (EPDS)^¶¶^ | 34 weeks of gestation | 901 | 8.8 (SD: 5.63) | 933 | 8.6 (SD: 5.51) | P=0.712^***^
Reduced prenatal visit schedule | Sikorski, 1996^98^ | Antenatal/postnatal depression (EPDS)^¶¶^ | 6 weeks postpartum | 843 | 6.9 (SD: 4.96) | 830 | 6.8 (SD: 5.06) | P=0.759^***^
Reduced prenatal visit schedule | Sikorski, 1996^98^ | Antenatal/postnatal depression (EPDS)^¶¶^ | 2.7 years postpartum | 548 | 5.7 (SD: 4.6) | 554 | 6.1 (SD: 5.24) | P=0.965^***^
Reduced prenatal visit schedule | Sikorski, 1996^98^ | Anxiety (anxiety subscale of HADS)^†††^ | 2.7 years postpartum | 541 | 5.2 (SD: 3.41) | 549 | 5.3 (SD: 3.79) | P=0.781^***^

* The six-item short-form of the Spielberger State-Trait Anxiety Inventory. Scores scaled to 100 with higher scores indicating greater anxiety.

† There is high risk of bias for this outcome due to attrition and missing data.

‡ Linear mixed-effects model of STAI-6 at 30 weeks and postnatal followup modelled against randomized arm, time point, the interaction between randomized arm and time point, parity, and baseline STAI-6 as fixed effects; site as a random effect, and a random intercept for each participant.

§ There is high risk of bias for this outcome due to attrition and missing data.

ǁ EuroQol instrument 5 Dimensions 5 levels, converted to a single index score (on a scale where a score of 0 is equivalent to death and 1 to perfect health).

¶ Multiple imputation analysis, adjusted for center, parity, and potential EQ-5D-5L index baseline imbalances. Completers adjusted mean difference: 0.012 (95% CI, −0.002 to 0.026), p-value NR.

** Multiple imputation analysis, adjusted for center, parity, and potential EQ-5D-5L index baseline imbalances. Completers adjusted mean difference: 0.001 (95% CI, −0.015 to 0.017), p-value NR.

†† State component of the State-Trait Anxiety Inventory. Includes 20 questions, scores range from 20 to 80 with higher scores indicating higher reported anxiety.

‡‡ Calculated.

§§ State-Trait Anxiety Inventory. Both subscales include 20 questions with scores ranging from 20 to 80 with higher scores indicating higher reported anxiety.

ǁǁ Anxiety scores on both state and trait scales did not differ significantly between the two study groups at baseline or followup, nor was the change in state anxiety scores significantly different.

¶¶ Edinburgh Perinatal/Postnatal Depression Scale, scores range from 0 to 30 with higher scores indicating higher likelihood of depression.

*** P-value from study-reported log-rank test.

††† Anxiety subscale of the Hospital Anxiety and Depression Scale, scores range from 0 to 21 with higher scores indicating higher symptoms of anxiety.

Abbreviations: CI = Confidence interval; CG = Control group; EPDS = Edinburgh Perinatal/Postnatal Depression Scale; EuroQol-5D-5L = EuroQol instrument 5 Dimensions 5 Levels; HDP = Hypertensive disorders of pregnancy; HADS = Hospital Anxiety and Depression Scale; HRQoL = Health related quality of life; IG = Intervention group; NA = Not applicable; NR = Not reported; NS = Not significant; SD = Standard deviation; STAI = State component of the State-Trait Anxiety Inventory.

### Detailed Results by Outcome

#### Home Blood Pressure Measurement Interventions

Cesarean delivery is often cited as a potential harm in trials examining interventions to improve maternal and neonatal pregnancy outcomes. In the case of hypertensive disorders of pregnancy, however, cesarean delivery may provide benefit in terms of hastening delivery in patients whose clinical status does not allow time for induction of labor. Because it is a commonly reported outcome for antenatal intervention trials, we have also included it here, but recognize that cesarean delivery may be performed for medical necessity and therefore a considered a benefit in some circumstances.

Differences in rates of cesarian delivery could be attributed to the timing of clinical presentation and the course of the illness. In the BUMP trial (N = 2,441), the proportion of patients having emergency Cesarean delivery before and during labor was very similar between study groups, with slightly fewer cases in the home measurement group than the usual care group (RR 0.89 [95% CI, 0.76 to 1.03]).^104^ The risk of induction or Cesarean delivery for a hypertension-related complication was also similar between groups: 7.8 percent with the addition of home blood pressure measurement and 7.1 percent with usual care (RR 1.09 [95% CI, 0.82 to 1.45]).

The BUMP trial also reported the mean difference between study groups in anxiety using the State Trait Anxiety Inventory short form (STAI-6). Anxiety was slightly lower in the home measurement group at 30 weeks of gestation (mean difference −1.45 [95% CI, −3.11 to 0.22]) and postpartum (12 months after baseline) (mean difference −1.37 [95% CI, −3.25 to 0.51]). These represent small differences on this 6-item instrument using 4-point Likert scale responses sets (scale range 6 to 24),^109^ and the differences were not statistically significant. The smaller trial of home blood pressure measurement and a reduced office-visit schedule for low-risk pregnancies (N = 80) reported anxiety measured at four time points using the State Trait Anxiety Inventory (STAI).^97^ The STAI includes 20 items with responses measured on a 4-point Likert scale resulting in a possible score range of 20 to 80, with higher scores reflecting higher anxiety levels.^110^ At all of the time points reported (28, 34, 38 weeks of gestation, 6 weeks postpartum) the mean anxiety ranged from 35 to 38 in both the home measurement and usual care groups, and there were no differences between groups.

#### Reduced Prenatal Screening Visit Schedules

Data on Cesarean deliveries were reported in all three trials of reduced prenatal visit schedules. The small US trial (N = 81) reported no cases in the reduced visit condition and 3 cases in the usual care control condition, and did not provide data on the reason or indication.^99^ The large US trial (N = 2,328) reported Cesarean delivery for any indication for intervention (13.0%) and control groups (12.0%) or for fetal distress (2.0% vs 2.2%, respectively).^96^ The relative risks between groups were small for both outcomes, with confidence intervals including the null. Similarly, the large UK trial (N = 2,794) reported overall rates of inductions (intervention group: 18.0% vs control group: 16.9%) and Cesarean deliveries (13.9% vs 15.4%).^98^ Rates of hypertension-related induction (2.4% vs 2.7%) and hypertension-related cesarean delivery (0.8% vs 1.0%) were also similar between intervention and control groups. Relative risks for all of these outcomes were close to or less than one, with no statistically significant differences.

The small US trial reported anxiety measured at 36 weeks of gestation with the STAI instrument (described above).^99^ Numeric results were not presented but the authors noted in the study text that there were no statistically significant differences between the two study groups. The large UK trial measured anxiety and depression during pregnancy (34 weeks of gestation) and postpartum (2.7 years postpartum, on average).^98^ Mean anxiety, measured using the anxiety subscale (7 items) of the Hospital Anxiety and Depression Scale (HADS), and depression, measured with the Edinburgh Postnatal Depression Scale (EPDS), were not different between groups during pregnancy or at over two years postpartum.

#### Indicated Rather Than Routine Urine Screening for Proteinuria

The NRSI with a historical control (N = 2,441) of indicated urine screening reported similar rates of cesarean delivery (any indication) in the indicated screening group (17.8%) and the routine screening group (18.5%).^95^