# Chapter 2 Methods

## Scope and Purpose

The USPSTF will use this report to update its 2017 recommendation on screening for preeclampsia. In 2017, the USPSTF concluded with moderate certainty that screening for preeclampsia in pregnant women with blood pressure measurements throughout pregnancy had a substantial net benefit (B recommendation).^54^

The updated review broadens the topic beyond preeclampsia to screening for all hypertensive disorders of pregnancy and was designed to include screening interventions in the postpartum period (but not monitoring or surveillance of HDP). The approach to screening and clinical management of preeclampsia and other hypertensive disorders of pregnancy do not appreciably differ – gestational hypertension and preeclampsia are predicated on the identification of elevated blood pressure during pregnancy and result in heightened surveillance and ongoing testing and diagnostic evaluations to assess the disease course. Treatments for preeclampsia, gestational hypertension, and chronic hypertension include similar interventions according to disease severity, including treatment with antihypertensive medication at certain thresholds, induction of delivery in the presence of certain signs or symptoms, and treatment with magnesium sulfate to prevent seizures and stroke. Therefore, this updated review will focus on studies comparing different screening protocols for all hypertensive disorders of pregnancy, including preeclampsia. The review aims to assess the comparative effectiveness of different screening protocols that vary by gestational timing, frequency, modality, and sequencing over the course of pregnancy.

While the definition of hypertensive disorders of pregnancy includes pregnancies among individuals with existing chronic hypertension, this review is focused on screening interventions aimed at identifying hypertensive disorders of pregnancy among those without a diagnosis, in keeping with standard USPSTF procedures. Therefore, studies evaluating different approaches to monitoring individuals with hypertension during pregnancy or postpartum were outside of the review scope.

The primary aim of this review is to examine the comparative effectiveness of interventions to detect hypertensive disorders of pregnancy including comparisons of: blood pressure measurement setting (office or home), interval, frequency, or timing; proteinuria assessment setting, interval, or sequence of testing; and personalization of screening based on risk assessment.

Unlike the previous review, this update does not include a review of the test performance characteristics of point of care protein urine screening tests commonly used in pregnancy (e.g., urine dipstick). Since the previous review of this screening topic, the definition of preeclampsia was updated such that proteinuria is one of several clinical signs or symptoms that are used to confirm a diagnosis of preeclampsia. Routine point of care urine screening for proteinuria has modest test performance and questionable clinical value in the absence of elevated blood pressure. While this review does not address the accuracy of urine screening (i.e., comparison against a gold standard), the scope does support the inclusion of studies comparing the effectiveness of different approaches to protein urine screening over the course of pregnancy (e.g., timing, indication, frequency, type of test).

In addition, this update review will not address the performance of risk prediction models to identify individuals at increased risk for developing preeclampsia. Evidence from clinical implementation studies is needed to inform screening recommendations, and existing reviews suggest that current models have limitations and may need further refinement prior to clinical application.^50,^ ^52^ While this review does not present evidence on the performance of risk prediction models, the scope was defined to include studies that incorporate risk assessment to personalize screening or to select patients for evaluation of new screening approaches.

## Key Questions and Analytic Framework

We followed USPSTF procedures and methods to define study inclusion and exclusion criteria (Appendix A Table 1) and developed an analytic framework (Figure 1) with three Key Questions (KQs).

Figure 1 Analytic Framework

"Figure 1 is the analytic framework that depicts the three Key Questions to be addressed in the systematic review. The figure illustrates how different screening programs used to identify hypertensive disorders of pregnancy among asymptomatic pregnant individuals may reduce maternal, perinatal, and child morbidity and mortality (KQ1). Additionally, the figure depicts how effective different screening programs used to identify hypertensive disorders of pregnancy among asymptomatic pregnant individuals may be (KQ2), as well as harms that may be associated with different screening programs used to identify hypertensive disorders of pregnancy among asymptomatic pregnant individuals (KQ3)."

### Key Questions

1. How effective are different screening programs used to identify hypertensive disorders of pregnancy for reducing maternal and perinatal morbidity and mortality?
2. How effective are different screening programs for identifying people with hypertensive disorders of pregnancy?
3. What are the harms of different screening programs used to identify hypertensive disorders of pregnancy?

In addition, we delineated four contextual questions, which were addressed using abbreviated, not fully systematic methods and are therefore not shown on our analytic framework:

1. How do racism and social inequalities contribute to existing inequities in morbidity and mortality from hypertensive disorders of pregnancy? For example, what accounts for higher mortality from hypertensive disorders of pregnancy among Black compared with White populations in the United States?
2. Are there effective interventions that could redress existing inequities in morbidity and mortality from hypertensive disorders of pregnancy?
3. What is the effectiveness of blood pressure self-monitoring and its potential utility in telehealth prenatal care delivery?
4. How are risk assessment and risk prediction tools being used in clinical practice to inform screening programs?

## Data Sources and Searches

We conducted comprehensive searches of MEDLINE and the Cochrane Collaboration Registry of Controlled Trials for relevant studies published between January 1^st^, 2014, and January 4^th^, 2022. This search was designed to partially overlap with the end search dates of the previous USPSTF-commissioned review of this topic, and to identify new studies. A research librarian developed and executed the search, which was peer-reviewed by a second research librarian (Appendix A). In addition, we considered for inclusion all studies from the previous review^52^ conducted to support the 2017 USPSTF recommendation on this topic.^54^ Additionally, supplemental and hand searching was conducted to address the identification of studies that may not have fit within the scope of the previous review (i.e., comparative effectiveness of screening, hypertensive disorders of pregnancy beyond preeclampsia). We examined the reference lists of other previously published reviews, meta-analyses, and primary studies to identify additional potential studies for inclusion. Ongoing trials were identified via ClinicalTrials.gov (https://ClinicalTrials.gov/) (Appendix E). Searches were managed using EndNote® X9 (Thomson Reuters, New York, NY).

## Study Selection

We developed specific inclusion criteria to guide study selection (Appendix A Table 1). Two reviewers independently reviewed the titles and abstracts of all identified articles using DistillerSR (Evidence Partners, Ottawa, Canada) and identified those that were potentially relevant. Two reviewers then independently evaluated the full text of all potentially relevant articles for inclusion in this review. Differences in judgments at the abstract and full text review stages were resolved by discussion. Excluded studies and reasons for exclusion are listed in Appendix C.

All key questions included studies that could address the comparative effectiveness of screening for hypertensive disorders of pregnancy using approaches that varied in their frequency, setting, or method of measurement. Included populations were pregnant or postpartum people, including those at an increased risk for hypertensive disorders of pregnancy. Studies limited to individuals already diagnosed with a hypertensive disorder of pregnancy (including chronic hypertension) or highly selected populations (e.g., people with renal disease) were excluded.

Studies that evaluated changes in the frequency or timing of prenatal care visits as a proxy for screening frequency were included if blood pressure measurement was described or could be inferred to be included in the visit. In addition, we included studies that addressed the use of home blood pressure measurements alongside usual clinical care. We excluded studies where other interventions occurred along with changes to the timing, frequency, or modality of screening (e.g., patient education and support, service delivery model, group model of care). Screening could occur over the course of a pregnancy or up to 8 weeks postpartum.

Key Question 1 addressed the effect of screening on maternal and perinatal health outcomes, including longer-term health consequences from complications of hypertensive disorders of pregnancy. Key Question 2 addressed the detection and time to diagnosis of a hypertensive disorder of pregnancy. Key Question 3 addressed the potential harms of screening programs, including missed diagnoses. Nonclinical outcomes, such as length of hospital stay and neonatal intensive care unit admission, were not included. Appendix A Table 1 lists all the outcomes considered in this review.

Study designs included in this review were RCTs, clinical controlled trials, and non-randomized studies of interventions (NRSI) comparing screening programs. The review was limited to studies conducted in countries with “very high” Human Development Index scores (as of 2020) as published by the United Nations Development Programme.^92^

## Quality Assessment and Data Abstraction and Synthesis

Two reviewers independently assessed the methodologic quality (risk of bias) of each included study using predefined criteria (Appendix A Table 2). Each study was assigned a quality rating of “good,” “fair,” or “poor” according to the USPSTF’s study-design-specific criteria. Disagreements were resolved by discussion. One investigator abstracted data on study design, patient characteristics, intervention and comparator descriptions, and outcomes into an evidence table. A second investigator checked the accuracy of the abstracted data against the article. Given the limited number and clinical heterogeneity in the included studies, we did not conduct any quantitative synthesis.

For consistency, in this report we use the following default terminology:

1. Race and/or ethnicity when referring to race/ethnicity
2. Black and White (in capitals) as descriptors for populations rather than nouns
3. Black persons as opposed to African Americans
4. Hispanic/Latino individuals to refer to both individuals from Spanish-speaking backgrounds and individuals from Latin America
5. White persons as opposed to Caucasian persons
6. In reference to persons indigenous to North America (and their descendants), American Indian or Alaska Native
7. Throughout the report when referring to different race groupings non-Hispanic/Latino ethnicity can be assumed unless otherwise stated.

There are no ideal or universally preferred terms for many of these categorizations and concepts, but we have tried to avoid inaccurate terms or those perceived as marginalizing. In select instances, when using less preferrable terms referenced by the source material, we note this using quotation marks (e.g., “diverse populations”).

To recognize gender diversity in pregnant and birthing people we apply gender neutral terms when possible, but in specific cases, gendered terms are used to communicate standard health outcomes of historic importance (e.g., maternal mortality). Since this is a pregnancy topic, the literature cited is focused on people capable of becoming pregnant, who are most often people assigned female sex at birth. Gender is often inferred or assumed based on anatomy or physical presentation, however, and may not reflect self-identified gender for some people who give birth. Additionally, binary constructions of gender fail to account for individuals that do not identify as either a men or women (e.g., people who identify as non-binary).

## Grading the Strength of the Body of Evidence

The strength of the overall body of evidence for each KQ was graded using an adaptation of the Evidence-based Practice Center approach,^93^ which is based on a system developed by the Grading of Recommendations Assessment, Development, and Evaluation (GRADE) Working Group.^94^ This adaptation explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency, precision, reporting bias, and study quality. We do not evaluate the fifth domain—directness—as it is implied in the structure of the key questions (i.e., link between the interventions to a health outcome).

Consistency (similarity of effect direction and size) was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision (degree of certainty around an estimate) was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there was insufficient evidence for a particular outcome) to address the potential for bias related to publication, selective outcome reporting, or selective analysis reporting. Study quality summarizes the degree to which the results are likely to have adequately low risk of bias based on individual study quality. The limitations domain highlighted important constraints in answering the overall key question.

Overall grades for the strength of evidence are rated as “High,” “Moderate,” “Low,” or “Insufficient.” A rating of “High” indicates high confidence that the evidence reflects the true effect, and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” strength of evidence ratings indicates a moderate confidence that the evidence reflects the true effect, and that further research may change our confidence in the estimate of effect or may change the estimate itself. A strength of evidence rating of “Low” indicates low confidence that the evidence reflects the true effect, and that further research is likely to change our confidence in the estimate of effect and to change the estimate itself. A grade of “Insufficient” is used to indicate that evidence is either unavailable or does not permit estimation of an effect. Strength of evidence was independently assessed by at least two independent reviewers, with discrepancies resolved through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft research plan was posted on the USPSTF website for public comment from May 20, 2021, through June 16, 2021. The USPSTF received comments and questions related to the scope of the review. In response, the USPSTF modified the research plan to clarify the population of interest, the wording of the contextual questions, and the focus of the review on the health effects of screening in the prenatal and postpartum periods. A final research plan was posted on the USPSTF website on September 2, 2021.

A draft version of this report was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers. Reviewer comments were presented to the USPSTF during its deliberations and addressed in subsequent revisions to the draft report. The revised draft of the report was posted for public comment on the USPSTF Website from February 7, 2023 through March 6, 2023. The draft received few public comments, leading to minor editorial changes but no updates to the included evidence or the report conclusions.

## USPSTF and AHRQ Involvement

The authors consulted with USPSTF members during the development of the research plan, including developing the scope of the review, the analytic framework, key questions, and inclusion criteria. After revisions in response to feedback from the public comment period, USPSTF members approved the final analytic research plan. An AHRQ Medical Officer provided project oversight, reviewed draft versions of the evidence review, and assisted in the external review of the report. The USPSTF and AHRQ had no role in the study selection, quality assessment, or writing of the evidence review.