# Chapter 1 Introduction

## Condition Definition

Hypertensive disorders of pregnancy include gestational hypertension; preeclampsia-eclampsia; and chronic hypertension with superimposed preeclampsia. Chronic (or preexisting) hypertension is diagnosed prior to pregnancy or before 20 weeks of gestation. Gestational hypertension and preeclampsia involve new-onset hypertension after the 20^th^ week of gestation in a person with previously normal blood pressure.^1,2^

The diagnosis of preeclampsia requires the presence of hypertension accompanied by proteinuria or any of the following signs or symptoms: thrombocytopenia; impaired liver function as indicated by elevated blood concentrations of liver enzymes and severe persistent right upper quadrant or epigastric pain unresponsive to medication; renal insufficiency; pulmonary edema; new-onset headache unresponsive to medication; or visual disturbances.^1^ The presence of any of these systemic signs or symptoms, or of severe hypertension (systolic blood pressure ≥ 160mmHg or diastolic blood pressure ≥ 110mmHg) are indications of preeclampsia with severe features. Eclampsia is the onset of seizures among individuals with preeclampsia and without a prior seizure disorder such as epilepsy. Gestational hypertension is defined as the new onset of hypertension after the 20^th^ week of gestation without proteinuria or any of the additional signs and symptoms that define preeclampsia/eclampsia. HELLP syndrome is a severe form of preeclampsia that is diagnosed based on a constellation of laboratory findings (hemolysis, elevated liver enzymes, and low platelet count).^1^

## Prevalence and Burden

Globally, the United States stands out as having rates of maternal mortality two to ten times higher than other very-high development index countries (20.1 per 100,000 live births in the United States in 2019).^3^ Hypertensive disorders of pregnancy are among the leading causes of pregnancy-related death (death while pregnancy or within one year of the end of pregnancy).^4^ Data from the Center for Disease Control and Prevention indicate that the rate of hypertensive disorders of pregnancy in the United States has been steadily increasing over the last several decades, from approximately 500 cases per 10,000 deliveries in 1993 to 1021 cases per 10,000 deliveries in 2016 to 2017.^5^ A population-based analysis of United States found that over the past four decades advancing maternal age and the increasing prevalence of chronic hypertension and higher body mass index (BMI) have contributed to these increasing trends.^6^ From 2014-2017, hypertensive disorders of pregnancy, including preeclampsia, were responsible for 6.8 percent of pregnancy-related deaths in the United States.^4^ A majority of deaths attributed to hypertensive disorders of pregnancy occur in the six weeks following delivery (44% and 21% during 1-6 and 7-42 days after delivery, respectively).^7^ Severe morbidity from hypertensive disorders of pregnancy also occurs and contributes to the burden of disease.^8–11^ Hypertensive disorders of pregnancy contribute to fetal growth restriction through impeding blood flow to the fetus.^12^ Finally, because there is no treatment for preeclampsia and it resolves only after delivery of the placenta, the condition is a leading cause of medically induced preterm birth and low birth weight. It has been estimated that preeclampsia contributes to 6 percent of all preterm births and 19 percent of medically indicated preterm births.^13^

Inequities in hypertensive disorders of pregnancy and related morbidity and mortality for Black individuals are well documented and persistent.^14,^ ^15^ In the United States, the maternal mortality rate (maternal deaths during and up to 42 days postpartum) is highest among Black people (44.0 per 100,000 live births in 2019, which was 2.5 times higher than among White people: 17.9 per 100,000 live births in 2019).^3^ Other estimates based on vital statistics data have estimated that the maternal mortality rate for non-Hispanic Black people is 3.55 times that of White women. Hypertensive disorders of pregnancy account for a larger proportion of pregnancy-related mortality and serious morbidity among Black populations than White populations.^16–21^ According to national estimates, fewer than half of White people with preeclampsia are diagnosed with cases having severe features, whereas nearly two-thirds of cases among Black people develop severe disease features.^16,^ ^19^ These differences in severity contribute to higher overall maternal mortality rates and greater contribution of preeclampsia/eclampsia to maternal mortality observed in Black populations.^21,^ ^22^ In 2016 to 2017 eclampsia and preeclampsia were the leading cause of maternal death among Black people, and the second leading cause of maternal mortality among White people. The risk of dying from eclampsia and preeclampsia was about five times greater for Black (3.93 per 100,000 live births) than White individuals (0.78 per 100,000 live births).^21^

While the risks for hypertensive disorders of pregnancy and related complications are clearly greatest for Black people in the United States, limited public health surveillance restricts our ability to identify the extent to which other racial or ethnic groups (particularly for American Indian/Alaska Native [AI/AN] people) are also at heightened risk.^21^ Pregnancy-related mortality among AI/AN people is also elevated compared to White people (29.7 compared to 12.7 per 100,000 live births in 2007-2016), with hypertensive disorders of pregnancy a leading cause of pregnancy-related mortality, accounting for 12.8 percent of pregnancy-related deaths.^16^ Among a retrospective review of cases deliveries from 2013 to 2017 at one medical center, AI/AN individuals had significantly higher severe maternal morbidity rates compared with other racial/ethnic groups (11.7% vs. 3.9% for White individuals).^8^ Limited public health data, and lack of information about specific populations of this diverse group, have been noted. A recent scoping review highlighted factors such as hemorrhage, cardiomyopathy, and hypertensive disorders of pregnancy that may contribute to high pregnancy-related mortality among AI/AN individuals, as well as the need for further research to understand root causes.^23^

Data for other racial and ethnic groups are mixed, with lower incidence of hypertensive disorders of pregnancy and better pregnancy outcomes reported among Asian and Hispanic/Latino people than White people in some national estimates.^16,^ ^19,^ ^20,^ ^24,^ ^25^ The diversity of backgrounds collapsed within these broad groupings, and sparse data for groups with smaller population numbers, likely conceal a more complex picture. Asian and Hispanic/Latino individuals usually have the lowest rates of hypertensive disorders of pregnancy in national data reports, but when data with more detailed information about race and ethnicity are disaggregated, risk for hypertensive disorders of pregnancy varies considerably among subgroups within these broad categories, defined by geography, ethnic background, and immigration status. For example, South Asian and Filipino people have higher risks for hypertensive disorders of pregnancy than Asian people overall.^26^

Elevated risks of certain adverse outcomes related to hypertensive disorders of pregnancy also vary by race and ethnicity. Billing data from the Healthcare Cost and Utilization Project’s National Inpatient Sample from 1998 to 2014 show that among individuals with hypertensive disorders of pregnancy, the risk of stroke in pregnancy was highest for Asian/Pacific Islander people and elevated for Hispanic/Latino and Black people compared with White people.^27^ A separate analysis of the National Inpatient Sample for the years 2012 to 2014 found increased risk for morbidity related to preeclampsia for all other racial and ethnic groups compared with White individuals.^18^ Eclampsia is a rare but serious complication of pregnancy that contributes to maternal mortality and also reflects underlying inequities in health. Nationwide data from US births (1989-2018) show that incidence of eclampsia is highest among Black people (4.4 per 1000 births) and lower among other racial and ethnic groups, including Hispanic/Latino people (2.1 per 1000).^25^ A study using birth data from California, however, found that eclampsia risk was elevated for Hispanic/Latino people relative to White people.^20^

## Etiology and Natural History

The etiology of hypertensive disorders of pregnancy is complex and the likelihood of developing such conditions may be influenced by maternal genetic, environmental, and immunologic factors.^2,^ ^28–31^ Hypertensive disorders of pregnancy may have an etiology associated with the adaptation of the maternal circulatory, renal, and immune systems to pregnancy. The placenta is thought to play a primary role, as these disorders do not appear to regress until the placenta is delivered or removed.^29^

Individuals with gestational hypertension may eventually present with signs of preeclampsia; with progression to preeclampsia more likely if hypertension arises earlier in pregnancy (<32 weeks of gestation).^1^ While preeclampsia can remain stable until delivery, some cases have a more serious and life-threatening course. Significant maternal morbidities associated with preeclampsia include cerebrovascular bleeding; retinal detachment; and organ damage and failure (liver and kidney).^32,^ ^33^ Eclamptic seizure occurs in approximately 1 to 2 percent of diagnosed preeclampsia cases and can be the first presentation of the disorder. These seizures can lead to death or serious complications including brain damage, aspiration pneumonia, pulmonary edema, placental abruption, disseminated coagulopathy, acute renal failure, cardiopulmonary arrest, and coma.^34^

The majority of preeclampsia cases arise after 34 weeks of gestation; however, morbidity and mortality are elevated among cases with early-onset disease.^35^ Risk of adverse fetal, neonatal, and child health outcomes are increased with preeclampsia, including risk of intrauterine growth restriction or small for gestational age (IUGR/SGA), low birth weight, preterm birth, placental abruption, stillbirth, and neonatal death.^2^

In addition to adverse perinatal outcomes, there is growing evidence that having any hypertensive disorder of pregnancy, but especially preeclampsia, is associated with increased risk of maternal chronic hypertension and cardiovascular disease later in life,^36–38^ with greater risks among those who experience preeclampsia during more than one pregnancy and those who experienced earlier onset of HDP.^39^ A recent US-based, prospective cohort study of 109 healthy pregnant persons with singleton gestations found that the group of individuals who developed a hypertensive disorder of pregnancy (n=58) had 4-fold increased odds of a new chronic hypertension diagnosis (adjusted odds ratio, 4.60 [95% CI, 1.65 to 12.81]) at 6-12 months postpartum and a significantly higher adjusted 30-year Framingham cardiovascular disease risk estimate compared to those without HDP (n=51) (7% vs 4%, p<.0001).^40^ The Nulliparous Pregnancy Outcomes Study Monitoring Mothers-to-be Heart Health Study, which followed 4,484 individuals after their first pregnancy, found an increased risk of hypertension at 2-7 years postpartum among individuals who experienced any HDP (RR 2.7, [95% CI, 2.0 to 3.6]) and an even higher risk among those who experienced both an indicated preterm birth and HDP (RR 4.3 [95% CI, 2.7 to 6.7]).^41^ A large Danish cohort of 482,972 individuals found the increased risk of incident hypertension among pregnancies complicated by HDP persisted through 20 years postpartum.^42^ In a meta-analysis of over 13 million individuals, the relative risks of any cardiovascular disease and cardiovascular death for those with a history of hypertensive disorders of pregnancy were 1.80 (95% CI, 1.67 to 1.94) and 1.78 (95% CI, 1.58 to 2.00), respectively.^43^ The relative risk of cardiovascular events associated with having had any hypertensive disorder of pregnancy are elevated in the year following delivery, and longer term differences in absolute risk for cardiovascular disease and related mortality are seen.^37,^ ^44^ As with incident hypertension, the risk of CVD appears to be highest among pregnancies in which the onset of the hypertensive disorder was preterm.^45^

## Risk Factors

The medical risk factors most consistently and strongly associated with preeclampsia include having an autoimmune disease (specifically antiphospholipid antibody syndrome or systemic lupus erythematous), preexisting diabetes mellitus, chronic hypertension, chronic kidney disease, or a pregnancy conceived with assisted reproductive technology.^46^ There is also consistent evidence that having a previous pregnancy complicated by preeclampsia or another hypertensive disorder, placental abruption, or stillbirth is associated with increased risk or preeclampsia. Most pregnant people who develop gestational hypertension or preeclampsia, however, do not have a known major risk factor. Several personal history and pregnancy characteristics have been identified as being independently associated with an increased risk for preeclampsia and gestational hypertension in observational studies. These include nulliparity, high pre-pregnancy body mass index (BMI), multifetal pregnancy, older maternal age (>35 years), and family history of preeclampsia or early-onset cardiovascular disease.^19,^ ^24,^ ^47^ Maternal age is also associated with eclampsia in a J-shaped relationship – the highest incidence is seen among pregnant individuals under age 15 (7.8 per 1000) and over age 44 (5.4 per 1000). Eclampsia is also more common with multiple pregnancies (8.3 per 1000) compared with singleton (2.7 per 1000).^48^

The presence of multiple risk factors, whether personal characteristics or medical history risk factors, further heightens risk for preeclampsia and gestational hypertension. Several models have been developed with the aim of identifying pregnant individuals who are at risk of developing preeclampsia. Many of these models include variables for medical history, patient characteristics, blood serum biomarkers (e.g., serum placental growth factor), mean arterial pressure (MAP), and ultrasound readings (e.g., Doppler uterine artery pulsatility index). The most extensively researched of these are various iterations of the Fetal Medicine Foundation (FMF) model.^49^ Currently, risk assessment and risk prediction tools are being used to inform the use of aspirin for prevention of preeclampsia;^50,^ ^51^ however, no randomized controlled trials (RCTs) have incorporated the use of a risk prediction model to evaluate the optimal frequencies or intervals of screening for hypertensive disorders of pregnancy. In the absence of clinical implementation studies, it is not yet clear whether screening informed by risk prediction models would necessarily be superior to risk evaluations based on clinical history taking.^52^ Moreover, it remains to be seen whether risk-based screening protocols, regardless of the risk-assessment approach used, could improve outcomes relative to usual care screening. Existing guidelines recognize the performance and practical limitations of existing risk assessment models.^1,^ ^53–55^

## Sources of Health Inequities

This report focuses on the on the sources and efforts to address the inequities associated with race and ethnicity in the United States. Risk factors for HDP, such as the use of ART, chronic health conditions such as diabetes and chronic hypertension, and age at the time of giving birth are not evenly distributed in the population and contribute to maternal and infant morbidity and mortality. Socioeconomic factors, residence (region, rurality), and access to health care influence the prevalence of risk factors. These factors and other social and structural determinants of health contribute to heightened HDP risk and worse outcomes for individuals regardless of their race or ethnicity. At the same time, adjustment for these factors does not account fully for the increased rates of HDP or risk for worse outcomes for Black and AI/AN individuals.

Racial and ethnic categories do not reflect biologically or genetically defined differences among people, but instead are idiosyncratic groupings that have arisen from historical, economic, and cultural relationships among people and nations.^56–58^ Efforts to understand underlying causes of race and/or ethnicity related inequities in morbidity and mortality from hypertensive disorders of pregnancy increasingly focus on the complex effects of interpersonal and structural racism on health status. Current and past policy conditions and historical events have implications for a range of exposures and conditions that contribute to HDP risk and pregnancy outcomes. These include inequities in income and wealth, housing stability and location, medical care access and quality and other factors that contribute to health status and resources for maintaining health.^14,^ ^26,^ ^59^ ^56–58^ Several frameworks have been developed to describe the factors contributing to higher incidence of hypertensive disorders of pregnancy and greater disease severity and mortality among Black and AI/AN individuals. Most broadly, the National Office of Minority Health and Health Disparities Research Framework describes important individual, interpersonal, community, and societal factors and conditions that contribute to a host of health inequities in the United States.^60^ Other models, such as those developed for the recent Maternal Morbidity and Mortality Measurement report, focus the pregnancy care continuum (prenatal, intrapartum, postpartum). These frameworks have evolved from public health frameworks and years of scholarship documenting how structural conditions shaped by policy and history have differently impacted specific racial and ethnic populations in the United States.^61–64^

Contributors to racial and ethnic inequities in outcomes of hypertensive disorders of pregnancy include lower prenatal health care access and quality, greater psychosocial and work stress, and a higher prevalence of chronic health conditions (e.g., obesity, diabetes, hypertension) among Black and AI/AN individuals than other racial/ethnic groups, as well as systemic racial biases in health care.^16,^ ^64^ The National Health and Nutrition Examination Survey from 2013-2016 estimated that Black populations had the highest prevalence of chronic hypertension compared with White, Asian, and Hispanic/Latino populations.^65^ Higher prevalence of chronic health conditions associated with hypertensive disorders of pregnancy is also linked to the inequities at the societal and community level, making these factors difficult to disentangle. Environmental factors, including air and water pollution, are also associated with increased preeclampsia risk, and historical residential segregation and environmental racism make these exposures more common for Black populations than other racial/ethnic groups.^66–70^

Access to prenatal care and high-quality obstetric services, particularly for individuals who are at the highest risk for adverse pregnancy outcomes, has been identified as potential source of racial and ethnic inequities in birth outcomes. Having fewer than five prenatal visits increases the risk of eclampsia nearly two-fold, independent of race or ethnicity, and people who are in poverty or uninsured are less able to obtain routine prenatal care.^20^ A study of over 300,000 pregnant individuals without a diagnosis of chronic hypertension found that a single elevated blood pressure reading before the 20^th^ week of pregnancy was associated with increased risk of hypertensive disorders of pregnancy.^71^ This finding demonstrates the importance of obtaining baseline blood pressure readings and conducting risk assessment as pregnancy progresses through regular prenatal care in the first half of pregnancy. National targets outlined in Healthy People 2030 set a target for 80.5 percent of pregnant individuals to receive early and adequate prenatal care by 2030 (based on the Adequacy of Prenatal Care Utilization Index). As of 2019, 76.7 percent of pregnant individuals received adequate prenatal care by this measure, with White and Asian populations close to or above the Healthy People 2030 goal (81.8% and 79.1%, respectively). However, less access to early prenatal care was seen among AI/AN (60.9%), Native Hawaiian/Pacific Islander (48.1%), Black (68.2%), and Hispanic/Latino populations (71.6%).^72^

## Screening and Treatment

### Screening Strategies

Screening tests are used to identify people that have a condition before it becomes symptomatic or has progressed. A positive screening test is followed by further clinical evaluation to confirm or specify the exact diagnosis. Ideally, screening tests correctly identify those who ultimately receive a diagnosis without flagging a large number of people that are not found to have the condition upon further examinations. Those with a confirmed diagnosis can then receive clinical interventions shown to reduce the health risks associated with the condition. Screening for hypertensive disorders of pregnancy has been a standard prenatal care practice for over 100 years.^73^ Individuals who are identified as having a hypertensive disorder of pregnancy require enhanced surveillance and evidence-based clinical management to reduce the potential for maternal or infant mortality and serious complications associated with hypertensive disorders of pregnancy.^53^ Hypertensive disorders of pregnancy comprise an array of conditions with diversity of clinical presentation and course, and screening is not based on a single stand-alone instrument or time point. In addition, blood pressure measurements before or early in pregnancy is important for diagnosis. Without measures before 20 weeks of gestation, gestational hypertension cannot be distinguished from undiagnosed chronic hypertension until after pregnancy.

In the general population, blood pressure is traditionally measured with a sphygmomanometer by detecting sounds (auscultatory method) or by recording pulsations (oscillometric method). Factors such as patient caffeine consumption, cigarette use, and sitting position, as well as cuff size and placement, can affect the accuracy of blood pressure measurements in both in-office and out-of-office settings.^74^ In 2017, the American College of Cardiology/American Heart Association Task Force on Clinical Practice Guidelines published extensive guidance for increasing accuracy of both in-office and out-of-office blood pressure measurements.^74^ The guidance recommends use of an ambulatory blood pressure monitor (ABPM), which typically records blood pressure over 24 hours using oscillometry, as the gold standard method of measuring blood pressure, as it is able to diagnose white coat, masked, and nocturnal hypertension.^75^ However, due to the limited availability of ambulatory blood pressure monitors, home blood pressure measurement, in which an individual measures their own blood pressure at some prespecified interval (e.g., 2 times a day for a week) with semiautomatic devices, is also recommended. Home blood pressure readings are subject to reporting bias, and the measurements are generally higher than ambulatory blood pressure readings, but lower than in-office readings.^75^ In 2021, the US Preventive Services Task Force (USPSTF) recommended that adults should be screened for hypertension with office blood pressure measurement, and that blood pressure measurement outside of a clinical setting should be obtained for diagnostic confirmation before beginning treatment.^76^

Routine blood pressure measurement throughout pregnancy and the postpartum period is a key component of screening for hypertensive disorders of pregnancy, and requires both an appropriate measurement technique and a device validated for use in pregnancy to achieve the most accurate results.^77^ It is important to validate accuracy specifically among people who are pregnant and those who have preeclampsia because there may be differences in performance due to physiologic changes associated with these states.^78^ Various factors, including physiologic changes associated with pregnancy, may affect the accuracy of blood pressure measurements, and failure to employ the best methods of assessment may result in an over- or underestimate of blood pressure, impacting diagnosis. Because ABPM incorporates assessment during the night while an individual is sleeping, it provides the advantage of identifying nocturnal hypertension. This may be especially relevant for pregnancy given potential diurnal variation in blood pressure that has been observed in individuals with preeclampsia (blood pressure may be highest at night). A recent Cochrane review aimed to summarize the evidence examining how the techniques and settings used for blood pressure measurement to diagnose hypertensive disorders of pregnancy affected perinatal and maternal health outcomes.^79^ The review identified only three studies and concluded there was uncertainty regarding the effects for the included comparisons (self-measurement versus office, use of Korotkoff phase IV versus Korotkoff phase V for diastolic blood pressure determination, semi-automated monitor versus usual care).

Other relevant screening assessments may include querying the pregnant patient regarding symptoms associated with preeclampsia and tests for proteinuria (typically urine dipstick). The importance of routine urine tests for screening has been questioned.^80^ Reviews of the performance of point of care urine tests indicate substandard accuracy even in enriched clinical populations of individuals with suspected preeclampsia.^52,^ ^81^ Indeed, the importance of distinguishing gestational hypertension from preeclampsia solely on basis of the presence or absence of proteinuria has been questioned, given similarities in the ongoing management of both conditions.^80^

### Prevention and Treatment Approaches

High-quality prenatal care aims to improve birth outcomes by identifying hypertensive disorders of pregnancy and managing them with evidence-based clinical intervention when indicated (e.g., treatment with anti-hypertensive medications, induction of labor, magnesium sulfate to prevent seizures, and administration of steroids to improve fetal outcomes in the setting of preterm delivery).^1,^ ^53,^ ^82–85^ Few effective preventive interventions for hypertensive disorders of pregnancy have been identified. For individuals at increased risk for preeclampsia, daily low-dose aspirin taken during pregnancy has been shown to reduce the risk of developing preeclampsia and its serious health consequences, including perinatal mortality, preterm birth, and small for gestational age infants.^50,^ ^51^ There is also limited evidence that calcium supplementation may be beneficial for reducing preeclampsia and gestational hypertension risk, particularly for women with low calcium diets, but more evidence is needed.^86^ Evidence is mixed on whether behavioral interventions related to diet and physical activity before and during pregnancy are effective at preventing hypertensive disorders of pregnancy. A 2017 systematic review of 17 trials reported reduced risk for those engaging in 30-60 minutes of aerobic exercise several times a week, but only 7 of the trials could be combined in meta-analysis.^87,^ ^88^ A 2018 systematic review of 23 behavioral intervention trials included fewer trials of exercise alone and more trials of interventions combining diet and exercise and did not find reductions in the risk of hypertensive disorders of pregnancy, although gestational weight gain was reduced for some participants.^89^ In both reviews, there was no effect of exercise on the risk for preeclampsia. Another 2018 systematic review of prenatal exercise, however, showed reduced risk for HDP and noted that it required at least 600 minutes of moderate-intensity exercise each week.^90^

Individuals with gestational hypertension or preeclampsia without severe features arising prior to 37 weeks of gestation require close antenatal surveillance to assess for worsening disease or fetal compromise that might require more expedient delivery.^1^ For individuals who develop a hypertensive disorder of pregnancy, preeclampsia and gestational hypertension usually resolve in the hours, days, or more uncommonly, weeks following delivery of the placenta. Current recommendations for delivery of patients with hypertensive disorders of pregnancy take into consideration the specific diagnosis and the associated risks and benefits both to the mother and the fetus. For individuals with gestational hypertension and preeclampsia without severe features, delivery is recommended when the patient reaches 37 0/7 weeks of gestation. For preeclampsia with severe features, delivery is recommended at 34 0/7 weeks of gestation, or at the time features develop if after 34 0/7 weeks. Given the serious morbidity associated with HELLP syndrome, delivery is recommended upon diagnosis regardless of the gestational age at which it arises. Similarly, individuals with eclampsia should be delivered in a timely manner once the patient is stabilized.

## Previous Recommendations of the USPSTF and Others

In 2017, the USPSTF concluded with moderate certainty that screening for preeclampsia with blood pressure measurement throughout pregnancy had a substantial net benefit (B recommendation).^54^ Although the USPSTF found no recent studies on the direct effectiveness of screening for preeclampsia in improving health outcomes, trial evidence and extensive clinical experience were cited as providing evidence of effective treatments for preeclampsia. The USPSTF found inadequate evidence on the effectiveness of risk prediction tools (e.g., clinical indicators, serum markers, or uterine artery pulsatility index) that would support different screening strategies for predicting preeclampsia. Furthermore, there were no randomized implementation studies found that evaluated the health effects of using risk assessment models to replace or inform screening compared with standard screening using blood pressure measurements.^51^

Screening for hypertensive disorders of pregnancy has long been a central component of prenatal care. In the Guidelines to Prenatal Care (8^th^ ed.) issued by the American College of Obstetricians and Gynecologists (ACOG) and the American Academy of Pediatrics (AAP) (2018),^91^ the importance of regular prenatal care visits, with greater frequency in the presence of risk factors for complications, is noted. Blood pressure measurement at every visit is advised. Recent ACOG recommendations related to preeclampsia (2020) focus on the diagnostic criteria for gestational hypertension and preeclampsia, and management decisions for those diagnosed.^1^