# Appendix E Ongoing Studies

Trial identifier | Study name | Location | Estimated N | Interventions | Relevant outcome measures | Status
NCT03334149 | Blood Pressure Monitoring in High Risk Pregnancy to Improve the Detection and Monitoring of Hypertension (BUMP) | UK | 3042 | Self-Monitoring of Blood Pressure vs. usual care | - Time from recruitment to diagnosis of raised blood pressure; - Quality of life; - Stillbirth and early neonatal deaths; - Gestational age at delivery; - Mode of delivery; - Birth weight, small for gestational age; - STAI-6 short form anxiety questionnaire | Completed December 2020 (no published results); Results included in this report via author correspondence
NCT03509272 | LimPrOn: Limburg Pre-eclampsia Investigation (LimPrOn) | Belgium | 2000 | No intervention vs. home monitoring based on risk assessment via physiologic measures (e.g., hemodynamic measure and echocardiogram) | - Birth weight; - Gestational age; - Mode of delivery | Recruiting; Estimated completion: December 2030
NCT04958057 | Social Risks-Focused Lifestyle Intervention to Reduce Preeclampsia (SAIL) | US | 100 | Routine prenatal care vs. 6 monthly group sessions with the study nurse addressing preeclampsia education, coaching on stress management, resource navigation, and training in problem solving. | - Preeclampsia | Not yet recruiting; Estimated completion: June 2024