# Appendix D Intervention Details

Appendix D Table 1 Detailed Inclusion and Exclusion Criteria

Author, Year | Inclusion criteria | Exclusion criteria
Tucker, 2021^88^ | Pregnant individuals at higher risk of pre-eclampsia were recruited by research midwives through antenatal clinics in 15 secondary care maternity units between 16- and 24-weeks’ gestation. Higher risk was defined by the relevant National Institute of Health and Care Excellence guidance at the time and included one or more of the following risk factors for pregnancy hypertension: age 40 years or older, nulliparity, pregnancy interval of more than 10 years, family history of pre-eclampsia, previous history of pre-eclampsia or gestational hypertension, body mass index 30 kg/m^2^ or above at booking for pregnancy care, chronic kidney disease, twin pregnancy, pre-pregnancy diabetes (type 1 or 2), autoimmune disease (e.g., systemic lupus erythematosus or anti-phospholipid disease) | Pre-existing diagnosis of hypertension (i.e., diagnosed before randomization)
Ross-McGill, 2000^81^ | Individuals undergoing either shared general practitioner and hospital antenatal care, or entirely general practitioner care, were eligible whatever their parity | Multiple pregnancy, established hypertension ≥140/90 mmHg, or with previous early onset (before 34 weeks) pre-eclampsia, serious medical disease, or previous pregnancy loss after 24 weeks
Walker, 1997^83^ | Low-risk pregnancy, beginning prenatal care before 26 weeks’ gestation, older than 18 years of age, and ability to speak or read Spanish or English. Pre-pregnancy weight less than 250 pounds. | Evidence of diabetes, hypertension, cardiac conditions, seizures, lupus, asthma requiring medication, chronic infections, multiple gestation, previous stillbirth, previous preterm birth, previous cesarean section.
McDuffie, 1996^80^ | Pregnant individuals in the first trimester classified as having a low risk of adverse events | Age younger than 18 years or older than 39 years, completed 13 weeks of gestation, past or current high risk obstetrical condition, current medical condition, non-English speaking, planning to change insurance during the pregnancy. Past high risk obstetrical conditions were defined as preterm delivery, preterm labor, abruptio placentae, severe preeclampsia, classical cesarean delivery (vertical uterine incision), gestational diabetes, incompetent cervix, uterine anomaly, diethylstilbestrol exposure, isoimmunization, fetal anomaly, or small for gestational age neonate. Current high-risk obstetrical conditions included multiple gestation (if known at intake), pregnancy conceived through assisted reproductive technology, and large (> 4cm) leiomyomata). Current medical conditions included diabetes, chronic hypertension, drug or alcohol abuse, or any ongoing medical or psychiatric illness requiring treatment or monitoring.
Sikorski, 1996^82^ | Pregnant individuals aged 16 to 39 years at low antenatal risk; at least 24 weeks gestation; registered with general practitioner; understanding or literacy in English, Turkish, Vietnamese, Punjabi, Bengali, Cantonese, Spanish, or Portuguese. | Booking for obstetric care after 22 weeks’ gestation, requiring specialist obstetric care (more than visits to an obstetrician planned), or multiple pregnancy. Weighing less than 41 kg (Asian), 47 kg (Afro-Caribbean), or 45 kg (any other ethnic group), weighing more than 100 kg. Previous pregnancy history of: fetal loss (18 weeks’ gestation or later); neonatal death; three or more consecutive spontaneous abortions; cervical suture; birth prior to 34 weeks’ gestation or less than 2.5 kg; severe pregnancy-related hypertensive disorder with proteinuria in last pregnancy; severe non-proteinuric hypertension requiring induction of labor, medication, or epidural for raised blood pressure in last pregnancy; previous myomectomy or classical caesarean section; rhesus or ABO incompatibility antibodies. Medical history of: DBP >90 mm Hg at booking, essential hypertension, diabetes mellitus, renal disease, cardiac disease, previous postnatal, depression requiring medication (including puerperal psychosis), previous cone biopsy, assisted conception (other than clomiphene), current treatment for tuberculosis, taking drugs for a psychiatric disorder, substance abuse.
Rhode, 2007^79^ | All pregnant individuals who enrolled for care and delivered between November 2000 and March 2004. | Spontaneous abortion, transfer out of care, transfer to high-risk care, loss to follow up. Enrollment prior to and delivery after August 15, 2002 (transitional period).

Abbreviations: DBP = Diastolic blood pressure.

Appendix D Table 2 Detailed Intervention Descriptions

Author, Year | Intervention Group Detailed Description | Control Group Detailed Description | Adherence
Tucker, 2021^88^ | Pregnant individuals attended usual antenatal care appointments and were provided with a monitor validated for use in pregnancy (Microlife WatchBP Home). They were given instructions for blood pressure self-monitoring and enrolled on a mobile phone-based telemonitoring system with an optional paper diary. Pregnant individuals were asked to monitor their BP three times a week from randomization to delivery. They were instructed to sit quietly and comfortably for one minute, take two readings one minute apart and submit their second reading to the telemonitoring system. The telemonitoring app transmitted blood pressure readings and received automated responses based on a color-coded chart developed for the trial. If the second reading was outside the expected range (110-134/70-84 mm Hg), this would automatically trigger the system to request a third reading (taken after 5 minutes). Persistently high (≥135/85 mm Hg) or low readings (symptomatic and systolic BP <85 mm Hg) automatically triggered a message to ask the participant to contact their local maternity unit. Once a persistently high readings were recorded (≥135/85 mm Hg), the telemonitoring system would send a request to take daily readings for the remainder of their pregnancy. | Usual antenatal clinic visit schedule as required (at least seven times during an uncomplicated pregnancy) which included having their BP measured by their usual antenatal care team | IG: 98% (1198/1220) performed self-monitoring with 99.8% recording their readings in the app. Readings occurred approximately every third day (32.6% [SD 35.0] of the days) between randomization and delivery or clinic hypertension (whichever came first). Individuals followed the protocol of monitoring three times per week until delivery or clinic hypertension 76.7% (SD 51.3) of the time; if their SMBP rose to ≥135/85 mm Hg and they were monitoring daily until delivery or diagnosis if blood pressure, this happened 71.7% (SD 48.3) of the time.; CG: NR
Ross-McGill, 2000^81^ | The reduced schedule intervention group were loaned a portable blood pressure monitor at 28 weeks and trained in its use. They were instructed to measure their blood pressure weekly at home and record the results in a pre-printed diary. If the systolic reading was between 140 and 160 mmHg or the diastolic between 90 and 100 mm Hg, they were instructed to repeat the measurement after four hours and to contact their midwife if either second reading was >140 or 90 mm Hg, respectively. If any single systolic reading was >160 mm Hg or diastolic ≥100 mm Hg, the women were instructed to contact their midwife immediately. Women in the home monitoring group were instructed to attend the midwife clinic at 34, 38 and 41 weeks. | Women in the routine care group were seen at 28, 30, 32, 34, 36, 37, 38, 39, 40 and 41 weeks | The mean number of antenatal visits in the intervention group was 4.5 (visits specifically related to pregnancy were 3.2). In the control group the mean number of visits was 7.4 (the number of visits related to pregnancy were 3.2)
Walker, 1997^83^ | Pregnant individuals were scheduled to attend eight prenatal visits (an initial visit, and subsequent visits at 15-19 weeks, 24-28 weeks, 32 weeks, 36 weeks, 38 weeks, and weekly until delivery, unless a complication developed requiring more frequent care). Each woman was primarily cared for by one Certified Nurse-Midwife (CNM) during her pregnancy. Length of time allotted for outpatient prenatal visits for both groups was 45 minutes for an initial evaluation and 15 minutes for a return prenatal visit. At each return prenatal visit blood pressure, weight, fetal heart rate, and fundal height measurements were taken, and the urine was tested for glucose and protein. The timing of routine prenatal laboratory tests and other diagnostic tests and examinations was not altered by the study protocol. | After the initial visit, pregnant individuals returned for care every 4 weeks until 28 weeks, every two weeks until 36 weeks, and then weekly until delivery. More frequent visits were scheduled as needed. | On average individuals in the intervention group attended 3.2 visits fewer than those in traditional group (p=0.0001). Individuals in the intervention group attended a mean of 7.65 (1.62) visits (range: 3-11). The control group attended a mean of 10.84 (2.33) visits (range: 6-16).
McDuffie, 1996^80^ | Prenatal visits scheduled for 8, 12, 16, 24, 28, 32, 36, 38 and 40 weeks for a total of 9 visits. For parous women a telephone call was scheduled at 12 weeks instead of a visit. Ongoing risk assessment occurred at each visit and if risk factors were identified additional visits to providers or to nurses for fetal monitoring were scheduled. Blood pressure measured at each visit. | Routine prenatal visit schedule (14 visits) | Overall, 2.7 fewer visits occurred in the intervention group. Mean of 10.3 (2.8) visits in intervention group and 12.9 (2.8) visits to providers in control group.
Sikorski, 1996^82^ | Reduced prenatal visit schedule consisting of as seven visits for nulliparous women and six visits for multiparous women. Nulliparous women were seen at booking, 24, 28, 32, 36, 38, and 40 weeks; multiparous were seen at booking, 26, 32, 36, 38, and 40 weeks. Patients were informed that they could receive extra visits at any time they, or their caregivers, consider it to be necessary. | Standard prenatal visit schedule consisting of 13 visits | The difference between the mean number of visits between groups was smaller than intended. Those in the reduced visit schedule had an average of 8.6 visits; after adjusting for gestational age at booking and delivery this was an average of 2.6 more visits than intended. Those in the traditional group received an average of 10.8 visits (of 13 planned); after adjusting for gestational age at booking and delivery this was an average of 1.65 fewer visits than intended.
Rhode, 2007^79^ | Urine testing with chemical reagent strips was performed on an indicated basis whenever any of the following were met: first prenatal visit, patient complaint of symptoms of urinary tract infection, severe vomiting, weight loss of ≥0.9 kg since previous visit, blood pressure elevation (≥140 mm Hg SBP or ≥90 mm Hg DBP), pregnancy requiring periodic urine testing (e.g., chronic hypertension, renal disease). Clinicians could also request urine testing if other symptoms were detected such as persistent headache. | First prenatal visit included urine screening and culture, and blood pressure measurement. All subsequent visits included urine screening and blood pressure determination. | In the intervention group the mean number of urinary tests during pregnancy were 1.4 (SD: 1.3). The range of tests was 0-16. It was unclear why 18.1% of the indicated urine tests were done.; In the control group the mean number of urinary tests during pregnancy were 7.8 (SD: 3.4). The range of tests was 0-19.

Abbreviations: BP = Blood pressure; CG = Control group; DBP = Diastolic blood pressure; NR = Not reported; SBP = Systolic blood pressure; SD = Standard deviation.