# Appendix C Excluded Studies

Reason for Exclusion*
E1. Setting
E1a. Clinics and study sites treating only high-risk maternity patients
E1b. Study country not a “very high” HDI
E2. Population
E2a. Patients seeking high risk obstetric care or those with known chronic conditions (other than HTN or DM)
E2b. Hospitalized patients
E2c. Population selected for high-risk monitoring (e.g. already diagnosed with HDP)
E3. Study design
E3a. Editorial, narrative review, commentary, post-marketing surveillance, case reports
E3b. Case-control study, not nested
E4. No relevant outcomes
E4a. Non-clinical health outcomes, such as length of hospital stay (without indication), ICU admission, or NICU admission
E5. No screening for a hypertensive disorder or pregnancy
E6. Intervention
E6a. Secondary evaluations and tests used to confirm diagnosis or assess preeclampsia severity
E6b. Prognostic evaluation used to inform disease management
E6c. Intervention includes health care delivery or behavioral interventions alongside changes to screening
E7. Comparator
E8. Non-English language
E9. Publication date before 1990
E10. Poor study quality
E11. Unable to locate article
E12. Study aim

1 Aguilar R, Gorgonio N. A randomized controlled trial to evaluate the effectiveness of the new who model of antenatal care versus the standard model of antenatal care in a tertiary government hospital. Int J Gynaecol Obstet. 131. E362. 2015. KQ1E1b, KQ2E1b, KQ3E1b
2 Bailit JL, Grobman WA, . Does the presence of a condition-specific obstetric protocol lead to detectable improvements in pregnancy outcomes? Am J Obstet Gynecol. 213(1): 86.e1–86.e6. 2015. PMID: 25659468. 10.1016/j.ajog.2015.01.055 KQ1E6, KQ2E6, KQ3E625659468
3 Banke-Thomas A, Rosser C, . Patient costs and outcomes before and after the institution of a pre-eclampsia quality improvement initiative in a southwestern tertiary facility. J Obstet Gynaecol (Lahore). 39(6): 748–752. 2019. PMID: 31008661. 10.1080/01443615.2019.1575343 KQ1E2c, KQ2E2c, KQ3E2c31008661
4 Berglund AC, Lindmark GC. Health services effects of a reduced routine programme for antenatal care: an area-based study. Eur J Obstet Gynecol Reprod Biol. 77(2): 193–199. 1998. 10.1016/S0301-2115(97)00270-4 KQ1E10, KQ2E10, KQ3E109578278
5 Binstock MA, Wolde-Tsadik G. Alternative prenatal care. Impact of reduced visit frequency, focused visits and continuity of care. J Reprod Med. 40(7): 507–512. 1995. PMID: 7473439. KQ1E6c, KQ2E6c, KQ3E6c7473439
6 Black MH, Zhou H, . Prehypertension prior to or during early pregnancy is associated with increased risk for hypertensive disorders in pregnancy and gestational diabetes. J Hypertens. 33(9): 1860–7; discussion 1867. 2015. PMID: 26147387. 10.1097/HJH.0000000000000646 KQ1E7, KQ2E7, KQ3E726147387
7 Boehm FH, Glass CA, . Prevention of preterm birth. Role of daily telephone contact. J Reprod Med. 41(8): 595–601. 1996. KQ1E6c, KQ2E6c, KQ3E6c8866388
8 Bronstein JM, Ounpraseuth S, . Use of specialty OB consults during high-risk pregnancies in a Medicaid-covered population: initial impact of the Arkansas ANGELS intervention. Med Care Res Rev. 69(6): 699–720. 2012. 10.1177/1077558712458157 KQ1E6, KQ2E6, KQ3E622951314
9 Butler Tobah YS, LeBlanc A, . Randomized comparison of a reduced-visit prenatal care model enhanced with remote monitoring. Am J Obstet Gynecol. 221(6): 638.e1–638.e8. 2019. 10.1016/j.ajog.2019.06.034 KQ1E6c, KQ2E6c, KQ3E6c
10 Chappell LC, McManus RJ. P-077. Self-monitoring of blood pressure in women with higher risk pregnancies: the BUMP1 multicentre randomised controlled trial. Pregnancy Hypertens. 25. 2021. 10.1016/j.preghy.2021.07.112 KQ1E11, KQ2E11, KQ3E11
11 Chappell L, Tucker K, . Self-monitoring of blood pressure in women with pregnancy hypertension: the BUMP2 multicentre randomised controlled trial. J Hypertens. 39(Suppl 1): e9. 2021. 10.1097/01.hjh.0000744452.18575.74 KQ1E2c, KQ2E2c, KQ3E2c
12 Chappell LC, Tucker K, . P-094. Self-monitoring of blood pressure in women with pregnancy hypertension: the BUMP2 multicentre randomised controlled trial. Pregnancy Hypertens. 25. e59–e60. 2021. 10.1016/j.preghy.2021.07.129 KQ1E2c, KQ2E2c, KQ3E2c
13 13. Chappell, LC, Tucker, KL, . Blood pressure monitoring in pregnant women with hypertension for improving blood pressure control: the BUMP2 randomised controlled trial. 2021. KQ1E2c, KQ2E2c, KQ3E2c
14 Cluver C, Tong S. Revisiting blood pressure thresholds to define hypertension during pregnancy: is 140/90 mmHg too high? Lancet Global Health. 9(8): e1041–e1042. 2021. 10.1016/S2214-109X(21)00285-0 KQ1E3a, KQ2E3a, KQ3E3a34237264
15 Cordisco A, Periti E, . Clinical implementation of pre-eclampsia screening in the first trimester of pregnancy. Pregnancy Hypertens. 25. 34–38. 2021. 10.1016/j.preghy.2021.05.010 KQ1E6b, KQ2E6b, KQ3E6b34051436
16 Dalfo Pibernat A, Garcia Millan R, . Approach of pre-eclampsia: importance of home blood pressure monitoring and ambulatory blood pressure monitoring in the early detection. Int Nurs Rev. 68(1): 138. 2021. PMID: 33891769. 10.1111/inr.12664 KQ1E3a, KQ2E3a, KQ3E3a33891769
17 Damiano E, Theiler R. Improved value of individual prenatal care for the interdisciplinary team. J Pregnancy. 2018. 3515302. 10.1155/2018/3515302 KQ1E6c, KQ2E6c, KQ3E6c
18 Farrar D, Tuffnell D, . An evaluation of the influence of the publication of the UK National Institute for Health and Care Excellence’s guidance on hypertension in pregnancy: a retrospective analysis of clinical practice. BMC Pregnancy Childbirth. 20(1): 101. 2020. PMID: 32050920. 10.1186/s12884-020-2780-y KQ1E6, KQ2E6, KQ3E632050920
19 Greeley ET, Terry KL, . [251-POS]: Risk of eclampsia compared to number of prenatal visits. Pregnancy Hypertens. 5(1): 126–127. 2015. PMID: 25787601. KQ1E3, KQ2E3, KQ3E3
20 Greeley ET, Terry KL, . [257-POS]: Risk of gestational hypertension in relation to number of prenatal visits. Pregnancy Hypertens. 5(1): 129. 2015. PMID: 25787606. KQ1E3, KQ2E3, KQ3E3
21 Hannola K, Hoppu S, . Obstetric early warning system to predict maternal morbidity of pre-eclampsia, postpartum hemorrhage and infection after birth in high-risk women: a prospective cohort study. Midwifery. 99. 103015. 2021. PMID: 33915316. 10.1016/j.midw.2021.103015 KQ1E6, KQ2E6, KQ3E633915316
22 Hauspurg A, Lemon LS, . A postpartum remote hypertension monitoring protocol implemented at the hospital level. Obstet Gynecol. 134(4): 685–691. 2019. PMID: 31503166. 10.1097/AOG.0000000000003479 KQ1E2c, KQ2E2c, KQ3E2c31503166
23 Hirshberg A, Aviles DJ, . 7: text message remote blood pressure monitoring eliminated racial disparities in postpartum hypertension care. Am J Obstet Gynecol. 220(1): S6. 2019. 10.1016/j.ajog.2018.11.008 KQ1E2c, KQ2E2c, KQ3E2c
24 Hirshberg A, Sammel MD, . Text message remote monitoring reduced racial disparities in postpartum blood pressure ascertainment. Am J Obstet Gynecol. 221(3): 283–285. 2019. PMID: 31121137. 10.1016/j.ajog.2019.05.011 KQ1E2c, KQ2E2c, KQ3E2c31121137
25 Hoppe KK, Thomas N, . Telehealth with remote blood pressure monitoring compared with standard care for postpartum hypertension. Am J Obstet Gynecol. 223(4): 585–588. 2020. PMID: 32439388. 10.1016/j.ajog.2020.05.027 KQ1E2c, KQ2E2c, KQ3E2c32439388
26 Ivey TL, Hughes D, . Antenatal management of at-risk pregnancies from a distance. Aust N Z J Obstet Gynaecol. 55(1): 87–9. 2015. 10.1111/ajo.12254 KQ1E3, KQ2E3, KQ3E325355283
27 Jeganathan S, Prasannan L, . Adherence and acceptability of telehealth appointments for high-risk obstetrical patients during the coronavirus disease 2019 pandemic. Am J Obstet Gynecol MFM. 2(4): 100233. 2020. 10.1016/j.ajogmf.2020.100233 KQ1E4, KQ2E4, KQ3E432984803
28 Jewell D, Sharp D, . A randomised controlled trial of flexibility in routine antenatal care. BJOG. 107(10): 1241–7. 2000. 10.1111/j.1471-0528.2000.tb11614.x KQ1E6c, KQ2E6c, KQ3E6c11028575
29 Johnsen H, Blom KF, . Using eHealth to increase autonomy supportive care: a multicenter intervention study in antenatal care. Comput Inform Nurs. 36(2): 77–83. 2018. 10.1097/cin.0000000000000389 KQ1E6, KQ2E6, KQ3E628984634
30 Johnson G. Changing to ‘new style’ antenatal care. Br J Midwifery. 6(9): 564–567. 1998. KQ1E6c, KQ2E6c, KQ3E6c
31 Kildea S, Gao Y, . Effect of a Birthing on Country service redesign on maternal and neonatal health outcomes for First Nations Australians: a prospective, non-randomised, interventional trial. Lancet Global Health. 9(5): e651–e659. 2021. 10.1016/S2214-109X(21)00061-9 KQ1E6c, KQ2E6c, KQ3E6c33743199
32 Kitt JA, Fox RL, . Short-term postpartum blood pressure self-management and long-term blood pressure control: a randomized controlled trial. Hypertension. 78(2): 469–479. 2021. 10.1161/HYPERTENSIONAHA.120.17101 KQ1E2c, KQ2E2c, KQ3E2c34176288
33 Leighton C, Conroy M, . Implementation and impact of a maternal-fetal medicine telemedicine program. Am J Perinatol. 36(7): 751–758. 2019. 10.1055/s-0038-1675158 KQ1E2a, KQ2E2a, KQ3E2a30380582
34 Litwinska M, Syngelaki A, . Management of pregnancies after combined screening for pre-eclampsia at 19-24 weeks’ gestation. Ultrasound Obstet Gynecol. 52(3): 365–372. 2018. PMID: 29943498. 10.1002/uog.19099 KQ1E6, KQ2E6, KQ3E629943498
35 Marko KI, Ganju N, . A mobile prenatal care app to reduce in-person visits: prospective controlled trial. JMIR Mhealth Uhealth. 7(5): e10520. 2019. 10.2196/10520 KQ1E6c, KQ2E6c, KQ3E6c31042154
36 Marko KI, Krapf JM, . Testing the feasibility of remote patient monitoring in prenatal care using a mobile app and connected devices: a prospective observational trial. JMIR Res Protoc. 5(4): e200. 2016. 10.2196/resprot.6167 KQ1E6c, KQ2E6c, KQ3E6c27864167
37 Matsubara S, Suzuki H, . Eclampsia and hypertension: difficult to predict based solely on blood pressure monitoring. Acta Obstet Gynecol Scand. 95(12): 1448. 2016. PMID: 27538383. 10.1111/aogs.13001 KQ1E3a, KQ2E3a, KQ3E3a27538383
38 McManus R. SY7-3. Trials of IT based-telemonitoring of blood pressure for pregnant women at higher risk: an overview of the BUMP trials. Pregnancy Hypertens. 25. e10. 2021. 10.1016/j.preghy.2021.07.280 KQ1E3a, KQ2E3a, KQ3E3a
39 Moore ML, Meis PJ, . A randomized trial of nurse intervention to reduce preterm and low birth weight births. Obstet Gynecol. 91(5 Pt 1): 656–61. 1998. 10.1016/s0029-7844(98)00012-x KQ1E6c, KQ2E6c, KQ3E6c9572206
40 Nakagawa K, Umazume T, . Feasibility and safety of urgently initiated maternal telemedicine in response to the spread of COVID-19: a 1-month report. J Obstet Gynaecol Res. 46(10): 1967–1971. 2020. 10.1111/jog.14378 KQ1E3, KQ2E3, KQ3E332691488
41 Ohno Y, Terauchi M, . The risk factors for labor onset hypertension. Hypertens Res. 39(4): 260–265. 2016. PMID: 26490090. 10.1038/hr.2015.112 KQ1E7, KQ2E7, KQ3E726490090
42 Panaitescu AM, Wright D, . Proposed clinical management of pregnancies after combined screening for pre-eclampsia at 35-37 weeks’ gestation. Ultrasound Obstet Gynecol. 50(3): 383–387. 2017. PMID: 28133834. 10.1002/uog.17419 KQ1E6, KQ2E6, KQ3E628133834
43 Partridge CA, Holman JR. Effects of a reduced-visit prenatal care clinical practice guideline. J Am Board Fam Pract. 18(6): 555. 2005. 10.3122/jabfm.18.6.555 KQ1E6c, KQ2E6c, KQ3E6c16322418
44 Peahl AF, Powell A, . Patient and provider perspectives of a new prenatal care model introduced in response to the coronavirus disease 2019 pandemic. Am J Obstet Gynecol. 224(4): 384.e1–384.e11. 2021. 10.1016/j.ajog.2020.10.008 KQ1E4, KQ2E4, KQ3E4
45 Pealing L, Crawford C, . Self-monitoring blood pressure in hypertensive pregnancies: the OPTIMUM-BP pilot randomized controlled trial. BJOG. 126(6): e139. 2019. 10.1111/1471-0528.15677 KQ1E2c, KQ2E2c, KQ3E2c
46 Pealing LM, Tucker KL, . A randomised controlled trial of blood pressure self-monitoring in the management of hypertensive pregnancy. OPTIMUM-BP: A feasibility trial. Pregnancy Hypertens. 18. 141–149. 2019. PMID: 31618706. 10.1016/j.preghy.2019.09.018 KQ1E2c, KQ2E2c, KQ3E2c31618706
47 Perry H, Sheehan E, . Home blood-pressure monitoring in a hypertensive pregnant population. Ultrasound Obstet Gynecol. 51(4): 524–530. 2018. PMID: 29468771. 10.1002/uog.19023 KQ1E2c, KQ2E2c, KQ3E2c29468771
48 Pflugeisen BM, McCarren C, . Virtual visits: managing prenatal care with modern technology. MCN Am J Matern Child Nurs. 41(1): 24–30. 2016. 10.1097/nmc.0000000000000199 KQ1E6c, KQ2E6c, KQ3E6c26474477
49 Pflugeisen BM, Mou J. Patient satisfaction with virtual obstetric care. Matern Child Health J. 21(7): 1544–1551. 2017. 10.1007/s10995-017-2284-1 KQ1E4, KQ2E4, KQ3E428176034
50 Pluym Id, Tandel M, . 57 Randomized control trial of postpartum visits at 2 weeks and 6 weeks. Am J Obstet Gynecol. 224(2): S40. 2021. 10.1016/j.ajog.2020.12.055 KQ1E4, KQ2E4, KQ3E4
51 Pluym Id, Tandel MD, . Randomized control trial of postpartum visits at 2 and 6 weeks. Am J Obstet Gynecol MFM. 3(4): 100363. 2021. 10.1016/j.ajogmf.2021.100363 KQ1E4, KQ2E4, KQ3E433785465
52 Rhodes CA, Beevers DG, . A randomized trial of ambulatory blood pressure monitoring versus clinical blood pressure measurement in the management of hypertension in pregnancy. A feasibility study. Pregnancy Hypertens. 11. 142–144. 2018. PMID: 29523267. 10.1016/j.preghy.2017.09.006 KQ1E2c, KQ2E2c, KQ3E2c29523267
53 Rolnik DL, Selvaratnam RJ, . Routine first trimester combined screening for preterm preeclampsia in Australia: a multicenter clinical implementation cohort study. Int J Gynaecol Obstet. 27. 27. 2021. 10.1002/ijgo.14049 KQ1E6, KQ2E6, KQ3E6
54 Salazar MR, Espeche WG, . Nocturnal hypertension and risk of developing early-onset preeclampsia in high-risk pregnancies. Hypertens Res. 44(12): 1633–1640. 2021. 10.1038/s41440-021-00740-z KQ1E7, KQ2E7, KQ3E734480133
55 Salazar MR, Espeche WG, . Office blood pressure values and the necessity of out-of-office measurements in high-risk pregnancies. J Hypertens. 37(9): 1838–1844. 2019. PMID: 31157745. 10.1097/HJH.0000000000002140 KQ1E7, KQ2E7, KQ3E731157745
56 Salazar MR, Espeche WG, . Significance of masked and nocturnal hypertension in normotensive women coursing a high-risk pregnancy. J Hypertens. 34(11): 2248–52. 2016. PMID: 27490952. 10.1097/HJH.0000000000001067 KQ1E7, KQ2E7, KQ3E727490952
57 Schneider P, Lee King PA, . Improving the timely delivery of antihypertensive medication for severe perinatal hypertension in pregnancy and postpartum. Am J Perinatol. 02. 02. 2021. PMID: 33934326. 10.1055/s-0041-1728835 KQ1E6, KQ2E6, KQ3E633934326
58 Shinar S, Melamed N, . Changes in rate of preterm birth and adverse pregnancy outcomes attributed to preeclampsia after introduction of a refined definition of preeclampsia: a population-based study. Acta Obstet Gynecol Scand. 27. 27. 2021. PMID: 34043808. 10.1111/aogs.14199 KQ1E6, KQ2E6, KQ3E634043808
59 Snaith VJ, Hewison J, . Antenatal telephone support intervention with and without uterine artery Doppler screening for low risk nulliparous women: a randomised controlled trial. BMC Pregnancy Childbirth. 14. 121. 2014. 10.1186/1471-2393-14-121 KQ1E5, KQ2E5, KQ3E524685072
60 Spencer NM, Gabra M, . Improving compliance with guidelines for hypertensive disorders of pregnancy through an electronic health record alert: a retrospective chart review. Pregnancy Hypertens. 25. 1–6. 2021. PMID: 34004478. 10.1016/j.preghy.2021.04.001 KQ1E2c, KQ2E2c, KQ3E2c34004478
61 Tayyar A, Garcia-Tizon Larroca S, . Competing risk model in screening for preeclampsia by mean arterial pressure and uterine artery pulsatility index at 30-33 weeks’ gestation. Fetal Diagn Ther. 36(1): 18–27. 2014. PMID: 24970282. 10.1159/000360792 KQ1E6, KQ2E6, KQ3E624970282
62 Topel ML, Duncan EM, . Estimated impact of the 2017 American College of Cardiology/American Heart Association blood pressure guidelines on reproductive-aged women. hypertension. 72(4): e39–e42. 2018. PMID: 30354726. 10.1161/HYPERTENSIONAHA.118.11660 KQ1E6, KQ2E6, KQ3E630354726
63 Tucker JS, Hall MH, . Should obstetricians see women with normal pregnancies? A multicentre randomised controlled trial of routine antenatal care by general practitioners and midwives compared with shared care led by obstetricians. BMJ. 312. 554–559. 1996. PMID: 8595287. KQ1E6, KQ2E6, KQ3E68595287
64 Tucker KL, Taylor KS, . Blood pressure self-monitoring in pregnancy: examining feasibility in a prospective cohort study. BMC Pregnancy Childbirth. 17(1): 442. 2017. PMID: 29284456. 10.1186/s12884-017-1605-0 KQ1E7, KQ2E7, KQ3E729284456
65 van den Heuvel JFM, Kariman SS, . SAFE@HOME - Feasibility study of a telemonitoring platform combining blood pressure and preeclampsia symptoms in pregnancy care. Eur J Obstet Gynecol Reprod Biol. 240. 226–231. 2019. PMID: 31330428. 10.1016/j.ejogrb.2019.07.012 KQ1E10, KQ2E10, KQ3E1031330428
66 van den Heuvel JFM, Lely AT, . SAFE@HOME: Digital health platform facilitating a new care path for women at increased risk of preeclampsia - A case-control study. Pregnancy Hypertens. 22. 30–36. 2020. PMID: 32717653. 10.1016/j.preghy.2020.07.006 KQ1E10, KQ2E10, KQ3E1032717653
67 van den Heuvel JFM, van Lieshout C, . SAFE@HOME: Cost analysis of a new care pathway including a digital health platform for women at increased risk of preeclampsia. Pregnancy Hypertens. 24. 118–123. 2021. PMID: 33813364. 10.1016/j.preghy.2021.03.004 KQ1E10, KQ2E10, KQ3E1033813364
68 Villar J, Ba’aqeel H, . Who antenatal care randomised trial for the evaluation of a new model of routine antenatal care. Lancet. 357(9268): 1551–1564. 2001. PMID: 11377642. KQ1E1b, KQ2E1b, KQ3E1b11377642
69 Wang L, Xing W, . Observation of personalized obstetric care clinical intervention on perinatal pregnancy-induced hypertension. Int J Clin Exp Med. 9(11): 22345–22350. 2016. KQ1E1b, KQ2E1b, KQ3E1b
70 Wright D, Dragan I, . Proposed clinical management of pregnancies after combined screening for pre-eclampsia at 30-34 weeks’ gestation. Ultrasound Obstet Gynecol. 49(2): 194–200. 2017. PMID: 27671544. 10.1002/uog.17309 KQ1E6, KQ2E6, KQ3E627671544
71 Xydopoulos G, Perry H, . Home blood-pressure monitoring in a hypertensive pregnant population: cost-minimization study. Ultrasound Obstet Gynecol. 53(4): 496–502. 2019. PMID: 29516615. 10.1002/uog.19041 KQ1E2c, KQ2E2c, KQ3E2c29516615