# Appendix B Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

- McDuffie RS Jr, Beck A, Bischoff K, Cross J, Orleans M. Effect of frequency of prenatal care visits on perinatal outcome among low-risk women. A randomized controlled trial. JAMA. 275(11): 847–851. 1996. PMID: 8596222.8596222
  - McDuffie R, Bischoff K, . An evaluation of risk-based prenatal care: a randomized controlled trial. Am J Obstet Gynecol. 172: 270. 1995.
  - McDuffie R, Bischoff, K, Beck A, Orleans M. Does reducing the number of prenatal office visits for low-risk women result in increased use of other medical services? Obstet Gynecol. 90(1): 68–70. 1997.9207816
- Rhode MA, Shapiro H, Jones OH 3rd. Indicated vs. routine prenatal urine chemical reagent strip testing. J Reprod Med. 52(3): 214–219. 2007. PMID: 17465289.17465289
- Ross-McGill H, Hewison J, Hirst J, . Antenatal home blood pressure monitoring: a pilot randomised controlled trial. BJOG. 107(2): 217–221. 2000. PMID: 10688505.10688505
- Sikorski J, Wilson J, Clement S, Das S, Smeeton N. A randomised controlled trial comparing two schedules of antenatal visits: the antenatal care project. BMJ. 312(7030): 546–553. 1996. PMID: 8595286.8595286
  - Clement S, Candy B, Sikorski J, Wilson J, Smeeton N. Does reducing the frequency of routine antenatal visits have long term effects? Follow up of participants in a randomised controlled trial. BJOG. 106(4): 367–370. 1999.
  - Henderson J, Roberts T, Sikorski J, Wilson J, Clement S. An economic evaluation comparing two schedules of antenatal visits. J Health Serv Res Policy. 5(2): 69–75. 2000.10947550
- Tucker K, Mort S, . A randomised controlled trial of self-monitoring of blood pressure during higher risk pregnancy: The BUMP1 trial. 2021.
- Walker DS, Koniak-Griffin D. Evaluation of a reduced-frequency prenatal visit schedule for low-risk women at a free-standing birthing center. J Nurse Midwifery. 42(4): 295–303. 1997.9277060