# Appendix A Detailed Methods

## Search Strategy

Key:

- / = MeSH subject heading
- $ = truncation
- ti = word in title
- ab = word in abstract
- pt = publication type
- * = truncation
- kw = keyword
- adj = adjacent

### MEDLINE

Database: Ovid MEDLINE(R) and Epub Ahead of Print, In-Process, In-Data-Review & Other Non-Indexed Citations and Daily <1946 to May 28, 2021>

Search Strategy:

------------------------------------------------------------

1. Pre-Eclampsia/
2. Hypertension, Pregnancy-Induced/
3. Eclampsia/
4. HELLP Syndrome/
5. Pregnancy/
6. Pregnancy Trimester, First/
7. Pregnancy Trimester, Second/
8. Pregnancy Trimester, Third/
9. Postpartum Period/
10. Hypertension/
11. (5 or 6 or 7 or 8 or 9) and 10
12. (preeclamp$ or pre eclamp$).ti.
13. eclamp$.ti. (8692)
14. gestosis.ti. (776)
15. HELLP.ti. (1269)
16. ((gestational or pregnan$ or postpartum or antepartum or puerper$ or prenatal or antenatal or perinatal or peripartum) and (tox?emi$ or hypertens$ or blood pressure)).ti.
17. 1 or 2 or 3 or 4 or 11 or 12 or 13 or 14 or 15 or 16
18. Blood pressure/
19. Blood pressure determination/
20. Blood pressure monitoring, Ambulatory/
21. Blood pressure monitors/
22. Urinalysis/
23. Proteinuria/
24. ((blood or systolic or diastolic) adj pressure).ti,ab.
25. urinalys$.ti,ab.
26. (urine adj (measur$ or analy$ or test$ or collect$)).ti,ab.
27. (proteinuria or albuminuria or urine albumin).ti,ab.
28. or/18-27
29. Mass screening/
30. screen$.ti,ab.
31. (detect$ or predict$ or identif$).ti.
32. 29 or 30 or 31
33. 17 and (28 or 32)
34. 33 not (animals/ not humans/)
35. limit 34 to (english language and yr="2014 -Current")

### Cochrane Central Register of Controlled Clinical Trials (http://www.thecochranelibrary.com/) (CENTRAL)

ID Search Hits
#1 preeclamp*:ti,ab,kw
#2 (pre-eclampsia or pre-eclamptic):ti,ab,kw
#3 eclamp*:ti,ab,kw
#4 gestosis:ti,ab,kw
#5 HELLP:ti,ab,kw
#6 #1 or #2 or #3 or #4 or #5
#7 hypertension:ti,ab,kw
#8 hypertensive:ti,ab,kw
#9 (toxemi*:ti,ab,kw or toxaemi*:ti,ab,kw)
#10 “blood pressure”:ti,ab,kw near/5 (high or elevated or abnormal):ti,ab,kw
#11 #7 or #8 or #9 or #10
#12 (pregnancy or pregnant):ti,ab,kw
#13 (prenatal or antenatal or perinatal or peripartum):ti,ab,kw
#14 gestational:ti,ab,kw
#15 (postpartum or antepartum):ti,ab,kw
#16 peurper*:ti,ab,kw
#17 #12 or #13 or #14 or #15 or #16
#18 #11 and #17
#19 #6 or #18
#20 screen*:ti,ab,kw
#21 (detect* or predict* or identif*):ti
#22 (blood or systolic or diastolic):ti,ab,kw next pressure:ti,ab,kw
#23 urinalys*:ti,ab,kw
#24 urine:ti,ab,kw next (measur* or analy* or test* or collect*):ti,ab,kw
#25 (proteinuria or albuminuria or “urine albumin”):ti,ab,kw
#26 risk*:ti,ab,kw
#27 “multivariable prediction”:ti,ab,kw
#28 #20 or #21 or #22 or #23 or #24 or #25 #26 or #27
#29 #19 and #28 with Publication Year from 2014 to present, in Trials

Appendix A Table 1 Inclusion and Exclusion Criteria

Category | Inclusion Criteria | Exclusion Criteria
Populations | Studies among pregnant persons without a diagnosis of hypertensive disorders of pregnancy, including pregnant persons with common chronic conditions managed in usual primary/prenatal care (i.e., chronic hypertension, diabetes mellitus) | Studies that exclusively include:; - Inpatients or hospitalized persons; - Other selected nongeneralizable populations or populations with other preexisting health conditions requiring specialized prenatal care (e.g., HIV, hepatitis, renal disease, organ transplant recipients, sickle cell trait)
Interventions | Screening programs used to identify preeclampsia and other hypertensive disorders of pregnancy over the course of pregnancy and in the postpartum period (up to 8 weeks after delivery), including studies comparing screening with different protocols in terms of:; - Blood pressure measurement, setting (office or home), interval, frequency, or timing; - Proteinuria assessment setting, interval, or sequence of testing; - Personalization of screening based on risk assessment | Secondary evaluations and tests used to confirm diagnosis or assess preeclampsia severity; Prognostic evaluation used to inform disease management
Comparisons | Usual care screening programs, as defined by the study
Outcomes | KQ1 (maternal and perinatal health outcomes):; Maternal; - Eclamptic seizure; - Stroke; - Cardiomyopathy, myocardial infarction; - Renal or hepatic injury/failure; - Pulmonary edema, adult respiratory distress syndrome; - Venous thromboembolism (deep vein thrombosis/pulmonary embolism); - Disseminated intravascular coagulation; - Longer-term health consequences from complications of pregnancy; - Maternal mortality; Fetal/infant; - Preterm birth (<37 weeks): late preterm birth (34–36 weeks), moderate preterm birth, (32–34 weeks), very preterm birth (<32 weeks), extremely preterm birth (<28 weeks); - Gestational age at birth; - Low birth weight (weight <2,500 g); - Intrauterine growth restriction/small for gestational age (<10th percentile weight for gestational age); - Stillbirth or neonatal mortality; - Longer-term health consequences from exposure to maternal hypertensive disorders; KQ 2 (hypertensive disorders of pregnancy):; - Gestational hypertension; - Preeclampsia, preeclampsia with severe features; - Hemolysis, elevated liver enzymes, and low platelet count (HELLP) syndrome; - Chronic hypertension with superimposed preeclampsia; - Timing of diagnosis; KQ 3 (harms):; - Missed diagnosis (e.g., diagnosis timing, severity at time of diagnosis); - Overdiagnosis and overtreatment (e.g., increased labor induction, cesarean delivery, induced preterm birth, hypermagnesemia); - Mental health diagnoses or symptoms; - Reduced quality of life | Nonclinical health outcomes, such as length of hospital stay (without indication), intensive care unit admission, or neonatal intensive care unit admission
Setting | Primary care outpatient settings for obstetric care (e.g., obstetrician-gynecologists, family physicians, certified nurse midwives); Countries categorized as “Very High” or equivalent on the Human Development Index (as defined by the United Nations Development Programme) | Clinics and study sites treating only high-risk maternity patients
Study Designs | Randomized, controlled trials, controlled clinical trials, and nonrandomized studies comparing screening programs (e.g., comparisons over time or between settings, population cohort studies, nested case-control studies) | Studies that do not represent the spectrum of disease (e.g., case-control study, editorial, narrative review, commentary, postmarketing surveillance, and case report)
Publication Dates | References from the previous USPSTF review, and eligible studies identified through a bridge search
Study Quality | Good and fair quality according to USPSTF design-specific criteria | Poor quality according to USPSTF design-specific criteria
Language | English | Non-English language studies

Appendix A Table 2 Study Design-Specific Quality Rating Criteria

Study Design | Adapted Quality Criteria^*^
Randomized and controlled trials, adapted from the U.S. Preventive Services Task Force methods^144^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported
Cohort studies, adapted from Risk Of Bias In Non-randomized Studies - of Interventions (ROBINS-I)^145^ | Bias arising in randomization process or due to confounding; - Balance in baseline characteristics; - No baseline confounding; - No time-varying confounding; Bias in selecting participants into the study; - No evidence of biased selection of sample; - Start of followup and start of intervention coincide; Bias due to departures form intended interventions; - Participant intervention status is clearly and explicitly defined and measured; - Classification of intervention status is unaffected by knowledge of the outcome or risk of the outcome; Bias in classifying interventions; - Fidelity to intervention protocol; - Participants were analyzed as originally allocated; Bias from missing data; - Outcome data are reasonably complete and comparable between groups; - Confounding variables that are controlled for in analysis are reasonably complete; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; No evidence that the measures, analyses, or subgroup analyses are selectively reported

* Good-quality studies generally meet all quality criteria. Fair-quality studies do not meet all the criteria but do not have critical limitations that could invalidate study findings. Poor-quality studies have a single fatal flaw or multiple important limitations that could invalidate study findings. Critical appraisal of studies using a priori quality criteria are conducted independently by at least two reviewers. Disagreements in final quality assessment are resolved by consensus, and, if needed, consultation with a third independent reviewer

Appendix A Figure 1 Literature Flow Diagram

^*^Studies may appear in more than one Key Question.

This figure is a flow chart that summarizes the search and selection of articles in this review. There were 13,252 citations identified through literature databases. An additional 24 citations were identified from outside sources, and 382 citations were identified from the previous systematic review. After duplicates were removed, 6,316 unique citations were screened at the title/abstract stage. The full-text of 82 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1 (k=5), Key Question 2 (k=5), and Key Question 3 (k=6). Reasons for excluding the other articles are available in Appendix C.