# References

1 U.S. Preventive Services Task Force. Recommendation Statement: Latent Tuberculosis Infection: Screening. September 2016. https://uspreventiveservicestaskforce.org/uspstf/index.php/recommendation/latent-tuberculosis-infection-screening. Accessed 1 December 2021.
2 Centers for Disease Control and Prevention. Tuberculosis: Basic TB Facts. Atlanta, GA: Centers for Disease Control and Prevention; 2016. https://www.cdc.gov/tb/topic/basics/default.htm. Accessed June 2020.
3 Houben RMGJ, Dodd PJ. The global burden of latent tuberculosis infection: a re-estimation using mathematical modelling. PLoS Med. 2016;13(10):e1002152. doi: 10.1371/journal.pmed.1002152.27780211
4 World Health Organization. Global tuberculosis report 2020. Geneva, Switzerland: 2020.
5 Centers for Disease Control and Prevention, National Center for Health Statistics. Infectious disease. Atlanta, GA: Centers for Disease Control and Prevention; 2020. https://www.cdc.gov/nchs/fastats/infectious-disease.htm. Accessed 29 October 2020.
6 Centers for Disease Control and Prevention. Tuberculosis: Trends in Tuberculosis, 2019. Atlanta, GA: Centers for Disease Control and Prevention; 2019. https://www.cdc.gov/tb/publications/factsheets/statistics/tbtrends.htm. Accessed 8 November 2020.
7 Centers for Disease Control and Prevention. Reported Tuberculosis in the United States, 2020: Table 1. Tuberculosis Cases, Incidence Rates per 100,000 Population, Deaths, and Death Rates per 100,000 Population, and Percentage Change: United States, 1953-2020. https://www.cdc.gov/tb/statistics/reports/2020/table1.htm. Accessed 1 December 2021.
8 Centers for Disease Control and Prevention. Table 5. Tuberculosis cases, percentages, and incidence rates per 100,000 population by origin of birth: United States, 1993-2020. 2020. https://www.cdc.gov/tb/statistics/reports/2020/table23.htm. Accessed 5 January 2022.
9 Centers for Disease Control and Prevention. Table 6A. Tuberculosis Cases and Percentages among Non-U.S.-Born Persons by the Top 30 Countries of Birth: United States, 2016-2020. 2020. Accessed 22 December 2021.
10 Geng E, Kreiswirth B, Driver C, Changes in the transmission of tuberculosis in New York City from 1990 to 1999. N Engl J Med. 2002 May 9;346(19):1453–8. doi: 10.1056/NEJMoa012972. PMID: 12000815.12000815
11 Chin DP, DeRiemer K, Small PM, Differences in contributing factors to tuberculosis incidence in U.S.-born and foreign-born persons. Am J Respir Crit Care Med. 1998 1998/12/01;158(6):1797–803. doi: 10.1164/ajrccm.158.6.9804029.9847270
12 Talbot EA, Moore M, McCray E, Tuberculosis among foreign-born persons in the United States, 1993-1998. JAMA. 2000;284(22):2894–900. doi: 10.1001/jama.284.22.2894.11147986
13 Borgdorff MW, Behr MA, Nagelkerke NJ, Transmission of tuberculosis in San Francisco and its association with immigration and ethnicity. Int J Tuberc Lung Dis. 2000;4(4):287–94.10777075
14 Jasmer RM, Ponce de Leon A, Hopewell PC, Tuberculosis in Mexican-born persons in San Francisco: reactivation, acquired infection and transmission. Int J Tuberc Lung Dis. 1997 Dec;1(6):536–41. PMID: 9487452.9487452
15 Walter ND, Jasmer RM, Grinsdale J, Reaching the limits of tuberculosis prevention among foreign-born individuals: a tuberculosis-control program perspective. Clin Infect Dis. 2008 Jan 1;46(1):103–6. doi: 10.1086/523733. PMID: 18171222.18171222
16 Centers for Disease Control and Prevention. Table 2. Tuberculosis Cases, Percentages, and Incidence Rates per 100,000 Population by Hispanic Ethnicity and Non-Hispanic Race: United States, 1993-2020. Atlanta, GA: CDC; 2020. https://www.cdc.gov/tb/statistics/reports/2020/table2.htm. Accessed 22 December 2021.
17 Centers for Disease Control and Prevention. Table 3. tuberculosis cases and percentages by hispanic ethnicity and non-hispanic race, and by origin of birth: United States, 1993-2020. Atlanta, GA: CDC; 2020. Accessed 22 December 2021.
18 Centers for Disease Control and Prevention. Take on Tuberculosis. Atlanta, GA: CDC; 2020. Accessed 6 January 2022.
19 Centers for Disease Control and Prevention. Table 33. Tuberculosis Cases and Percentages among Non-U.S.-Born Persons, by Number of Years in the united states: United States and the District of Columbia, 2020. Atlanta, GA: CDC; 2020. https://www.cdc.gov/tb/statistics/reports/2020/table33.htm. Accessed 22 December 2021.
20 Centers for Disease Control and Prevention. Table 29. Tuberculosis Cases and Incidence Rates per 100,000 Population, Ranked and Grouped by Number of Cases: United States and the District of Columbia, 2020 and 2019. Atlanta, GA: CDC; 2020. https://www.cdc.gov/tb/statistics/reports/2020/table29.htm. Accessed 22 December 2021.
21 Centers for Disease Control and Prevention. Tuberculosis (TB) (Mycobacterium tuberculosis). Atlanta, GA: Centers for Disease Control and Prevention; 2015. https://ndc.services.cdc.gov/case-definitions/tuberculosis-2009/. Accessed 8 June 2015.
22 World Health Organization. Latent TB Infection. Geneva, Switzerland: World Health Organization; 2018. https://www.who.int/tb/areas-of-work/preventive-care/ltbi_factsheet_2march18.pdf. Accessed 22 December 2021.
23 Centers for Disease Control and Prevention. Latent TB Infection (TB Infection): 2018 Case Definition. https://ndc.services.cdc.gov/case-definitions/latent-tb-infection-2018/. Accessed 6 August 2022.
24 Getahun H, Matteelli A, Chaisson RE, Latent Mycobacterium tuberculosis infection. N Engl J Med. 2015 May 28;372(22):2127–35. doi: 10.1056/NEJMra1405427. PMID: 26017823.26017823
25 Miramontes R, Hill AN, Yelk Woodruff RS, Tuberculosis infection in the United States: prevalence estimates from the National Health and Nutrition Examination Survey, 2011-2012. PLoS One. 2015;10(11):e0140881. doi: 10.1371/journal.pone.0140881. PMID: 26536035.26536035
26 Haddad MB, Raz KM, Lash TL, Simple estimates for local prevalence of latent tuberculosis infection, United States, 2011-2015. Emerg Infect Dis. 2018 Oct;24(10):1930–3. doi: 10.3201/eid2410.180716. PMID: 30226174.30226174
27 McAdam JM, Bucher SJ, Brickner PW, Latent tuberculosis and active tuberculosis disease rates among the homeless, New York, New York, USA, 1992-2006. Emerg Infect Dis. 2009 Jul;15(7):1109–11. doi: 10.3201/eid1507.080410. PMID: 19624932.19624932
28 Grzybowski S, Barnett GD, Styblo K. Contacts of cases of active pulmonary tuberculosis. Bull Int Union Tuberc. 1975;50(1):90–106. PMID: 1218291.1218291
29 Marks SM, Taylor Z, Qualls NL, Outcomes of contact investigations of infectious tuberculosis patients. Am J Respir Crit Care Med. 2000 Dec;162(6):2033–8. doi: 10.1164/ajrccm.162.6.2004022. PMID: 11112109.11112109
30 American Thoracic Society, Centers for Disease Control and Prevention. Targeted tuberculin testing and treatment of latent tuberculosis infection. MMWR Recomm Rep. 2000 Jun 9;49(RR-6):1–51. PMID: 10881762.10881762
31 Ferebee SH. Controlled chemoprophylaxis trials in tuberculosis. A general review. Bibl Tuberc. 1970;26:28–106. PMID: 4903501.4903501
32 Horsburgh CR Jr. Priorities for the treatment of latent tuberculosis infection in the United States. N Engl J Med. 2004 May 13;350(20):2060–7. doi: 10.1056/NEJMsa031667. PMID: 15141044.15141044
33 Sloot R, Schim van der Loeff MF, Kouw PM, Risk of tuberculosis after recent exposure. A 10-year follow-up study of contacts in Amsterdam. Am J Respir Crit Care Med. 2014 Nov 1;190(9):1044–52. doi: 10.1164/rccm.201406-1159OC. PMID: 25265362.25265362
34 Shea KM, Kammerer JS, Winston CA, Estimated rate of reactivation of latent tuberculosis infection in the United States, overall and by population subgroup. Am J Epidemiol. 2014 Jan 15;179(2):216–25. doi: 10.1093/aje/kwt246. PMID: 24142915.24142915
35 Centers for Disease Control and Prevention. Latent tuberculosis infection: a guide for primary health care providers. Publication Number 22–0468. Atlanta GA: Centers for Disease Control and Prevention; 2020. https://www.cdc.gov/tb/publications/ltbi/pdf/LTBIbooklet508.pdf
36 Cohn DL, O'Brien RJ, Geiter LJ, Targeted tuberculin testing and treatment of latent tuberculosis infection. MMWR Morb Mortal Wkly Rep. 2000;49(6):1–54.10993565
37 Lewinsohn DM, Leonard MK, LoBue PA, Official American Thoracic Society/Infectious Diseases Society of America/Centers for Disease Control and Prevention Clinical Practice Guidelines: diagnosis of tuberculosis in adults and children. Clin Infect Dis. 2017;64(2):e1–e33. doi: 10.1093/cid/ciw694.27932390
38 Centers for Disease Control and Prevention. Division of Tuberculosis Elimination Strategic Plan 2016-2020. Atlanta, GA: Centers for Disease Control and Prevention; 2016-2020. https://www.cdc.gov/tb/about/strategicplan.htm. Accessed 7 November 2020.
39 Yang H, Kruh-Garcia NA, Dobos KM. Purified protein derivatives of tuberculin--past, present, and future. FEMS Immunol Med Microbiol. 2012;66(3):273–80. doi: 10.1111/j.1574-695X.2012.01002.x. PMID: 22762692.22762692
40 Sterling TR, Njie G, Zenner D, Guidelines for the treatment of latent tuberculosis infection: recommendations from the National Tuberculosis Controllers Association and CDC, 2020. MMWR. 2020;69:1–11. doi: 10.15585/mmwr.rr6901a1.
41 Centers for Disease Control and Prevention. Tuberculosis (TB). Who Should Be Tested? Atlanta, GA: Centers for Disease Control and Prevention; 2016. https://www.cdc.gov/tb/topic/testing/whobetested.htm. Accessed 14 January 2021.
42 Kimberlin DW, Barnett ED, Lynfield R, Red book: 2021-2024 report of the committee on infectious diseases. Itasca, IL: American Academy of Pediatrics; 2021.
43 World Health Organization. Systematic Screening for Active Tuberculosis: Principles and Recommendations. Geneva, Switzerland: World Health Organization; 2013. http://www.who.int/tb/tbscreening/en/. Accessed 24 March 2014.
44 World Health Organization. Guidelines for treatment of tuberculosis. Fourth ed. Geneva, Switzerland: World Health Organization; 2010.
45 World Health Organization. Latent Tuberculosis Infection: Updated and Consolidated Guidelines for Programmatic Management. Geneva, Switzerland: World Health Organization; 2018. https://apps.who.int/iris/bitstream/handle/10665/260233/9789241550239-eng.pdf;jsessionid=683A7356F9BC0C6AAEF6B3B0FBD8CFFA?sequence=1. Accessed 14 January 2021.
46 United Nations Development Programme. Latest Human Development Index Ranking. 2020. http://hdr.undp.org/en/content/latest-human-development-index-ranking. Accessed 6 January 2022.
47 U.S. Preventive Services Task Force. Procedure manual Rockville, MD; 2015. https://www.uspreventiveservicestaskforce.org/uspstf/about-uspstf/methods-and-processes/procedure-manual. Accessed 11 November 2021.
48 West SL, Gartlehner G, Mansfield AJ, Comparative effectiveness review methods: clinical heterogeneity. 2010.
49 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials,. 1986;7(3):177–88. doi: 10.1016/0197-2456(86)90046-2.3802833
50 Nyaga VN, Arbyn M, Aerts M. Metaprop: a Stata command to perform meta-analysis of binomial data. Arch Public Health. 2014;72(1):39. doi: 10.1186/2049-3258-72-39. PMID: 25810908.25810908
51 Naaktgeboren CA, Ochodo EA, Van Enst WA, Assessing variability in results in systematic reviews of diagnostic studies. BMC Med Res Methodol. 2016 Jan 15;16:6. doi: 10.1186/s12874-016-0108-4. PMID: 26772804.26772804
52 Lee J, Kim KW, Choi SH, Systematic review and meta-analysis of studies evaluating diagnostic test accuracy: a practical review for clinical researchers-part ii. statistical methods of meta-analysis. Korean J Radiol. 2015 Nov-Dec;16(6):1188–96. doi: 10.3348/kjr.2015.16.6.1188. PMID: 26576107.26576107
53 Painter JA, Graviss EA, Hai HH, Tuberculosis screening by tuberculosis skin test or QuantiFERON-TB Gold In-Tube Assay among an immigrant population with a high prevalence of tuberculosis and BCG vaccination. PLoS One. 2013 12/19;8(12):e82727. doi: 10.1371/journal.pone.0082727. PMID: 24367546.24367546
54 Mancuso JD, Mazurek GH, Tribble D, Discordance among commercially available diagnostics for latent tuberculosis infection. Am J Respir Crit Care Med. 2012 Feb 15;185(4):427–34. doi: 10.1164/rccm.201107-1244OC. PMID: 22161162.22161162
55 Mazurek GH, Weis SE, Moonan PK, Prospective comparison of the tuberculin skin test and 2 whole-blood interferon-gamma release assays in persons with suspected tuberculosis. Clin Infect Dis. 2007 Oct 1;45(7):837–45. doi: 10.1086/521107. PMID: 17806047.17806047
56 Mazurek GH, Zajdowicz MJ, Hankinson AL, Detection of Mycobacterium tuberculosis infection in United States Navy recruits using the tuberculin skin test or whole-blood interferon-gamma release assays. Clin Infect Dis. 2007 Oct 1;45(7):826–36. doi: 10.1086/521106. PMID: 17806046.17806046
57 Kang YA, Lee HW, Yoon HI, Discrepancy between the tuberculin skin test and the whole-blood interferon gamma assay for the diagnosis of latent tuberculosis infection in an intermediate tuberculosis-burden country. JAMA. 2005 Jun 8;293(22):2756–61. doi: 10.1001/jama.293.22.2756. PMID: 15941805.15941805
58 Tsiouris SJ, Coetzee D, Toro PL, Sensitivity analysis and potential uses of a novel gamma interferon release assay for diagnosis of tuberculosis. J Clin Microbiol. 2006 Aug;44(8):2844–50. doi: 10.1128/JCM.02411-05. PMID: 16891501.16891501
59 Taggart EW, Hill HR, Ruegner RG, Evaluation of an in vitro assay for interferon gamma production in response to the Mycobacterium tuberculosis-synthesized peptide antigens ESAT-6 and CFP-10 and the PPD skin test. Am J Clin Pathol. 2006 Mar;125(3):467–73. PMID: 16613353.16613353
60 Kim EY, Park MS, Kim YS, Risk factors for false-negative results of QuantiFERON-TB Gold In-Tube assay in non-HIV-infected patients with culture-confirmed tuberculosis. Diagn Microbiol Infect Dis. 2011 Jul;70(3):324–9. doi: 10.1016/j.diagmicrobio.2011.02.011. PMID: 21546200.21546200
61 Berkel GM, Cobelens FG, de Vries G, Tuberculin skin test: estimation of positive and negative predictive values from routine data. Int J Tuberc Lung Dis. 2005 Mar;9(3):310–6. PMID: 15786896.15786896
62 Taggart EW, Hill HR, Ruegner RG, Evaluation of an in vitro assay for gamma interferon production in response to Mycobacterium tuberculosis infections. Clin Diagn Lab Immunol. 2004 Nov;11(6):1089–93. doi: 10.1128/cdli.11.6.1089-1093.2004. PMID: 15539511.15539511
63 Fietta A, Meloni F, Cascina A, Comparison of a whole-blood interferon-gamma assay and tuberculin skin testing in patients with active tuberculosis and individuals at high or low risk of Mycobacterium tuberculosis infection. Am J Infect Control. 2003 Oct;31(6):347–53. PMID: 14608301.14608301
64 Bellete B, Coberly J, Barnes GL, Evaluation of a whole-blood interferon-gamma release assay for the detection of Mycobacterium tuberculosis infection in 2 study populations. Clin Infect Dis. 2002 Jun 1;34(11):1449–56. doi: 10.1086/340397. PMID: 12015690.12015690
65 Mazurek GH, LoBue PA, Daley CL, Comparison of a whole-blood interferon gamma assay with tuberculin skin testing for detecting latent Mycobacterium tuberculosis infection. JAMA. 2001 Oct 10;286(14):1740–7. PMID: 11594899.11594899
66 Bocchino M, Chairadonna P, Matarese A, Limited usefulness of QuantiFERON-TB Gold In-Tube for monitoring anti-tuberculosis therapy. Respir Med. 2010 Oct;104(10):1551–6. doi: 10.1016/j.rmed.2010.05.011. PMID: 20542675.20542675
67 Villarino ME, Brennan MJ, Nolan CM, Comparison testing of current (PPD-S1) and proposed (PPD-S2) reference tuberculin standards. Am J Respir Crit Care Med. 2000 Apr;161(4 Pt 1):1167–71. doi: 10.1164/ajrccm.161.4.9906050. PMID: 10764307.10764307
68 Villarino ME, Burman W, Wang YC, Comparable specificity of 2 commercial tuberculin reagents in persons at low risk for tuberculous infection. JAMA. 1999 Jan 13;281(2):169–71. PMID: 9917121.9917121
69 Seibert AF, Haynes J Jr., Middleton R, Tuberculous pleural effusion. Twenty-year experience. Chest. 1991 Apr;99(4):883–6. PMID: 1901261.1901261
70 Katsenos S, Nikolopoulou M, Konstantinidis AK, Interferon-gamma release assay clarifies the effect of bacille Calmette-Guerin vaccination in Greek army recruits. Int J Tuberc Lung Dis. 2010 May;14(5):545–50. PMID: 20392346.20392346
71 Park SY, Jeon K, Um SW, Clinical utility of the QuantiFERON-TB Gold In-Tube test for the diagnosis of active pulmonary tuberculosis. Scand J Infect Dis. 2009;41(11-12):818–22. doi: 10.3109/00365540903214298. PMID: 19922063.19922063
72 Bienek DR, Chang CK. Evaluation of an interferon-gamma release assay, T-SPOT.TB, in a population with a low prevalence of tuberculosis. Int J Tuberc Lung Dis. 2009 Nov;13(11):1416–21. PMID: 19861016.19861016
73 Soysal A, Torun T, Efe S, Evaluation of cut-off values of interferon-gamma-based assays in the diagnosis of M. tuberculosis infection. Int J Tuberc Lung Dis. 2008 Jan;12(1):50–6. PMID: 18173877.18173877
74 Dilektasli AG, Erdem E, Durukan E, Is the T-cell-based interferon-gamma releasing assay feasible for diagnosis of latent tuberculosis infection in an intermediate tuberculosis-burden country? Jpn J Infect Dis. 2010 Nov;63(6):433–6. PMID: 21099095.21099095
75 Ak O, Dabak G, Ozer S, The evaluation of the QuantiFERON-TB Gold test in pulmonary and extrapulmonary tuberculosis. Jpn J Infect Dis. 2009 Mar;62(2):149–51. PMID: 19305058.19305058
76 Wlodarczyk M, Rudnicka W, Janiszewska-Drobinska B, Interferon-gamma assay in combination with tuberculin skin test are insufficient for the diagnosis of culture-negative pulmonary tuberculosis. PLoS One. 2014;9(9):e107208. doi: 10.1371/journal.pone.0107208. PMID: 25221998.25221998
77 Hoff ST, Peter JG, Theron G, Sensitivity of C-Tb: a novel RD-1-specific skin test for the diagnosis of tuberculosis infection. Eur Respir J. 2016 Mar;47(3):919–28. doi: 10.1183/13993003.01464-2015. PMID: 26677940.26677940
78 Altet N, Latorre I, Jiménez-Fuentes M, Assessment of the influence of direct tobacco smoke on infection and active TB management. PLoS One. 2017;12(8):e0182998. doi: 10.1371/journal.pone.0182998. PMID: 28837570.28837570
79 Aggerbeck H, Ruhwald M, Hoff ST, Interaction between C-Tb and PPD given concomitantly in a split-body randomised controlled trial. Int J Tuberc Lung Dis. 2019 Jan 1;23(1):38–44. doi: 10.5588/ijtld.18.0137. PMID: 30572979.30572979
80 Choi JC, Jarlsberg LG, Grinsdale JA, Reduced sensitivity of the QuantiFERON(^®^) test in diabetic patients with smear-negative tuberculosis. Int J Tuberc Lung Dis. 2015 May;19(5):582–8. doi: 10.5588/ijtld.14.0553. PMID: 25868028.25868028
81 Zhu M, Zhu Z, Yang J, Performance evaluation of IGRA-ELISA and T-SPOT.TB for diagnosing tuberculosis infection. Clin Lab. 2019 Aug 1;65(8)doi: 10.7754/Clin.Lab.2019.181109. PMID: 31414740.31414740
82 Yu L, Mo P, Wei Z, Development and evaluation of a new interferon-gamma release assay for the diagnosis of tuberculosis infection in HIV-infected individuals in China. Infect Dis (Lond). 2015 Apr;47(4):237–43. doi: 10.3109/00365548.2014.988749. PMID: 25712792.25712792
83 Park IN, Shim TS. Qualitative and quantitative results of interferon-γ release assays for monitoring the response to anti-tuberculosis treatment. Korean J Intern Med. 2017 Mar;32(2):302–8. doi: 10.3904/kjim.2016.199. PMID: 27951621.27951621
84 Peña D, Rovetta AI, Hernández Del Pino RE, A Mycobacterium tuberculosis dormancy antigen differentiates latently infected bacillus calmette-guérin-vaccinated individuals. EBioMedicine. 2015 Aug;2(8):884–90. doi: 10.1016/j.ebiom.2015.05.026. PMID: 26425695.26425695
85 Lai CC, Tan CK, Lin SH, Diagnostic performance of whole-blood interferon-gamma assay and enzyme-linked immunospot assay for active tuberculosis. Diagn Microbiol Infect Dis. 2011 Oct;71(2):139–43. doi: 10.1016/j.diagmicrobio.2011.05.013. PMID: 21840675.21840675
86 Losi M, Bossink A, Codecasa L, Use of a T-cell interferon-gamma release assay for the diagnosis of tuberculous pleurisy. Eur Respir J. 2007 Dec;30(6):1173–9. doi: 10.1183/09031936.00067307. PMID: 17715165.17715165
87 Goletti D, Carrara S, Vincenti D, Accuracy of an immune diagnostic assay based on RD1 selected epitopes for active tuberculosis in a clinical setting: a pilot study. Clin Microbiol Infect. 2006 Jun;12(6):544–50. doi: 10.1111/j.1469-0691.2006.01391.x. PMID: 16700703.16700703
88 Janssens JP, Roux-Lombard P, Perneger T, Quantitative scoring of an interferon-gamma assay for differentiating active from latent tuberculosis. Eur Respir J. 2007 Oct;30(4):722–8. doi: 10.1183/09031936.00028507. PMID: 17537773.17537773
89 Chee CB, Gan SH, Khinmar KW, Comparison of sensitivities of two commercial gamma interferon release assays for pulmonary tuberculosis. J Clin Microbiol. 2008 Jun;46(6):1935–40. doi: 10.1128/jcm.02403-07. PMID: 18400912.18400912
90 Cho OH, Park KH, Kim SM, Diagnostic performance of T-SPOT.TB for extrapulmonary tuberculosis according to the site of infection. J Infect. 2011 Nov;63(5):362–9. doi: 10.1016/j.jinf.2011.06.010. PMID: 21781986.21781986
91 Boyd AE, Ashcroft A, Lipman M, Limited added value of T-SPOT. TB blood test in diagnosing active TB: a prospective bayesian analysis. J Infect. 2011 Jun;62(6):456–61. doi: 10.1016/j.jinf.2011.04.003. PMID: 21570124.21570124
92 Lai CC, Tan CK, Lin SH, Diagnostic value of an enzyme-linked immunospot assay for interferon-gamma in cutaneous tuberculosis. Diagn Microbiol Infect Dis. 2011 May;70(1):60–4. doi: 10.1016/j.diagmicrobio.2010.11.012. PMID: 21513844.21513844
93 Ruhwald M, Dominguez J, Latorre I, A multicentre evaluation of the accuracy and performance of IP-10 for the diagnosis of infection with M. tuberculosis. Tuberculosis (Edinb). 2011 May;91(3):260–7. doi: 10.1016/j.tube.2011.01.001. PMID: 21459676.21459676
94 Walsh MC, Camerlin AJ, Miles R, The sensitivity of interferon-gamma release assays is not compromised in tuberculosis patients with diabetes. Int J Tuberc Lung Dis. 2011 Feb;15(2):179–84, i-iii. PMID: 21219678.21219678
95 Tan CK, Lai CC, Chen HW, Enzyme-linked immunospot assay for interferon-gamma to support the diagnosis of tuberculosis in diabetic patients. Scand J Infect Dis. 2010 Oct;42(10):752–6. doi: 10.3109/00365548.2010.490237. PMID: 20513167.20513167
96 Higuchi K, Kawabe Y, Mitarai S, Comparison of performance in two diagnostic methods for tuberculosis infection. Med Microbiol Immunol. 2009 Feb;198(1):33–7. doi: 10.1007/s00430-008-0102-5. PMID: 19034505.19034505
97 Kobashi Y, Mouri K, Yagi S, Clinical evaluation for diagnosing active TB disease and transitional change of two commercial blood tests. Scand J Infect Dis. 2008;40(8):629–34. doi: 10.1080/00365540801932454. PMID: 18642159.18642159
98 Kobashi Y, Abe M, Mouri K, Usefulness of tuberculin skin test and three interferon-gamma release assays for the differential diagnosis of pulmonary tuberculosis. Intern Med. 2012;51(10):1199–205. PMID: 22687790.22687790
99 Kang WL, Wang GR, Wu MY, Interferon-gamma release assay is not appropriate for the diagnosis of active tuberculosis in high-burden tuberculosis settings: a retrospective multicenter investigation. Chin Med J (Engl). 2018 Feb 5;131(3):268–75. doi: 10.4103/0366-6999.223860. PMID: 29363640.29363640
100 Du F, Xie L, Zhang Y, Prospective comparison of QFT-GIT and T-SPOT.TB assays for diagnosis of active tuberculosis. Sci Rep. 2018 Apr 12;8(1):5882. doi: 10.1038/s41598-018-24285-3. PMID: 29651163.29651163
101 Di L, Li Y. The risk factor of false-negative and false-positive for T-SPOT.TB in active tuberculosis. J Clin Lab Anal. 2018 Feb;32(2)doi: 10.1002/jcla.22273. PMID: 28594104.28594104
102 Bae W, Park KU, Song EY, Comparison of the sensitivity of QuantiFERON-TB gold in-tube and T-SPOT.TB according to patient age. PLoS One. 2016;11(6):e0156917. doi: 10.1371/journal.pone.0156917. PMID: 27258377.27258377
103 Takwoingi Y, Whitworth H, Rees-Roberts M, Interferon gamma release assays for Diagnostic Evaluation of Active tuberculosis (IDEA): test accuracy study and economic evaluation. Health Technol Assess. 2019 May;23(23):1–152. doi: 10.3310/hta23230. PMID: 31138395.31138395
104 Xuan WX, Lu TT, Wang Z, Diagnostic significance of Mycobacterium tuberculosis t-cell assays for active tuberculosis. Chin Med J (Engl). 2017 Apr 5;130(7):811–6. doi: 10.4103/0366-6999.202738. PMID: 28345545.28345545
105 Takeda K, Nagai H, Suzukawa M, Comparison of QuantiFERON-TB Gold Plus, QuantiFERON-TB Gold In-Tube, and T-SPOT.TB among patients with tuberculosis. J Infect Chemother. 2020 Nov;26(11):1205–12. doi: 10.1016/j.jiac.2020.06.019. PMID: 32698989.32698989
106 Takasaki J, Manabe T, Morino E, Sensitivity and specificity of QuantiFERON-TB Gold Plus compared with QuantiFERON-TB Gold In-Tube and T-SPOT.TB on active tuberculosis in Japan. J Infect Chemother. 2018 Mar;24(3):188–92. doi: 10.1016/j.jiac.2017.10.009. PMID: 29108749.29108749
107 Zhang L, Shi X, Zhang Y, Analysis of factors influencing diagnostic accuracy of T-SPOT.TB for active tuberculosis in clinical practice. Sci Rep. 2017 Aug 10;7(1):7764. doi: 10.1038/s41598-017-07785-6. PMID: 28798488.28798488
108 Wang S, Wu J, Chen J, Evaluation of Mycobacterium tuberculosis-specific antibody responses for the discrimination of active and latent tuberculosis infection. Int J Infect Dis. 2018 May;70:1–9. doi: 10.1016/j.ijid.2018.01.007. PMID: 29410147.29410147
109 Pan L, Jia H, Liu F, Risk factors for false-negative T-SPOT.TB assay results in patients with pulmonary and extra-pulmonary TB. J Infect. 2015 Apr;70(4):367–80. doi: 10.1016/j.jinf.2014.12.018. PMID: 25597825.25597825
110 Sun Q, Wei W, Sha W. Potential role for mycobacterium tuberculosis specific il-2 and ifn-γ responses in discriminating between latent infection and active disease after long-term stimulation. PLoS One. 2016;11(12):e0166501. doi: 10.1371/journal.pone.0166501. PMID: 28033330.28033330
111 Qiu Y, Wang Y, Lin N, Multicenter clinical evaluation of three commercial reagent kits based on the interferon-gamma release assay for the rapid diagnosis of tuberculosis in China. Int J Infect Dis. 2015 Nov;40:108–12. doi: 10.1016/j.ijid.2015.09.004. PMID: 26358858.26358858
112 Kim JY, Park JH, Kim MC, Combined IFN-γ and TNF-α release assay for differentiating active tuberculosis from latent tuberculosis infection. J Infect. 2018 Oct;77(4):314–20. doi: 10.1016/j.jinf.2018.04.011. PMID: 29746954.29746954
113 Lian G, Du F, Wu H, Factors contributing to false-negative enzyme-linked immunospot assay for interferon-gamma results in active tuberculosis. Clin Lab. 2017 Apr 1;63(4):773–9. doi: 10.7754/Clin.Lab.2016.161007. PMID: 28397473.28397473
114 Whitworth HS, Badhan A, Boakye AA, Clinical utility of existing and second-generation interferon-γ release assays for diagnostic evaluation of tuberculosis: an observational cohort study. Lancet Infect Dis. 2019 Feb;19(2):193–202. doi: 10.1016/s1473-3099(18)30613-3. PMID: 30655049.30655049
115 Fukushima K, Kubo T, Akagi K, Clinical evaluation of QuantiFERON®-TB Gold Plus directly compared with QuantiFERON^®^-TB Gold In-Tube and T-Spot^®^.TB for active pulmonary tuberculosis in the elderly. J Infect Chemother. 2021 Dec;27(12):1716–22. doi: 10.1016/j.jiac.2021.08.016. PMID: 34412981.34412981
116 Shangguan Y, Fang H, Wang S, Risk factors for negative T-SPOT.TB assay results in patients with confirmed active tuberculosis: a retrospective study. J Infect Dev Ctries. 2020 Nov 30;14(11):1288–95. doi: 10.3855/jidc.12063. PMID: 33296342.33296342
117 Horne DJ, Jones BE, Kamada A, Multicenter study of QuantiFERON(^®^)-TB Gold Plus in patients with active tuberculosis. Int J Tuberc Lung Dis. 2018 Jun 1;22(6):617–21. doi: 10.5588/ijtld.17.0721. PMID: 29862944.29862944
118 Hoffmann H, Avsar K, Göres R, Equal sensitivity of the new generation QuantiFERON-TB Gold plus in direct comparison with the previous test version QuantiFERON-TB Gold IT. Clin Microbiol Infect. 2016 Aug;22(8):701–3. doi: 10.1016/j.cmi.2016.05.006. PMID: 27184875.27184875
119 Akashi S, Suzukawa M, Takeda K, IL-1RA in the supernatant of QuantiFERON-TB Gold In-Tube and QuantiFERON-TB Gold Plus is useful for discriminating active tuberculosis from latent infection. J Infect Chemother. 2020doi: 10.1016/j.jiac.2020.11.023. PMID: CN-02214472.
120 Lee MR, Chang CH, Chang LY, CD8 response measured by QuantiFERON-TB Gold Plus and tuberculosis disease status. J Infect. 2019 Apr;78(4):299–304. doi: 10.1016/j.jinf.2019.01.007. PMID: 30707912.30707912
121 Yi L, Sasaki Y, Nagai H, Evaluation of QuantiFERON-TB gold plus for detection of Mycobacterium tuberculosis infection in Japan. Sci Rep. 2016 Jul 29;6:30617. doi: 10.1038/srep30617. PMID: 27470684.27470684
122 Siegel SAR, Cavanaugh M, Ku JH, Specificity of QuantiFERON-TB Plus, a new-generation interferon gamma release assay. J Clin Microbiol. 2018 Dec;56(12)doi: 10.1128/jcm.00629-18. PMID: 30232132.30232132
123 Manngo PM, Gutschmidt A, Snyders CI, Prospective evaluation of host biomarkers other than interferon gamma in QuantiFERON Plus supernatants as candidates for the diagnosis of tuberculosis in symptomatic individuals. J Infect. 2019 Sep;79(3):228–35. doi: 10.1016/j.jinf.2019.07.007. PMID: 31319143.31319143
124 Lee JK, Lee HW, Heo EY, Comparison of QuantiFERON-TB Gold Plus and QuantiFERON-TB Gold In-Tube tests for patients with active and latent tuberculosis: A prospective cohort study. J Infect Chemother. 2021 Dec;27(12):1694–9. doi: 10.1016/j.jiac.2021.08.003. PMID: 34412980.34412980
125 Jung J, Jhun BW, Jeong M, Is the new interferon-gamma releasing assay beneficial for the diagnosis of latent and active mycobacterium tuberculosis infections in tertiary care setting? J Clin Med. 2021 Mar 29;10(7)doi: 10.3390/jcm10071376. PMID: 33805448.33805448
126 Qian F, Wang W, Qiu Z, Evaluation of a new tuberculosis-related interferon gamma release assay for tuberculosis infection diagnosis in Huzhou, eastern China. Indian J Pathol Microbiol. 2013 Apr-Jun;56(2):125–8. doi: 10.4103/0377-4929.118694. PMID: 24056648.24056648
127 Feng JY, Huang SF, Lee MC, Characteristics of IFN-gamma responses in IGRA among pulmonary TB suspects in a TB-endemic area. Diagn Microbiol Infect Dis. 2013 Sep;77(1):46–52. doi: 10.1016/j.diagmicrobio.2013.05.020. PMID: 23867329.23867329
128 Min JW, Lee HY, Lee JS, Effect of prolonged incubation time on results of the QuantiFERON TB Gold In-Tube assay for diagnosis of latent tuberculosis infection. Clin Vaccine Immunol. 2013 Sep;20(9):1377–80. doi: 10.1128/cvi.00290-13. PMID: 23825190.23825190
129 Jeon YL, Nam YS, You E, Factors influencing discordant results of the QuantiFERON-TB Gold In-tube test in patients with active TB. J Infect. 2013 Oct;67(4):288–93. doi: 10.1016/j.jinf.2013.06.005. PMID: 23796867.23796867
130 Wang S, Chen J, Zhang Y, Mycobacterium tuberculosis region of difference (RD) 2 antigen Rv1985c and RD11 antigen Rv3425 have the promising potential to distinguish patients with active tuberculosis from M. bovis BCG-vaccinated individuals. Clin Vaccine Immunol. 2013 Jan;20(1):69–76. doi: 10.1128/cvi.00481-12. PMID: 23136116.23136116
131 Kim S, Kim YK, Lee H, Interferon gamma mRNA quantitative real-time polymerase chain reaction for the diagnosis of latent tuberculosis: a novel interferon gamma release assay. Diagn Microbiol Infect Dis. 2013 Jan;75(1):68–72. doi: 10.1016/j.diagmicrobio.2012.09.015. PMID: 23102550.23102550
132 Lee J, Lee SY, Won DI, Comparison of whole-blood interferon-gamma assay and flow cytometry for the detection of tuberculosis infection. J Infect. 2013 Apr;66(4):338–45. doi: 10.1016/j.jinf.2012.08.020. PMID: 23010554.23010554
133 Pai M, Joshi R, Bandyopadhyay M, Sensitivity of a whole-blood interferon-gamma assay among patients with pulmonary tuberculosis and variations in T-cell responses during anti-tuberculosis treatment. Infection. 2007 Apr;35(2):98–103. doi: 10.1007/s15010-007-6114-z. PMID: 17401714.17401714
134 Harada N, Higuchi K, Yoshiyama T, Comparison of the sensitivity and specificity of two whole blood interferon-gamma assays for M. tuberculosis infection. J Infect. 2008 May;56(5):348–53. doi: 10.1016/j.jinf.2008.02.011. PMID: 18395264.18395264
135 Legesse M, Ameni G, Mamo G, Performance of QuantiFERON-TB Gold In-Tube (QFTGIT) for the diagnosis of Mycobacterium tuberculosis (Mtb) infection in Afar Pastoralists, Ethiopia. BMC Infect Dis. 2010;10:354. doi: 10.1186/1471-2334-10-354. PMID: 21162756.21162756
136 Adetifa IM, Lugos MD, Hammond A, Comparison of two interferon gamma release assays in the diagnosis of Mycobacterium tuberculosis infection and disease in The Gambia. BMC Infect Dis. 2007;7:122. doi: 10.1186/1471-2334-7-122. PMID: 17961228.17961228
137 Taki-Eddin L, Monem F. Utility of an interferon-gamma release assay as a potential diagnostic aid for active pulmonary tuberculosis. J Infect Dev Ctries. 2012 Jan;6(1):67–72. PMID: 22240431.22240431
138 Erdem H, Ozturk-Engin D, Elaldi N, The microbiological diagnosis of tuberculous meningitis: results of Haydarpasa-1 study. Clin Microbiol Infect. 2014 Oct;20(10):O600–8. doi: 10.1111/1469-0691.12478. PMID: 24849547.24849547
139 Kim CH, Lim JK, Yoo SS, Diagnostic performance of the QuantiFERON-TB Gold In-Tube assay and factors associated with nonpositive results in patients with miliary tuberculosis. Clin Infect Dis. 2014 Apr;58(7):986–9. doi: 10.1093/cid/ciu045. PMID: 24457341.24457341
140 Lempp JM, Margan JZ, Hankinson AL, Assessment of the QuantiFERON-TB Gold In-Tube test for the detection of Mycobacterium tuberculosis infection in US Navy recruits. Atlanta, GA: Centers for Disease Control and Prevention; 2015.
141 Niguse S, Desta K, Gebremichael G, QuantiFERON-TB Gold In-Tube test for the diagnosis of active and latent tuberculosis in selected health facilities of Addis Ababa, Ethiopia. BMC Res Notes. 2018 May 11;11(1):293. doi: 10.1186/s13104-018-3410-x. PMID: 29751780.29751780
142 Lombardi G, Pellegrino MT, Denicolò A, QuantiFERON-TB performs better in children, including infants, than in adults with active tuberculosis: a multicenter study. J Clin Microbiol. 2019 Oct;57(10)doi: 10.1128/jcm.01048-19. PMID: 31391228.31391228
143 Jeon Y, Kim MJ, Lee WI, Diagnostic utility of new equation for active tuberculosis based on parameters of interferon-γ release assay. Lab Med. 2017 Aug 1;48(3):214–9. doi: 10.1093/labmed/lmx022. PMID: 28398535.28398535
144 Kiazyk S, Larcombe L, Lopez C, IFN-γ promoter polymorphisms do not affect QuantiFERON^®^ TB Gold In-Tube test results in a Canadian population. Int J Tuberc Lung Dis. 2016 Dec 1;20(12):1647–52. doi: 10.5588/ijtld.16.0223. PMID: 28000585.28000585
145 Waruk JL, Machuki Z, Mesa C, Cytokine and chemokine expression profiles in response to Mycobacterium tuberculosis stimulation are altered in HIV-infected compared to HIV-uninfected subjects with active tuberculosis. Tuberculosis (Edinb). 2015 Sep;95(5):555–61. doi: 10.1016/j.tube.2015.05.001. PMID: 26073895.26073895
146 Kwon YS, Kim YH, Jeon K, Factors that predict negative results of QuantiFERON-TB Gold In-Tube test in patients with culture-confirmed tuberculosis: a multicenter retrospective cohort study. PLoS One. 2015;10(6):e0129792. doi: 10.1371/journal.pone.0129792. PMID: 26070207.26070207
147 Pathakumari B, Prabhavathi M, Raja A. Evaluation of cytokine and chemokine response elicited by Rv2204c and Rv0753c to detect latent tuberculosis infection. Cytokine. 2015 Dec;76(2):496–504. doi: 10.1016/j.cyto.2015.07.028. PMID: 26298037.26298037
148 Huang CT, Lee MR, Ruan SY, Prognostic value of the mitogen response in the interferon-γ release assay in patients with culture-confirmed tuberculosis. Respir Med. 2019 Oct-Nov;158:49–54. doi: 10.1016/j.rmed.2019.10.004. PMID: 31605921.31605921
149 Whitworth WC, Hamilton LR, Goodwin DJ, Within-subject interlaboratory variability of QuantiFERON-TB Gold In-Tube tests. PLoS One. 2012;7(9):e43790. doi: 10.1371/journal.pone.0043790. PMID: 22970142.22970142
150 Whitworth WC, Goodwin DJ, Racster L, Variability of the QuantiFERON(R)-TB gold in-tube test using automated and manual methods. PLoS One. 2014;9(1):e86721. doi: 10.1371/journal.pone.0086721. PMID: 24466211.24466211
151 Dorman SE, Belknap R, Graviss EA, Interferon-gamma release assays and tuberculin skin testing for diagnosis of latent tuberculosis infection in healthcare workers in the United States. Am J Respir Crit Care Med. 2014 Jan 1;189(1):77–87. doi: 10.1164/rccm.201302-0365OC. PMID: 24299555.24299555
152 Abbott BJ. EARNEST Rifabutin Pharmacokinetics (PK) Substudy. ClinicalTrials.gov. Bethesda, MD: National Library of Medicine; 2000-
153 Naidoo A, Naidoo K, McIlleron H, A review of moxifloxacin for the treatment of drug-susceptible tuberculosis. J Clin Pharmacol. 2017 Nov;57(11):1369–86. doi: 10.1002/jcph.968. PMID: 28741299.28741299
154 Moura LC, Ximenes RA, Lacerda HR, Predictive factors for repetition of the tuberculin test after a nonreactive test in patients with HIV/AIDS. Rev Panam Salud Publica. 2012 Feb;31(2):121–8. PMID: 22522874.22522874
155 Franken WP, Thijsen S, Wolterbeek R, Variation in T-SPOT.TB spot interpretation between independent observers from different laboratories. Clin Vaccine Immunol. 2009 Oct;16(10):1439–42. doi: 10.1128/cvi.00456-08. PMID: 19710293.19710293
156 O'Shea MK, Fletcher TE, Beeching NJ, Tuberculin skin testing and treatment modulates interferon-gamma release assay results for latent tuberculosis in migrants. PLoS One. 2014;9(5):e97366. doi: 10.1371/journal.pone.0097366. PMID: 24816576.24816576
157 Cummings KJ, Smith TS, Shogren ES, Prospective comparison of tuberculin skin test and QuantiFERON-TB Gold In-Tube assay for the detection of latent tuberculosis infection among healthcare workers in a low-incidence setting. Infect Control Hosp Epidemiol. 2009 Nov;30(11):1123–6. doi: 10.1086/644754. PMID: 19803719.19803719
158 Thompson MJ. Efficacy of various durations of isoniazid preventive therapy for tuberculosis: five years of follow-up in the IUAT trial. International Union Against Tuberculosis Committee on Prophylaxis. Bull World Health Organ. 1982;60(4):555–64. PMID: 6754120.6754120
159 Menzies D, Long R, Trajman A, Adverse events with 4 months of rifampin therapy or 9 months of isoniazid therapy for latent tuberculosis infection: a randomized trial. Ann Intern Med. 2008 Nov 18;149(10):689–97. PMID: 19017587.19017587
160 Menzies D, Adjobimey M, Ruslami R, Four months of rifampin or nine months of isoniazid for latent tuberculosis in adults. N Engl J Med. 2018 Aug 2;379(5):440–53. doi: 10.1056/NEJMoa1714283. PMID: 30067931.30067931
161 Sterling TR, Villarino ME, Borisov A, Three months of rifapentine and isoniazid for latent tuberculosis infection. N Engl J Med. 2011 Dec 8;365(23):2155–66. doi: 10.1056/NEJMoa1104875. PMID: 22150035.22150035
162 Sun HY, Huang YW, Huang WC, Twelve-dose weekly rifapentine plus isoniazid for latent tuberculosis infection: a multicentre randomised controlled trial in Taiwan. Tuberculosis (Edinb). 2018 Jul;111:121–6. doi: 10.1016/j.tube.2018.05.013. PMID: 30029896.30029896
163 Zenner D, Beer N, Harris RJ, Treatment of latent tuberculosis infection: an updated network meta-analysis. Ann Intern Med. 2017 Aug 15;167(4):248–55. doi: 10.7326/m17-0609. PMID: 28761946.28761946
164 Bush OB Jr., Sugimoto M, Fujii Y, Isoniazid prophylaxis in contacts of persons with known tuberculosis. Second report. Am Rev Respir Dis. 1965 Nov;92(5):732–40. PMID: 5321147.5321147
165 Falk A, Fuchs GF. Prophylaxis with isoniazid in inactive tuberculosis. A Veterans Administration Cooperative Study XII. Chest. 1978 Jan;73(1):44–8. PMID: 340155.340155
166 Ferebee SH, Mount FW, Murray FJ, A controlled trial of isoniazid prophylaxis in mental institutions. Am Rev Respir Dis. 1963 Aug;88:161–75. PMID: 14045220.14045220
167 Veening GJ. Long term isoniazid prophylaxis. Controlled trial on INH prophylaxis after recent tuberculin conversion in young adults. Bull Int Union Tuberc. 1968 Dec;41:169–71. PMID: 4885378.
168 Mount FW, Ferebee SH. The effect of isoniazid prophylaxis on tuberculosis morbidity among household contacts of previously known cases of tuberculosis. Am Rev Respir Dis. 1962 Jun;85:821–7. PMID: 14476668.14476668
169 Ferebee SH, Mount FW. Tuberculosis morbidity in a controlled trial of the prophylactic use of isoniazid among household contacts. Am Rev Respir Dis. 1962 Apr;85:490–510. PMID: 13892318.13892318
170 Egsmose T, Ang'awa JO, Poti SJ. The use of isoniazid among household contacts of open cases of pulmonary tuberculosis. Bull World Health Organ. 1965;33(3):419–33. PMID: 5321762.5321762
171 Girling DJ, Chan SL, Hong Kong Chest Service/Tuberculosis Research Centre, Madras/British Medical Research Council. A double-blind placebo-controlled clinical trial of three antituberculosis chemoprophylaxis regimens in patients with silicosis in Hong Kong. Am Rev Respir Dis. 1992;145:36–41.1731596
172 John GT, Thomas PP, Thomas M, A double-blind randomized controlled trial of primary isoniazid prophylaxis in dialysis and transplant patients. Transplantation. 1994 Jun 15;57(11):1683–4. PMID: 8009608.8009608
173 Horwitz O, Payne PG, Wilbek E. Epidemiological basis of tuberculosis eradication. 4. The isoniazid trial in Greenland. Bull World Health Organ. 1966;35(4):509–26. PMID: 5335457.5335457
174 Comstock GW, Ferebee SH, Hammes LM. A controlled trial of community-wide isoniazid prophylaxis in Alaska. Am Rev Respir Dis. 1967 Jun;95(6):935–43. PMID: 6026165.6026165
175 Campbell JR, Trajman A, Cook VJ, Adverse events in adults with latent tuberculosis infection receiving daily rifampicin or isoniazid: post-hoc safety analysis of two randomised controlled trials. Lancet Infect Dis. 2020 Mar;20(3):318–29. doi: 10.1016/s1473-3099(19)30575-4. PMID: 31866327.31866327
176 Menzies D, Dion MJ, Rabinovitch B, Treatment completion and costs of a randomized trial of rifampin for 4 months versus isoniazid for 9 months. Am J Respir Crit Care Med. 2004 Aug 15;170(4):445–9. doi: 10.1164/rccm.200404-478OC. PMID: 15172892.15172892
177 White MC, Tulsky JP, Lee JR, Isoniazid vs. rifampin for latent tuberculosis infection in jail inmates: toxicity and adherence. J Correct Health Care. 2012 Apr;18(2):131–42. doi: 10.1177/1078345811435973. PMID: 22419641.22419641
178 Sterling TR, Moro RN, Borisov AS, Flu-like and other systemic drug reactions among persons receiving weekly rifapentine plus isoniazid or daily isoniazid for treatment of latent tuberculosis infection in the PREVENT Tuberculosis Study. Clin Infect Dis. 2015 Aug 15;61(4):527–35. doi: 10.1093/cid/civ323. PMID: 25904367.25904367
179 Surey J, Stagg HR, Yates TA, An open label, randomised controlled trial of rifapentine versus rifampicin based short course regimens for the treatment of latent tuberculosis in England: the HALT LTBI pilot study. BMC Infect Dis. 2021 Jan 21;21(1):90. doi: 10.1186/s12879-021-05766-9. PMID: 33478428.33478428
180 Gao L, Zhang H, Xin H, Short-course regimens of rifapentine plus isoniazid to treat latent tuberculosis infection in older Chinese patients: a randomised controlled study. Eur Respir J. 2018 Dec;52(6)doi: 10.1183/13993003.01470-2018. PMID: 30361241.30361241
181 Zenner D, Beer N, Harris RJ, Treatment of latent tuberculosis infection. Ann Intern Med. 2017;167(4):248–55. doi: 10.7326/M17-0609.28761946
182 Krebs A. The IUAT trial on isoniazid preventive treatment in persons with fibrotic lung lesions. Bull Int Union Tuberc. 1976;51(1):193–201. PMID: 801115.801115
183 Falk A, Fuchs G. Isoniazid (INH) prophylaxis in inactive pulmonary tuberculosis: report of a Veterans Administration Cooperative Study. Bull Int Union Tuberc. 1976;51(1):219–23. PMID: 1030286.1030286
184 Bailey WC, Weill H, DeRouen TA, The effect of isoniazid on transaminase levels. Ann Intern Med. 1974 Aug;81(2):200–2. PMID: 4843577.4843577
185 Byrd RB, Horn BR, Griggs GA, Isoniazid chemoprophylaxis. Association with detection and incidence of liver toxicity. Arch Intern Med. 1977 Sep;137(9):1130–3. PMID: 332099.332099
186 Kahwati LC, Feltner C, Halpern M, Primary care screening and treatment for latent tuberculosis infection in adults: evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2016 Sep 6;316(9):970–83. doi: 10.1001/jama.2016.10357. PMID: 27599332.27599332
187 Menzies D, Pai M, Comstock G. Meta-analysis: new tests for the diagnosis of latent tuberculosis infection: areas of uncertainty and recommendations for research. Ann Intern Med. 2007 Mar 6;146(5):340–54. PMID: 17339619.17339619
188 Pai M, Zwerling A, Menzies D. Systematic review: T-cell-based assays for the diagnosis of latent tuberculosis infection: an update. Ann Intern Med. 2008 Aug 5;149(3):177–84. PMID: 18593687.18593687
189 Diel R, Loddenkemper R, Nienhaus A. Evidence-based comparison of commercial interferon-gamma release assays for detecting active TB: a metaanalysis. Chest. 2010 Apr;137(4):952–68. doi: 10.1378/chest.09-2350. PMID: 20022968.20022968
190 Diel R, Goletti D, Ferrara G, Interferon-gamma release assays for the diagnosis of latent Mycobacterium tuberculosis infection: a systematic review and meta-analysis. Eur Respir J. 2011 Jan;37(1):88–99. doi: 10.1183/09031936.00115110. PMID: 21030451.21030451
191 Linas BP, Wong AY, Freedberg KA, Priorities for screening and treatment of latent tuberculosis infection in the United States. Am J Respir Crit Care Med. 2011 Sep 1;184(5):590–601. doi: 10.1164/rccm.201101-0181OC. PMID: 21562129.21562129
192 Tasillo A, Salomon JA, Trikalinos TA, Cost-effectiveness of testing and treatment for latent tuberculosis infection in residents born outside the United States with and without medical comorbidities in a simulation model. JAMA Intern Med. 2017 Dec 1;177(12):1755–64. doi: 10.1001/jamainternmed.2017.3941. PMID: 29049814.29049814
193 Jo Y, Shrestha S, Gomes I, Model-based cost-effectiveness of state-level latent tuberculosis interventions in California, Florida, New York and Texas. Clin Infect Dis. 2020 Jun 25doi: 10.1093/cid/ciaa857. PMID: 32584968.32584968
194 Kalk E, Heekes A, Mehta U, Safety and effectiveness of isoniazid preventive therapy in pregnant women living with human immunodeficiency virus on antiretroviral therapy: an observational study using linked population data. Clin Infect Dis. 2020;71(8):e351–e8. doi: 10.1093/cid/ciz1224.31900473
195 Moro RN, Scott NA, Vernon A, Exposure to latent tuberculosis treatment during pregnancy. The PREVENT TB and the iAdhere Trials. Ann Am Thorac Soc. 2018 2018/05/01;15(5):570–80. doi: 10.1513/AnnalsATS.201704-326OC.29393655
196 A. A. P. Committee on Fetus Newborn, ACOG Committee on Obstetric Practice, Kilpatrick SJ, Guidelines for perinatal care. Elk Grove Village, IL: American Academy of Pediatrics; 2017.
197 Swindells S, Ramchandani R, Gupta A, One month of rifapentine plus isoniazid to prevent HIV-related tuberculosis. N Engl J Med. 2019 Mar 14;380(11):1001–11. doi: 10.1056/NEJMoa1806808. PMID: 30865794.30865794
198 Sosa LE, Njie GJ, Lobato MN, Tuberculosis screening, testing, and treatment of U.S. health care personnel: recommendations from the National Tuberculosis Controllers Association and CDC, 2019. Morbidity and Mortality Weekly Report (MMWR). 2019;68:439–43. doi: 10.15585/mmwr.mm6819a3 31099768
199 National Institute for Health and Care Excellence. Tuberculosis: recommendations (NICE guideline 33) 2019. https://www.nice.org.uk/guidance/ng33/chapter/Recommendations.
200 Peoples Métis,. Canadian Tuberculosis Standards. Public Health Agency of Canada,. 2014.
201 California Department of Public Health. TB risk assessment. https://www.cdph.ca.gov/Programs/CID/DCDC/Pages/TB-Risk-Assessment.aspx. Accessed 6 August 2022.
202 Michigan Department of Health and Human Services. Screening & testing for LTBI. Lansing, MI: Michigan Department of Health and Human Services; n.d. https://www.michigan.gov/mdhhs/0,5885,7-339-71550_5104_5281_46528_78973_79005-503330--,00.html. Accessed 22 October 2021.
203 Washington State Department of Health. TB provider toolkit. Washington State Department of Health; n.d. https://www.doh.wa.gov/YouandYourFamily/IllnessandDisease/Tuberculosis/TBProviderToolkit. Accessed 22 October 2021.
204 Ohio Department of Health. Resources and information for professionals. Ohio Department of Health; n.d. https://odh.ohio.gov/wps/portal/gov/odh/know-our-programs/tuberculosis/Education-and-Resources-for-Professionals. Accessed 22 October 2021.
205 Department of Health and Human Services Nevada Division of Public and Behavioral Health (DPBH). Welcome to the Nevada Division of Public and Behavioral Health (DPBH). Carson City, NV: Nevada DPBH; n.d. https://dpbh.nv.gov/. Accessed 22 October 2021.
206 Pennsylvania Department of Health. Tuberculosis health care providers. Harrisburg, PA: Pennsylvania Department of Health; n.d. https://www.health.pa.gov/topics/programs/Tuberculosis/Pages/Providers.aspx. Accessed 22 October 2021.
207 Wisconsin Department of Health Services. Tuberculosis (TB): forms. Madison, WI: Wisconsin Department of Health Services; n.d. https://www.dhs.wisconsin.gov/tb/forms.htm. Accessed 22 October 2021.
208 Delaware Department of Social Services. Delaware Adult Tuberculosis Risk Assessment and Symptom Evaluation. Delaware Department of Social Services; 2019. https://dhss.delaware.gov/dhss/dph/dpc/files/tbscreeningtool.pdf. Accessed 22 October 2021.
209 Haley CA, Cain KP, Yu C, Risk-based screening for latent tuberculosis infection. South Med J. 2008 Feb;101(2):142–9. doi: 10.1097/SMJ.0b013e3181611c9f. PMID: 18364613.18364613
210 Cain KP, Garman KN, Laserson KF, Moving toward tuberculosis elimination: implementation of statewide targeted tuberculin testing in Tennessee. Am J Respir Crit Care Med. 2012 Aug 1;186(3):273–9. doi: 10.1164/rccm.201111-2076OC. PMID: 22561962.22561962
211 Virginia Department of Health. Screening & testing. Richmond, VA: Virginia Department of Health; n.d. https://www.vdh.virginia.gov/tuberculosis/screening-testing/. Accessed 17 November 2021.
212 Virginia Department of Health. Virginia tuberculosis (TB) risk assessment. Richmond, VA: Virginia Department of Health; 2019. https://www.vdh.virginia.gov/content/uploads/sites/112/2019/02/VA-TB-Risk-Assessment-and-User-Guide-2019-1.pdf. Accessed 17 November 2021.
213 Schwartz NG PS, Pratt RH, Langer AJ. Tuberculosis--United States, 2019. MMWR Morb Mortal Wkly Rep. 2019;69:286–9. doi: 10.15585/mmwr.mm6911a3.
214 Almarzooqi F, Alkhemeiri A, Aljaberi A, Prospective cross-sectional study of tuberculosis screening in United Arab Emirates. Int J Infect Dis. 2018 May;70:81–5. doi: 10.1016/j.ijid.2018.03.001. PMID: 29526607.29526607
215 Centers for Disease Control and Prevention. Latent tuberculosis infection: a guide for primary health care providers. Developed in partnership with the New Jersey Medical School Global Tuberculosis Institute. Atlanta, GA: CDC, National Centers for H IV/AIDS, Viral Hepatitis, STD, and TB Prevention; 2013. http://www.cdc.gov/tb/publications/LTBI/default.htm
216 Balcells ME, Ruiz-Tagle C, Tiznado C, Diagnostic performance of GM-CSF and IL-2 in response to long-term specific-antigen cell stimulation in patients with active and latent tuberculosis infection. Tuberculosis (Edinb). 2018 Sep;112:110–9. doi: 10.1016/j.tube.2018.08.006. PMID: 30205963.30205963
217 Bua A, Molicotti P, Delogu G, QuantiFERON-TB Gold: a new method for latent tuberculosis infection. New Microbiol. 2007 Oct;30(4):477–80. PMID: 18080685.18080685
218 Chedid C, Kokhreidze E, Tukvadze N, Relevance of QuantiFERON-TB Gold Plus and heparin-binding hemagglutinin interferon-γ release assays for monitoring of pulmonary tuberculosis clearance: a multicentered study. Front Immunol. 2020;11:616450. doi: 10.3389/fimmu.2020.616450. PMID: 33603746.33603746
219 Chen Q, Guo X, Wang X, T-SPOT.TB in detection of active tuberculosis during pregnancy: a retrospective study in China. Med Sci Monit. 2016 Jan 6;22:57–60. doi: 10.12659/msm.896943. PMID: 26732770.26732770
220 Dewan PK, Grinsdale J, Kawamura LM. Low sensitivity of a whole-blood interferon-gamma release assay for detection of active tuberculosis. Clin Infect Dis. 2007 Jan 1;44(1):69–73. doi: 10.1086/509928. PMID: 17143818.17143818
221 Eum SY, Lee YJ, Kwak HK, Evaluation of the diagnostic utility of a whole-blood interferon-gamma assay for determining the risk of exposure to Mycobacterium tuberculosis in Bacille Calmette-Guerin (BCG)-vaccinated individuals. Diagn Microbiol Infect Dis. 2008 Jun;61(2):181–6. doi: 10.1016/j.diagmicrobio.2008.01.002. PMID: 18296002.18296002
222 Franken WP, Timmermans JF, Prins C, Comparison of Mantoux and QuantiFERON TB Gold tests for diagnosis of latent tuberculosis infection in Army personnel. Clin Vaccine Immunol. 2007 Apr;14(4):477–80. doi: 10.1128/cvi.00463-06. PMID: 17301213.17301213
223 Han J, Zeng F, Zhou Y. The value of T-SPOT.TB in early diagnosis of tracheobronchial tuberculosis. Sarcoidosis Vasc Diffuse Lung Dis. 2016 Jan 18;32(4):336–41. PMID: 26847101.26847101
224 He Y, Zhang W, Huang T, Evaluation of a diagnostic flow chart applying medical thoracoscopy, adenosine deaminase and T-SPOT.TB in diagnosis of tuberculous pleural effusion. Eur Rev Med Pharmacol Sci. 2015 Oct;19(19):3563–8. PMID: 26502844.26502844
225 Kalantri Y, Hemvani N, Chitnis DS. Evaluation of whole blood IFNgamma test using PPD and recombinant antigen challenge for diagnosis of pulmonary and extra-pulmonary tuberculosis. Indian J Exp Biol. 2009 Jun;47(6):463–8. PMID: 19634712.19634712
226 Kamiya H, Ikushima S, Kondo K, Diagnostic performance of interferon-gamma release assays in elderly populations in comparison with younger populations. J Infect Chemother. 2013 Apr;19(2):217–22. doi: 10.1007/s10156-012-0480-x. PMID: 23108426.23108426
227 Kang YA, Lee HW, Hwang SS, Usefulness of whole-blood interferon-gamma assay and interferon-gamma enzyme-linked immunospot assay in the diagnosis of active pulmonary tuberculosis. Chest. 2007 Sep;132(3):959–65. doi: 10.1378/chest.06-2805. PMID: 17505029.17505029
228 Kobashi Y, Mouri K, Yagi S, Usefulness of the QuantiFERON TB-2G test for the differential diagnosis of pulmonary tuberculosis. Intern Med. 2008;47(4):237–43. PMID: 18277023.18277023
229 Kobashi Y, Mouri K, Yagi S, Clinical utility of the QuantiFERON TB-2G test for elderly patients with active tuberculosis. Chest. 2008 May;133(5):1196–202. doi: 10.1378/chest.07-1995. PMID: 18263689.18263689
230 Kobashi Y, Shimizu H, Ohue Y, False negative results of QuantiFERON TB-2G test in patients with active tuberculosis. Jpn J Infect Dis. 2009 Jul;62(4):300–2. PMID: 19628910.19628910
231 Kobashi Y, Sugiu T, Shimizu H, Clinical evaluation of the T-SPOT.TB test for patients with indeterminate results on the QuantiFERON TB-2G test. Intern Med. 2009;48(3):137–42. PMID: 19182423.19182423
232 La Distia Nora R, Sitompul R, Bakker M, Tuberculosis and other causes of uveitis in Indonesia. Eye (Lond). 2018 Mar;32(3):546–54. doi: 10.1038/eye.2017.231. PMID: 29099497.29099497
233 Lee YJ, Lee J, Kim YY, Performance of whole-blood interferon-gamma release assay in patients admitted to the emergency department with pulmonary infiltrates. BMC Infect Dis. 2011;11:107. doi: 10.1186/1471-2334-11-107. PMID: 21513568.21513568
234 Li H, Yang L, Zheng CY, Use of bronchoalveolar lavage enzyme-linked immunospot for diagnosis of smear-negative pulmonary tuberculosis. Int J Tuberc Lung Dis. 2012 Dec;16(12):1668–73. doi: 10.5588/ijtld.12.0292. PMID: 23131267.23131267
235 Li K, Yang C, Jiang Z, Quantitative investigation of factors relevant to the T cell spot test for tuberculosis infection in active tuberculosis. BMC Infect Dis. 2019 Jul 29;19(1):673. doi: 10.1186/s12879-019-4310-y. PMID: 31357953.31357953
236 Liu Q, Gao Y, Ou Q, Differential expression of CD64 in patients with Mycobacterium tuberculosis infection: A potential biomarker for clinical diagnosis and prognosis. J Cell Mol Med. 2020 Dec;24(23):13961–72. doi: 10.1111/jcmm.16004. PMID: 33164320.33164320
237 Liu S, Wu M, A E, Factors associated with differential T cell responses to antigens ESAT-6 and CFP-10 in pulmonary tuberculosis patients. Medicine (Baltimore). 2021 Feb 26;100(8):e24615. doi: 10.1097/md.0000000000024615. PMID: 33663071.33663071
238 Lui G, Lee N, Cheung SW, Interferon gamma release assay for differentiating tuberculosis among pneumonia cases in acute healthcare setting. J Infect. 2011 Jun;62(6):440–7. doi: 10.1016/j.jinf.2011.04.011. PMID: 21575991.21575991
239 Memish ZA, Mah MW, Mahmood SA, Clinico-diagnostic experience with tuberculous lymphadenitis in Saudi Arabia. Clin Microbiol Infect. 2000 Mar;6(3):137–41. PMID: 11168089.11168089
240 Metcalfe JZ, Cattamanchi A, Vittinghoff E, Evaluation of quantitative IFN-gamma response for risk stratification of active tuberculosis suspects. Am J Respir Crit Care Med. 2010 Jan 1;181(1):87–93. doi: 10.1164/rccm.200906-0981OC. PMID: 19797760.19797760
241 Ozekinci T, Ozbek E, Celik Y. Comparison of tuberculin skin test and a specific T-cell-based test, T-SPOT.TB, for the diagnosis of latent tuberculosis infection. J Int Med Res. 2007 Sep-Oct;35(5):696–703. PMID: 17944056.17944056
242 Palazzo R, Spensieri F, Massari M, Use of whole-blood samples in in-house bulk and single-cell antigen-specific gamma interferon assays for surveillance of Mycobacterium tuberculosis infections. Clin Vaccine Immunol. 2008 Feb;15(2):327–37. doi: 10.1128/cvi.00342-07. PMID: 18032595.18032595
243 Pasticci MB, Papalini C, Murgia N, QuantiFERON-TB and tuberculin skin test in patients with active tuberculosis: the experience of a single medium-sized Italian University Hospital. Infez Med. 2021 Jun 1;29(2):229–35. PMID: 34061788.34061788
244 Piotrowski WJ, Adam B, Gwadera Ł, QuantiFERON-TB-GOLD In-Tube in patients with sarcoidosis. Adv Respir Med. 2018;86(5):234–9. doi: 10.5603/arm.2018.0037. PMID: 30378651.30378651
245 Ra SW, Lyu J, Choi CM, Distinguishing tuberculosis from Mycobacterium avium complex disease using an interferon-gamma release assay. Int J Tuberc Lung Dis. 2011 May;15(5):635–40. doi: 10.5588/ijtld.10.0485. PMID: 21756514.21756514
246 Salindri AD, Auld SC, Schechter MC, Negative tuberculin skin test result predicts all-cause mortality among tuberculosis patients with HIV and diabetes comorbidity. Ann Epidemiol. 2019 May;33:72–8.e4. doi: 10.1016/j.annepidem.2019.02.005. PMID: 30954339.30954339
247 Shalabi NM, Houssen ME. Discrepancy between the tuberculin skin test and the levels of serum interferon-gamma in the diagnosis of tubercular infection in contacts. Clin Biochem. 2009 Nov;42(16-17):1596–601. doi: 10.1016/j.clinbiochem.2009.08.013. PMID: 19732759.19732759
248 Shrestha R, Gyawali P, Yadav BK, In-vitro assessment of cell-mediated immunity by demonstrating effector-t cells for diagnosis of tuberculosis in Nepalese subjects. Nepal Med Coll J. 2011 Dec;13(4):275–8. PMID: 23016479.23016479
249 Tang J, Huang Y, Jiang S, QuantiFERON-TB Gold Plus combined with HBHA-Induced IFN-γ release assay improves the accuracy of identifying tuberculosis disease status. Tuberculosis (Edinb). 2020 Sep;124:101966. doi: 10.1016/j.tube.2020.101966. PMID: 32866942.32866942
250 Telisinghe L, Amofa-Sekyi M, Maluzi K, The sensitivity of the QuantiFERON(^®^)-TB Gold Plus assay in Zambian adults with active tuberculosis. Int J Tuberc Lung Dis. 2017 Jun 1;21(6):690–6. doi: 10.5588/ijtld.16.0764. PMID: 28482964.28482964
251 Turtle L, Kemp T, Davies GR, In routine UK hospital practice T-SPOT.TB is useful in some patients with a modest pre-test probability of active tuberculosis. Eur J Intern Med. 2012 Jun;23(4):363–7. doi: 10.1016/j.ejim.2012.01.002. PMID: 22560387.22560387
252 Wang L, Yu Y, Chen W, Evaluation of the characteristics of the enzyme-linked immunospot assay for diagnosis of active tuberculosis in China. Clin Vaccine Immunol. 2015 May;22(5):510–5. doi: 10.1128/cvi.00023-15. PMID: 25739918.25739918
253 Wang F, Yu J, Zhou Y, The use of TB-specific antigen/phytohemagglutinin ratio for diagnosis and treatment monitoring of extrapulmonary tuberculosis. Front Immunol. 2018;9:1047. doi: 10.3389/fimmu.2018.01047. PMID: 29868010.29868010
254 Warria K, Nyamthimba P, Chweya A, Tuberculosis disease and infection among household contacts of bacteriologically confirmed and non-confirmed tuberculosis patients. Trop Med Int Health. 2020 Jun;25(6):695–701. doi: 10.1111/tmi.13392. PMID: 32170771.32170771
255 Wawrocki S, Seweryn M, Kielnierowski G, IL-18/IL-37/IP-10 signalling complex as a potential biomarker for discriminating active and latent TB. PLoS One. 2019;14(12):e0225556. doi: 10.1371/journal.pone.0225556. PMID: 31821340.31821340
256 Xu HY, Li CY, Su SS, Diagnosis of tuberculous pleurisy with combination of adenosine deaminase and interferon-γ immunospot assay in a tuberculosis-endemic population: a prospective cohort study. Medicine (Baltimore). 2017 Nov;96(47):e8412. doi: 10.1097/md.0000000000008412. PMID: 29381918.29381918
257 Denholm JT, McBryde ES, Eisen D, SIRCLE: a randomised controlled cost comparison of self-administered short-course isoniazid and rifapentine for cost-effective latent tuberculosis eradication. Intern Med J. 2017 Dec;47(12):1433–6. doi: 10.1111/imj.13601. PMID: 29224209.29224209
258 Schein YL, Madebo T, Andersen HE, Treatment completion for latent tuberculosis infection in Norway: a prospective cohort study. BMC Infect Dis. 2018 Nov 19;18(1):587. doi: 10.1186/s12879-018-3468-z. PMID: 30453946.30453946