# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Sheena Harris, MD, MPH, AHRQ Medical Officer; Tina Fan, MD, MPH, AHRQ Medical Officer; Tracy Wolff, MD, MPH, Scientific Director, U.S. Preventive Services Task Force (USPSTF) Division, AHRQ; current and former members of the USPSTF; expert reviewers: Jon Warkentin, MD, MPH, Tennessee Department of Health; Pennan Barry, MD, MPH, California Department of Public Health; John Bernardo, MD, Boston University School of Medicine; Ned Calonge, MD, MPH, The Colorado Trust; Federal partner reviewers from the Centers for Disease Control and Prevention; Sharon Barrell, MA, editor; Teyonna Downing, publications specialist; and Roberta Wines, MPH, EPC Program Manager.