# Chapter 4 Discussion

## Summary of Evidence

Table 3 provides a summary of the main findings in this evidence review organized by KQ along with a description of consistency, precision, quality, limitations, strength of evidence, and applicability. This review did not find evidence on whether results differ for specific populations defined by age, sex, pregnancy, or race/ethnicity. Applicability of the findings to specific populations at higher risk for TB is described below in the sections on accuracy of screening tests and treatment of LTBI.

Table 3 Summary of Evidence on Screening for LTBI in Adults

Key Question and Topic | No. of Studies (k), No. of Participants (n) | Summary of Findings | Consistency and Precision | Study Quality | Limitations (Including Reporting Bias) | Overall Strength of Evidence | Applicability
KQ 1. Benefits of screening | 0, 0 | No eligible studies | NA | NA | NA | Insufficient | NA
KQ 2. Accuracy of screening; TST 5-mm accuracy | Sn 12 (1,323); Sp 3 (5,149); Observational studies of test accuracy | Sn pooled 0.80 (95% CI, 0.74 to 0.87, I^2^=94.2%); Sp pooled 0.95 (95% CI, 0.94 to 0.97) | Consistent but imprecise for Sn; Consistent and precise for Sp | Fair to Good | Independent interpretation of test often not reported; Description of participant characteristics highly variable across studies; Reporting bias not detected | Moderate for Sn; High for Sp | TST using Mantoux procedure with intermediate-strength dose of PPD; Lack of direct test for LTBI requires extrapolation of test characteristics from active TB (Sn) and healthy, low-risk populations (Sp)
KQ 2. Accuracy of screening; TST 10-mm accuracy | Sn 15 (1,427); Sp 8 (9,604); Observational studies of test accuracy | Sn pooled 0.81 (95% CI, 0.76 to 0.87, I^2^=91.4%); Sp pooled 0.98 (95% CI, 0.97 to 0.99, I^2^=96.2%) | Consistent but imprecise for Sn; Consistent and precise for Sp | Fair to Good | Independent interpretation of test often not reported; Description of participant characteristics highly variable across studies; Reporting bias not detected | Moderate for Sn; High for Sp | TST using Mantoux procedure with intermediate-strength dose of PPD; Lack of direct test for LTBI requires extrapolation of test characteristics from active TB (Sn) and healthy, low-risk populations (Sp)
KQ 2. Accuracy of screening; TST 15-mm accuracy (continued) | Sn 9 (1,004); Sp 10 (9,563); Observational studies of test accuracy | Sn pooled 0.60 (95% CI, 0.46 to 0.74, I^2^=89.8%); Sp pooled 0.99 (95% CI, 0.98 to 0.99, I^2^=88.7%) | Inconsistent and imprecise for Sn; Consistent and precise for Sp | Fair to Good | Independent interpretation of test often not reported; Description of participant characteristics highly variable across studies; Reporting bias not detected | Low for Sn; High for Sp | TST using Mantoux procedure with intermediate-strength dose of PPD; Lack of direct test for LTBI requires extrapolation of test characteristics from active TB (Sn) and healthy, low-risk populations (Sp); The 15-mm threshold is not recommended in current practice for patients at high risk for TB infection
KQ 2. Accuracy of screening; TST reliability | Interrater reliability 3 (3,142); Observational studies of test accuracy | Kappa 0.69 and 0.79 in two studies assessing reliability of rater assessment of skin test reaction in healthy populations at low risk for TB; Kappa 0.52 to 0.78 of rater assessment of skin test reaction as assessed in different study with populations including subjects with active TB and healthy, low -risk subjects | Consistent for moderate to substantial agreement; precision unknown | Fair | Reliability may be affected by the populations in which it is assessed; studies did not use similar methods for evaluating reliability; Reporting bias not detected | Low | TST using Mantoux procedure with intermediate-strength dose of PPD; TST administration and interpretation dependent on the use of appropriate, standardized technique
KQ 2. Accuracy of screening; IGRA T-SPOT.TB accuracy (continued) | Sn 37 (5,367); Sp 2 (1,664); Observational studies of test accuracy | Sn pooled 0.90 (95% CI, 0.87 to 0.92, I^2^=93.2%); Sp from 2 studies:; 0.95 (0.91 to 0.97); 0.97 (0.96 to 0.98) | Consistent and precise for Sn and Sp | Fair to Good for Sn; Fair for Sp | Independent interpretation of test often not reported; description of participant characteristics highly variable across studies; Studies varied with respect to how they reported borderline results; Reporting bias not detected | High for Sn; Moderate for Sp | Lack of direct test for LTBI requires extrapolation of test characteristics from active TB (Sn) and healthy, low-risk (Sp) populations
KQ 2. Accuracy of screening; IGRA T-SPOT.TB reliability (continued) | Interrater reliability 2 (404); Reproducibility 1 (130); Test-retest 2 (296); Observational studies of test accuracy | 1 study conducted in active TB patients with manual interpretation: interrater reliability 96% (kappa 0.92), manual vs. automatic interpretation: interrater reliability 85.8% (kappa 0.73); 1 study conducted among immigrants who were close contacts of active TB patients with kappa >0.6 among 6 manual readers; Discordant results in participants who had 2 samples drawn simultaneously (same lab and method of interpretation): 10/153 (6.5%); 1 study enrolling HCWs: 9/111 (8.1%) tests changed from negative to positive and 10/19 (52.6%) changed from positive to negative at 2 weeks. 1 study enrolling Nepalese military recruits, kappa for agreement between initial test and retest=0.66 (95% CI, 0.50 to 0.83) | Consistent for interrater reliability, unknown precision; Consistency unknown for single study, unknown precision; Inconsistent and imprecise for test-retest reliability | Fair | Independent interpretation of test often not reported; description of participant characteristics highly variable across studies; Studies varied with respect to how they reported borderline results; Reporting bias not detected | Low | T-SPOT.TB requires proper specimen handling prior to assay; interpretation of test can be done manually through visual inspection or through use of machine that automates interpretation
KQ 2. Accuracy of screening; IGRA QFT-GIT accuracy (continued) | Sn 48 (7,055); Sp 3 (2,090); Observational studies of test accuracy | Sn pooled 0.81 (95% CI, 0.79 to 0.84, I^2^=89.9%); Sp pooled 0.99 (95% CI, 0.98 to 0.99) | Consistent and precise for Sn and Sp | Fair to good for Sn; Fair for SP | Independent interpretation of test often not reported; description of participant characteristics highly variable across studies; Studies varied with respect to how they reported indeterminate results; Reporting bias not detected | High for Sn; Moderate for Sp | Lack of direct test for LTBI requires extrapolation of test characteristics from active TB (Sn) and healthy, low-risk (Sp) populations; QFT-GIT requires proper specimen handling prior to assay
KQ 2. Accuracy of screening; IGRA QFT-GIT reliability (continued) | Interrater reliability 1 (146); Reproducibility 1 (130); Test-retest reliability 2 (296); Interlaboratory reliability 1 (91); Observational studies of test accuracy | Across all 4 tests (2 samples from each participant analyzed by manual and automated ELISA): 88.6% were concordant (16.0% concordant positive and 72.6% concordant negative); 11.0% were discordant. Discordance by method of interpretation: automated vs. automated=4.8% (kappa 0.85); manual vs. manual=6.9% (kappa 0.80); automated vs. manual=3.4% to 9.0% across comparisons (kappa 0.73 to 0.90); Number of discordant results in participants who had 2 samples drawn simultaneously: 10 /172 (5.8%); 1 study enrolling HCWs, 10/134 (7.5%) results changed from negative to positive and 5/15 (33.3%) changed from positive to negative at 2 weeks. In the other study enrolling Nepalese military recruits, kappa for agreement between initial test and retest: 0.48 (95% CI, 0.26 to 0.70); Across 3 labs, 7/91 (7.7%) subjects had discordant results; kappas of pairwise lab sample comparisons were 0.87, 0.89, and 0.93 | Consistency unknown for single study, precision unknown; Consistency unknown for single study, precision unknown Inconsistent and imprecise for test-retest reliability; Consistency unknown for single study, precision unknown | Fair | High loss to followup between initial and followup testing; Reporting bias not detected | Insufficient | QFT-GIT requires proper specimen handling prior to assay, range of subjects including healthy controls, active TB, and close contacts
KQ 2. Accuracy of screening; IGRA QFT-Plus accuracy (continued) | Sn 11 (939); Sp 1 (211); Observational studies of test accuracy | Sn pooled 0.89 (95% CI, 0.84 to 0.94, I^2^=87.9%); Sp from 1 study: 0.98 (95% CI, 0.95 to 0.99) | Consistent and precise for Sn; Consistency unknown for single study, precise for Sp | Fair | Independent interpretation of test not reported; Reporting bias not detected | Moderate for Sn; Low for Sp | QFT-Plus requires proper specimen handling prior to assay
KQ 3. Benefits of treatment; INH vs. placebo | 1 RCT (27,830)^*^; Sensitivity analysis with 5 RCTs (36,823) | Developing active TB:; Main analysis; RR: 0.35 at 5 years’ followup (95% CI, 0.24 to 0.52) for INH × 24 weeks^†^ compared with placebo; NNT=112; Sensitivity analysis; RR: 0.31 at 2 to 10 years’ followup^‡^ (95% CI, 0.24 to 0.41) | Consistency NA for the single study; reasonably precise for developing active TB; Consistent across 5 RCTs used in sensitivity analysis for developing active TB (I^2^=0%); precise | Good (fair to good for Sn analysis) | Studies used in sensitivity analysis used longer duration (1 year of INH)^§^ and some used doses lower or higher than currently recommended; 1 trial was poor quality for high risk of selection, attrition, and measurement bias and confounding; Reporting bias not detected | High for benefit | Study population in main analysis trial included those with fibrotic pulmonary lesions and a ≥6-mm TST; median age 50; trials in main and sensitivity analysis published >30 years ago (1963, 1965, 1968, 1978, 1982). Trials in sensitivity analysis enrolled HH contacts of active cases, veterans with inactive pulmonary TB, persons residing in mental institutions, and military members exposed to an active TB case
KQ 3. Benefits of treatment; INH vs. placebo | 1 RCT (27,830)^*^ | Deaths due to TB: 0 vs. 3; RR: 0.14 (95% CI, 0.01 to 2.78) for the combined INH groups vs. placebo | Imprecise, consistency unknown | Good | Small number of events | Low for benefit | Same as above for main analysis applicability
KQ 3. Benefits of treatment; INH vs. placebo | 1 RCT (27,830)^*^ | All-cause mortality: NR by group | Imprecise, consistency unknown | Good | Data on all-cause mortality NR by group | Insufficient | Same as above for main analysis applicability
KQ 3. Benefits of treatment; RIF vs. INH | 2 RCTs (6,910) | Developing active TB: 8 vs. 9; All-cause mortality: 22 vs. 15 | Imprecise, consistency unknown | Fair to good | Open label, but used fairly rigorous methods with masked review panel. Unclear allocation concealment. | Low for non-inferiority of shorter-duration RIF | Study population included those 18 years or older with a positive TST/IGRA. Second study required patients to be at increased risk of progression to active TB. About half of participants were ages 18– 35 years.
KQ 3. Benefits of treatment; RIF vs. INH | 1 RCT (847) | Deaths due to TB: 0 vs. 0 | Imprecise, consistency unknown | Good | No events. Unclear allocation concealment. | Insufficient
KQ 3. Benefits of treatment; RPT+INH vs. INH | 1 RCT (6,886)^‖^ | Developing active TB: 5 vs. 10^¶^ | Consistency NA, single study; reasonably precise for developing active TB and all-cause mortality | Fair | Open label; single study, no data for deaths due to TB | Low for non-inferiority of RPT+INH | Median age 37; just over half male; 57% White; combined intervention was directly observed once weekly for 3 months; high-risk subjects; most had a close contact with an active TB case; 25% were included solely because of recent TST conversion
KQ 3. Benefits of treatment; RPT+INH vs. INH | 1 RCT (263) | Deaths due to TB: 0 vs. 0 | Consistency NA, single study; imprecise (no events) | Fair | Open label; small study. Noncompletion and consent withdrawal significantly higher in 9H group. No data for developing active TB. | Insufficient | Study completed in Taiwan; age ≥12 years, mean age 32; 58% male; all subjects had close contact with an active TB case and had positive TST within 1 month after exposure
KQ 3. Benefits of treatment; RPT+INH vs. INH | 2 RCTs (7,149) | All-cause mortality: 30 vs. 34 | Consistency NA, single study. Reasonably precise for all-cause mortality | Fair | Both studies were open label. One had higher noncompletion and consent withdrawal in 9H group. | Low for non-inferiority of RPT+INH | As above
KQ 4. Harms of screening | 0, 0 | No eligible studies | NA | NA | NA | Insufficient | NA
KQ 5. Harms of treatment; INH vs. Placebo | 1 RCT (27,830)^*^; Sensitivity analysis with 4 RCTs (35,161) | Hepatotoxicity:; Main analysis:; RR: 4.59 at 5 years (95% CI, 2.03 to 10.39) for 24 weeks INH compared with placebo; NNH=279; Sensitivity analysis: Pooled RR: 5.04^†^ (95% CI, 2.50 to 10.15; I 2=0%); Dose-response effect seen with increased risk with longer treatment duration | Consistency NA, single study in main analysis; consistent across studies in sensitivity analysis; imprecise | Fair | Harm ascertainment techniques not well described.; Studies used in sensitivity analysis limited by ascertainment bias | Moderate for harm | Study population in main analysis trial includes those with fibrotic pulmonary lesions and a ≥6-mm TST; median age 50; trial published in 1982. Trials in sensitivity analysis published in 1974, 1977, and 1978 and enrolled employees in a U.S. hospital, individuals meeting ATS criteria referred to a U.S. military medical center, and veterans with inactive pulmonary TB
KQ 5. Harms of treatment; INH vs. Placebo | 1 RCT (27,830)^*^ | Death from hepatotoxicity^‡^: 0 in placebo group, 0.14 per 1,000 receiving INH; RR: 2.35 (95% CI, 0.12 to 45.46; NNH=6,947) | Consistency NA, single study; imprecise | Fair | Rare number of events; Harm ascertainment techniques not well described | Low for harm | Same as above for hepatotoxicity
KQ 5. Harms of treatment; INH vs. Placebo | 1 RCT (27,830)^*^; Sensitivity analysis with 4 RCTs (55,398) | Discontinuation of treatment due to adverse events:; Main analysis: RR: 1.50^†^ (95% CI, 1.18 to 1.89; NNH=167); Sensitivity analysis: Pooled RR: 1.58 (95% CI, 1.00 to 2.49) | Consistency NA, single study in main analysis; reasonably consistent across the studies in sensitivity analysis; reasonably precise | Fair | Harm ascertainment techniques not well described; Studies used in sensitivity analyses limited by lack of prespecification of harm outcomes, ascertainment bias | Moderate for harm | Same as above for hepatotoxicity
KQ 5. Harms of treatment; INH vs. Placebo | 1 RCT (27,830)^*^ | GI adverse events: RR: 1.33^†^ (95% CI, 1.01 to 1.75) Sensitivity analysis: Different outcomes reported across studies; no differences among groups | Consistency NA, single study; reasonably precise | Fair | GI harms not prespecified, ascertainment bias | Low for harm | Study population in main analysis trial includes those with fibrotic pulmonary lesions and a ≥6-mm TST; median age 50; trial published in 1982
KQ 5; INH vs. RIF | 4 RCTs (7,390) | Hepatotoxicity: Pooled RR, 4.22 (95% CI, 2.21, 8.06), 3 trials, 7,339 participants; Death from hepatotoxicity: No events reported in any arms of any study | Consistent; precise | Fair to good | 3 trials were open label, 1 trial with high attrition | High for greater risk of hepato-toxicity with INH | Trials published in 2004, 2008, 2012, 2018^α^; participants had positive TST following Canadian guidelines or were inmates diagnosed with LTBI at jail entry
KQ 5; INH vs. RIF | 4 RCTs (7,390) | Discontinued due to AEs: RR, 2.25 (95% CI, 0.90 to 5.59), 3 trials, 7,339 participants | Inconsistent; imprecise | Fair to good | 3 trials were open label, 1 trial with high attrition | Low | Same as above
KQ 5; INH vs. RIF | 3 RCTs (7,274) | GI intolerance: 20 vs. 19 The calculated RRs for the two trials with sufficient data were: 0.34 (95% CI, 0.03, 3.23) and 1.16 (95% CI, 0.62 to 2.19). | Inconsistent, imprecise | Fair | 1 trial with high attrition; duration of followup may be inadequate; ascertainment bias | Insufficient | Same as above
KQ 5; RPT + INH vs. INH | 2 RCTs (7,149)^‖^ | Hepatotoxicity; From PREVENT TB trial: grade 3 or 4: 210 vs. 219^¶,^ RR, 0.90 (95% CI, 0.75 to 1.08); hepatoxicity attributable to study drug: 17 vs. 97, RR, 0.16 (95% CI, 0.10 to 0.28).; From Sun, 2018: AST/ALT >3x ULN: 6 vs. 13, RR, 0.46 (95% CI, 0.18 to 1.17); clinically relevant hepatotoxicity: 2 vs. 7, RR, 0.28 (95% CI, 0.06 to 1.34); mortality due to hepatotoxicity: 0 vs. 0 | Consistent, imprecise | Fair | One study was open label; one had high overall attrition, and the other had higher withdrawal and noncompletion rates in one group | Low (favoring less hepato-toxicity with RPT+INH) | PREVENT TB trial published in 2011, data were from HIV-negative subgroup with TST or IGRA confirmation; combined intervention was directly observed once week x 3 months; high-risk individuals; most had close contact with an active TB case; 25% were included solely because of recent TST conversion; one study completed in Taiwan; all subjects had close contact with an active TB case and had positive TST within 1 month after exposure
KQ 5; RPT + INH vs. INH | 2 RCTs (7,149) | Discontinuation due to AE: PREVENT TB: 186 vs. 136, RR, 1.28 (95% CI, 1.03 to 1.59); In Sun, 2018 12 vs. 7, RR, 1.70 (95% CI, 0.69 to 4.19) | Consistent, precise | Fair | One study was open label; one had high overall attrition, and the other had higher withdrawal and noncompletion rates in one group | Moderate (favoring lower discontinuation due to AE with INH) | Same as above
KQ 5; RPT + INH vs. INH | 2 RCTs (7,149) | Systemic drug reactions and hypersensitivity; PREVENT TB; Possible hypersensitivity: 146 vs. 17; RR, 8.04 (95% CI, 4.88 to 13.26); any clinically significant systemic drug reaction: 138 vs. 15, RR, 8.7 (95% CI 5.1 to 14.7).; Sun, 2018: Any systemic drug reaction: 5 vs. 0, RR, 10.9 (95% CI, 0.6 to 195.5) | Consistent, imprecise | Fair | One study was open label; one had high overall attrition, and the other had higher withdrawal and noncompletion rates in one group | Low (favoring fewer systemic drug reactions with INH) | Same as above
RIF + INH vs. RPT + INH | 1 RCT (52) | Hepatotoxicity: 4 vs. 3 participants; Mortality from hepatotoxicity: 0 vs. 0; Discontinuation due to AEs (hepatotoxicity): 1 vs. 0 | Consistency NA, single study; imprecise | Fair | One small pilot trial with small sample size and very few events | Insufficient | Subjects ages 16 to 65 years with confirmed LTBI at clinics in London, UK; mean age 32.5 vs. 38.2 years
KQ 5; RPT + INH weekly vs. RPT + INH twice weekly | 1 RCT (3,738) | Hepatotoxicity: 13 vs. 15 participants; RR, 0.88 (95% CI, 0.42 to 1.84); Mortality from hepatotoxicity: 0 vs. 0; Discontinuation due to AE: 77 vs. 82; RR, 0.95 (95% CI, 0.70 to 1.28); Hypersensitivity or allergy: 43 vs. 65; RR, 1.69 (95% CI, 1.26 to 2.27); Flu-like symptoms: 46 vs. 29; RR, 1.60 (95% CI, 1.01 to 2.54) | Consistency NA, single study; imprecise | Fair | Open label; study shortened treatment duration because of adverse effects | Insufficient | Subjects ages 50 to 69 years living in rural China with a positive QFT-GIT; 45% female

* Of the 27,830 participants in the IUAT trial, the only trial meeting all eligibility criteria for KQ 3 that compared INH with placebo, 6,965 were treated with a CDC-approved regimen (INH 300 mg × 24 weeks). The IUAT trial randomized 27,830 participants to INH 300 mg × 12 weeks (6,956), INH 300 mg × 24 weeks (6,965), INH 300 mg × 52 weeks (6,919), or placebo (6,990).

† The relative risks for the other treatment groups developing active TB compared with placebo were 0.79 (95% CI, 0.58 to 1.06) and 0.25 (95% CI, 0.16 to 0.39) for 12 and 52 weeks of INH, respectively.

‡ Followup for the five RCTs included in the sensitivity analysis ranged from 2 to 10 years; one study followed patients for 2 years, one for 5 years (IUAT), two for 7 years, and one for 10 years.

§ No longer a CDC-recommended treatment regimen.

‖ This open-label, noninferiority trial randomized 7,731 subjects; we obtained data from the CDC for this table on the subset of participants most directly relevant for this review: the 6,886 adults (age ≥18 years) who were HIV negative and were TST or IGRA positive.

¶ The combination therapy group was found to be noninferior to the INH-only group.

Abbreviations: AE=adverse event; AST=aspartate transaminase; ALT=alanine transaminase; CDC=Centers for Disease Control and Prevention; CI=confidence interval; ELISA=enzyme-linked immunosorbent assay; HCW=healthcare worker; HIV=human immunodeficiency virus; HH=household; I^2^=the proportion of variation in study estimates due to heterogeneity; IGRA=interferon-gamma release assay; INH=isoniazid; IUAT=International Union Against Tuberculosis; k=number of studies; KQ=key question; LTBI=latent tuberculosis infection; n=number; NA=not applicable; NNT=number needed to treat; No.=number; NR=not reported; PPD=purified protein derivative; QFT-GIT=QuantiFERON-TB Gold-In-Tube® test (3rd-generation test); QFT-Plus=QuantiFERON-TB Gold Plus® test (4th generation test); RCT=randomized, controlled trial; RIF=rifampin; RPT=rifapentine; RR=relative risk; Sn=sensitivity; Sp=specificity; TB=tuberculosis; T-SPOT.TB=Commercial ELISPOT Assay; TST=tuberculin skin test; ULN=upper limit of normal; vs.=versus.

## Evidence for Benefit and Harms of Screening

We did not identify any RCTs or prospective cohort studies directly assessing the effectiveness or harms of screening for LTBI compared with no screening in the populations and outcomes specified for this review. Therefore, the strength of evidence was graded as insufficient for KQs 1 and 4.

## Accuracy and Reliability of Screening Tests

The lack of tests for the direct diagnosis of LTBI necessitates that evaluating the accuracy of screening tests relies on extrapolation from studies of persons with active, confirmed TB (sensitivity) or healthy persons without TB risks and exposures (specificity). The evidence suggests that for the populations and settings studied, currently available tests are moderately sensitive and highly specific. Previously published systematic reviews evaluating accuracy of screening tests for LTBI, including our prior review for the USPSTF,^186^ are generally consistent with our findings.^187–190^ The applicability of the evidence to primary care practice settings and populations is somewhat uncertain because the lack of a direct test for LTBI requires screening test accuracy studies to be conducted in specific populations (e.g., populations with active, confirmed TB for estimates of sensitivity). Nevertheless, it seems reasonable to assume applicability to primary care practice settings that serve high-risk populations (e.g., clinics serving persons who had temporary or permanent residence in a country with a high TB rate), where the use of a highly specific test among a higher prevalence population minimizes false positives and a moderately sensitive test (conducted after it is indicated by a clinical risk assessment) can help determine the likelihood of infection to inform treatment decisions.

## Benefits and Harms of Treatment of LTBI

The best evidence on effectiveness of pharmacotherapy with a CDC-recommended regimen versus placebo is from the IUAT trial (N=27,830). It enrolled subjects with pulmonary fibrotic lesions, a group thought to be at the highest risk for progression to active TB, and it reported that participants with smaller lesions progressed to active TB at lower rates than those with larger lesions. In addition, the treatment studies used in our sensitivity analysis did not enroll populations that were identified to have LTBI via screening in primary care settings; rather, they were household contacts of active cases,^164^ veterans with inactive pulmonary TB,^165,^ ^183^ persons residing in mental institutions,^166^ and military members exposed to an active TB case.^167^ Thus, the available evidence has uncertain applicability to persons in primary care settings who screen positive on the TST or IGRA but have normal chest X-rays or who are not recent converters or close contacts. Therefore, estimates of treatment effectiveness may represent the upper bounds of effectiveness. When assessing applicability of the evidence comparing INH with placebo, we note that the trials were published more than 40 years ago (1963, 1965, 1968, 1978, and 1982) and treatment of LTBI has been the standard of care for decades. More current data for estimating effectiveness were not available. It is unclear whether changes in the prevalence of TB (which has decreased), treatments for active TB, or likelihood of LTBI progressing to active TB would significantly change estimates of effectiveness. Trials comparing INH with placebo mostly evaluated longer durations of treatment (e.g., 1 year of isoniazid) because longer durations were recommended at the time. After INH had established effectiveness, subsequent studies evaluated shorter durations of treatment and other regimens (compared with standard INH regimens) and were generally focused on harm reduction, improving adherence, or both. Early studies of INH indicated a four- to five-fold increase in hepatotoxicity compared with placebo, although deaths because of hepatotoxicity were very rare—a total of three participants in IUAT, all of whom had continued to take INH after liver abnormalities were recognized. Subsequent head-to-head trials and network meta-analyses indicated noninferiority, improved adherence, and lower risk of hepatotoxicity for current CDC-preferred LTBI treatments (rifampin, INH plus rifapentine, and INH plus rifampin) than with INH alone.

## Limitations

Our review had limitations. First, it did not cover testing of close contacts of persons with active TB (usually managed by public health programs) or high-risk populations for whom LTBI testing is considered part of standard disease management (e.g., persons with HIV, persons with planned or active use of tumor necrosis factor-alpha inhibitors or other targeted immune modulators). Next, we did not evaluate cost-effectiveness. A 2011 publication estimated the incremental cost-effectiveness of screening for LTBI as cost saving for IGRA compared with TST and as $100,000 per quality-adjusted life year (QALY) gained for IGRA compared with no screening for persons born outside the US.^191^ A 2017 publication reported that screening for and treating LTBI among persons born outside the US is likely cost-effective except among persons with end-stage renal disease (because of competing risks of death).^192^ A 2020 publication found that the cost-effectiveness of targeted screening for and treatment of LTBI varied significantly across populations and states,^193^ likely attributable to differences in prevalence of TB and risk factors for LTBI from region to region. Testing and treatment consistently prevented the most TB cases for persons born outside the US.^193^ Next, there is uncertainty about the applicability of studies conducted outside of the United States. For example, differences in healthcare and social services systems could potentially influence study results through availability of support (or lack thereof) for following up to have TSTs assessed or access to DOT. Incorporation of country TB burden in our eligibility criteria, results, and analyses served as a proxy for some applicability issues in that realm. Finally, we did not identify eligible studies focused on pregnant women. Some studies of potential harms of LTBI treatment among pregnant women that were not eligible for our review (e.g., because all participants were persons living with HIV) may help to inform treatment decisions for pregnant women. For example, a retrospective cohort study of almost 44,000 women on antiretroviral therapy for HIV in South Africa compared outcomes for the 7,310 who received 6 to 12 months of INH 5 mg/kg/day (per national guidelines for TB prevention in persons living with HIV) with the others who did not and found improved pregnancy outcomes for those taking INH, including decreased miscarriage and stillbirth.^194^ In addition, analysis of data from the PREVENT TB and iAdhere trials of pregnant women inadvertently exposed to either INH or rifapentine found no increase in fetal loss or congenital anomalies.^195^ The current joint guidelines from the American Academy of Pediatrics and the American College of Obstetrics and Gynecology recommend screening for latent TB in early pregnancy for women at high risk for TB, including recent TB exposure, HIV infection, risk factors increasing risk of progression to active disease (e.g., cancer), use of immune-suppressing drugs such as tumor necrosis factor-alpha inhibitors or chronic steroids, renal failure on dialysis, homelessness, living or working in long-term care facilities such as nursing homes and prisons, being medically underserved, and being born in a country with high prevalence of TB.^196^

## Future Research Needs

While progress toward the public health goal of TB elimination in the United States continues, future research could potentially improve programs that screen for and treat LTBI. Research that informs our understanding of the incremental net benefit of more or less frequent screening could help determine optimal approaches to screening. Future research on the optimal approaches for identifying appropriate candidates for LTBI screening (i.e., risk assessment tools to identify persons at sufficiently high risk) could improve screening programs. For example, operations research could evaluate efficient ways to identify persons with risk factors that warrant screening within low-prevalence primary care settings. Such settings may have more challenges with implementing screening for LTBI than specialized clinics that care for high-risk populations and therefore commonly screen for LTBI (e.g., prison clinics, clinics serving large proportions of persons born outside the US). Further, development of tests or approaches that are able to identify which persons with LTBI will or will not develop active TB disease would optimize efficiency of LTBI treatment and reduce unnecessary harms, for example, from treating persons who would never have developed active TB and exposing them to potential adverse drug effects and the socioeconomic disruptions of taking a medication and the required, related monitoring.

Future research on new pharmacotherapy regimens or even shorter treatment durations could potentially identify treatment regimens that would further optimize benefits and adherence while further limiting harms. The BRIEF (Brief Rifapentine-Isoniazid Efficacy for TB) trial found 1 month of INH plus rifapentine to be noninferior to 9 months of INH for a composite outcome of progression to TB or death from TB or unknown causes among persons living with HIV.^197^ Completion of therapy was also greater for the 1-month regimen. The 1-month regimen is not listed in the CDC recommendations, although it is listed as an alternative choice in the WHO guidelines. The regimen has not been studied in persons without HIV. The BRIEF trial participants were eligible if they were from an area with a high prevalence of TB or if they had evidence of LTBI; of those enrolled, only 23 percent had a positive TST or IGRA.

## Conclusion

No studies evaluated the benefits and harms of screening for LTBI compared with no screening. TST and IGRAs are moderately sensitive and highly specific. Treatment of LTBI with recommended regimens reduces the risk of progression to active TB. INH is associated with higher rates of hepatotoxicity than placebo or rifampin.