# Chapter 3 Results

## Literature Search

We identified 3,801 unique records and assessed 526 full-text articles for eligibility (Figure 2). We excluded 413 articles for various reasons, detailed in Appendix C, and included 113 articles representing 112 studies. Details of quality assessments of included studies are in Appendix D Tables 1 and 2. For most KQs, this review did not find evidence on whether results differ for specific populations of interest (e.g., no subgroup analyses describing effect modification by age or sex). Studies were usually not designed or powered to assess whether results differed for specific populations; any exceptions are described within each KQ below.

Figure 2 Summary of Evidence Search and Selection

Figure 2 is a flow diagram that documents the search and selection of articles. There were 3,679 unique records identified by searching PubMed (n=3,324) and Cochrane Library (n=355). In addition, 91 records were included from the previous review. In total, 3,801 titles and abstracts were screened for potential inclusion after duplicates were removed. Of these, 526 were deemed appropriate for full-text review to determine eligibility. After full-text review, 413 were excluded: 17 for not being original research; 188 for ineligible population; 48 for ineligible intervention; 40 for ineligible or no comparator; 36 for ineligible or no outcome; 45 for ineligible study design; 5 for ineligible language/non-English; 2 for ineligible country; and 32 for poor quality. 112 studies, described in 113 articles, met inclusion criteria. Zero studies were included for Key Question 1. 101 studies were included for Key Question 2. Six studies were included for Key Question 3. Zero studies were included for Key Question 4. Ten studies, described in 12 articles, were included for Key Question 5.

## Results by Key Question

### KQ 1 What Are the Benefits of Targeted Screening for LTBI in Primary Care Settings in Asymptomatic Adults Who Are at Increased Risk for Developing Active TB, Including Among Specific Populations of Interest?

We found no eligible studies that addressed this question.

### KQ 2a What Are the Accuracy and Reliability of the TST or IGRA for Screening in Asymptomatic Adults Who Are at Increased Risk for Developing Active TB Disease, Including Among Specific Populations of Interest?

We identified 101 studies of good or fair quality assessing the sensitivity, specificity, or reliability of one or more of the included screening tests. Thirty-two studies reported on TST and are detailed in Appendix D Tables 1 and 3.^53–84^ Thirty-nine studies reported on T-SPOT.TB.^54,^ ^72–74,^ ^78,^ ^81,^ ^83,^ ^85–116^ Twelve studies^105,^ ^106,^ ^115–125^ reported on QFT-Gold Plus and 51 studies reported on QFT-GIT.^53,^ ^54,^ ^58,^ ^60,^ ^66,^ ^71,^ ^76–79,^ ^85,^ ^89,^ ^93,^ ^98,^ ^100,^ ^102,^ ^103,^ ^105,^ ^106,^ ^114,^ ^115,^ ^117–122,^ ^124,^ ^126–148^ Detailed study characteristics for the IGRA tests are reported in Appendix D Tables 2 and 4. Across this body of evidence, the mean age of enrolled persons ranged from 30 years to 71 years and the proportion of men ranged from 38 percent to 86 percent. Nineteen studies were conducted exclusively or partly in the United States.^54–56,^ ^59,^ ^62,^ ^64,^ ^65,^ ^67–69,^ ^72,^ ^80,^ ^94,^ ^117,^ ^122,^ ^140,^ ^149–151^ We rated 25 studies as good quality and 76 studies as fair quality; individual study quality ratings are in Appendix E Table 1.

#### Sensitivity of Screening Tests

##### TST

Twenty-one studies estimated sensitivity for TST using various thresholds for a positive test.^53,^ ^55,^ ^57,^ ^58,^ ^61,^ ^63,^ ^66,^ ^69,^ ^71,^ ^73–84^ Characteristics of studies are provided in Appendix D Table 1. Twelve studies reported sensitivity using a 5-mm induration threshold,^53,^ ^55,^ ^61,^ ^63,^ ^66,^ ^73,^ ^74,^ ^76,^ ^78,^ ^80–82^ 15 studies reported sensitivity using a 10-mm induration threshold,^53,^ ^55,^ ^57,^ ^58,^ ^61,^ ^69,^ ^71,^ ^73–77,^ ^80,^ ^83,^ ^84^ and nine studies reported sensitivity using a 15-mm induration threshold.^53,^ ^55,^ ^57,^ ^61,^ ^73,^ ^74,^ ^76,^ ^77,^ ^79^ Six studies estimating TST sensitivity were conducted in countries with a high TB burden;^53,^ ^58,^ ^77,^ ^79,^ ^81,^ ^82^ eight were conducted in countries with an intermediate TB burden;^57,^ ^71,^ ^73–76,^ ^83,^ ^84^ and seven were conducted in countries with a low TB burden,^55,^ ^61,^ ^63,^ ^66,^ ^69,^ ^78,^ ^80^ including three in the United States.^55,^ ^69,^ ^80^

Five studies included persons who had either not started TB treatment or had started only in the 7 days prior to TST testing,^55,^ ^63,^ ^66,^ ^73,^ ^78^ while three studies included those tested between 8 and 14 days after starting treatment^77,^ ^79,^ ^80^ and two studies included those tested between 15 and 30 days after starting treatment.^74,^ ^82^ Five studies did not report the timing of testing with respect to starting treatment for TB disease.^53,^ ^57,^ ^61,^ ^76,^ ^81^

Three studies^58,^ ^77,^ ^79^ provided stratified results for the HIV-negative segment of their population, and 10 studies excluded subjects with HIV from the study.^57,^ ^61,^ ^63,^ ^66,^ ^71,^ ^73,^ ^75,^ ^76,^ ^82,^ ^84^ The prevalence of HIV among the four studies that allowed persons living with HIV to enroll ranged from 0.1 percent to 10.8 percent.^55,^ ^78,^ ^80,^ ^152^ Four studies did not report the HIV prevalence among the enrolled population.^69,^ ^74,^ ^81,^ ^83^ In the 15 studies that reported the BCG vaccination status of enrolled participants, the prevalence of BCG vaccination ranged from 12.4 percent to 100 percent.^53,^ ^55,^ ^57,^ ^58,^ ^61,^ ^66,^ ^73–79,^ ^83,^ ^84^

We calculated pooled estimates for sensitivity of TST by induration threshold (Table 2, Figure 3). The pooled sensitivity of TST was 0.80 (95% CI, 0.74 to 0.87; 12 studies; 1,323 participants) with a 5-mm induration threshold, 0.81 (95% CI, 0.76 to 0.87; 15 studies; 1,427 participants) with a 10-mm induration threshold, and 0.60 (95% CI, 0.46 to 0.74; 9 studies; 1,004 participants) with a 15-mm induration threshold. These pooled sensitivities were very similar to those found in the prior report, with the exception of an increase in sensitivity for the 15-mm threshold (0.52 in the prior report). Because of substantial heterogeneity, we stratified TST sensitivity results based on factors that could plausibly alter the sensitivity of TST (Appendix F Figures 1–12). These factors included having a higher proportion of persons living with HIV among test subjects and the inclusion of subjects who had already been receiving TB treatment for more than 1 or 2 weeks. We also stratified findings by country burden of TB and prevalence of BCG vaccination among test subjects, which overlap somewhat because persons living in high-TB-burden countries are more likely to have had BCG vaccination, though several studies were conducted in countries with lower TB burden where study subjects had immigrated from higher-burden countries and thus had higher rates of BCG vaccination. We were unable to identify factors that explain heterogeneity in the TST sensitivity estimates, because the stratified analyses for 5-mm threshold studies and some for the 10-mm threshold studies showed no difference among strata, and the analyses for the 15-mm threshold and some for the 10-mm threshold did not have enough studies in all the strata to meaningfully evaluate findings. Pooled estimates from these stratified analyses showed no meaningful differences from the prior report.

Figure 3 Individual Study and Pooled Estimates of Sensitivity for Various Thresholds of the TST for TB Infection

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TST=tuberculin skin test; TB=tuberculosis.

Figure 3 displays a forest plot reporting individual study and pooled estimates of sensitivity for various thresholds of the Tuberculin Skin Test (TST). The pooled estimate for the twelve included studies for the 5mm induration threshold was 0.80 (95% CI, 0.74 to 0.87). The pooled estimate for the fifteen included studies for the 10mm induration threshold was 0.81 (95% CI, 0.76 to 0.87). The pooled estimate for the nine included studies for the 15mm induration threshold was 0.60 (95% CI, 0.46 to 0.74).

Table 2 Summary of Sensitivity and Specificity Estimates for Various Thresholds of the TST and IGRA Tests

Test | Sensitivity Number of Studies (Total N) | Pooled Estimate (95% CI), I^2^ | Specificity Number of Studies (Total N) | Pooled Estimate (95% CI), I^2^
TST (5-mm threshold) | 12 (1,323) | 0.80 (0.74 to 0.87), 94.2% | 3 (5,149) | 0.95 (0.94, 0.97), NA^*^
TST (10-mm threshold) | 15 (1,427) | 0.81 (0.76 to 0.87), 91.4% | 8 (9,604) | 0.98 (0.97 to 0.99), 96.2%
TST (15-mm threshold) | 9 (1,004) | 0.60 (0.46 to 0.74), 96.5% | 10 (9,563) | 0.99 (0.98 to 0.99), 88.7%
IGRA; T-SPOT.TB | 37 (5,367) | 0.90 (0.87 to 0.92), 93.2% | 2 (1,664) | 0.95 (0.91 to 0.97)^†^; 0.97 (0.96 to 0.98)^†^
IGRA; QFT-GIT | 48 (7,055) | 0.81 (0.79 to 0.84), 89.9% | 3 (2,090) | 0.99 (0.98 to 0.99), NA^*^
IGRA; QFT-Plus | 11 (939) | 0.89 (0.84 to 0.94), 87.9% | (211) | 0.98 (0.95 to 0.99)^†^

* I^2^ was not calculated when fewer than four studies were available.

† Fewer than three studies were available, so we did not conduct a quantitative synthesis.

Abbreviations: CI=confidence interval; I^2^=the proportion of variation in study estimates due to heterogeneity; IGRA=interferon-gamma release assay; mm=millimeter; N=number of patients; NA=not applicable; QFT-GIT=QuantiFERON-TB Gold-In-Tube® test (3rd-generation test); QFT-Plus=QuantiFERON-TB Gold Plus® test (4th generation test); T-SPOT.TB=Commercial ELISPOT Assay; TST=tuberculin skin test.

##### T-SPOT. TB

Thirty-seven studies estimated the sensitivity for T-SPOT.TB.^73,^ ^74,^ ^78,^ ^81,^ ^83,^ ^85–116^ Characteristics of studies are described in Appendix D Table 2. Thresholds for positive test results varied by study: 19 studies used the threshold approved in European Medicines Agency labeling,^73,^ ^74,^ ^81,^ ^83,^ ^86–91,^ ^93,^ ^96–98,^ ^102,^ ^104,^ ^107,^ ^110,^ ^113^ 10 studies employed the threshold approved in FDA labeling,^85,92,94,^ ^95,^ ^103,^ ^105,^ ^106,^ ^108,^ ^114,^ ^115^ and eight studies did not report which threshold was used.^78,^ ^99–101,^ ^109,^ ^111,^ ^112,^ ^116^ With regard to baseline TB prevalence within study settings, 12 studies included participants from countries with high TB burden,^81,^ ^99–101,^ ^104,^ ^107–111,^ ^113,^ ^116^ while 16 studies were conducted in countries with an intermediate TB burden.^73,^ ^74,^ ^83,^ ^85,^ ^89,^ ^90,^ ^92,^ ^95^-^98,^ ^102,^ ^105,^ ^106,^ ^112,^ ^115^ Seven studies included participants from countries with low TB burden,^78,^ ^86–88,^ ^91,^ ^103,^ ^114^ and two studies were conducted in multiple countries that were a mix of low and intermediate TB burden.^93,^ ^94^ Only one study was conducted in the United States.^94^ Most studies provided information on the timing of tests relative to the initiation of TB treatment among study participants: 16 studies tested prior to or no more than within 7 days of starting TB treatment, ^73,^ ^78,^ ^81,^ ^83,^ ^87,^ ^94,^ ^96,^ ^97,^ ^100,^ ^102,^ ^103,^ ^108^-^111,^ ^114^ six studies tested between 8 and 14 days of initiating TB treatment,^88,^ ^89,^ ^93,^ ^105,^ ^106,^ ^115^ and two studies tested within 15 to 30 days of treatment initiation.^74,^ ^107^ 13 studies did not provide any data regarding timing of testing with respect to TB treatment initiation.^85,^ ^86,^ ^90–92,^ ^95,^ ^98,^ ^99,^ ^101,^ ^104,^ ^112,^ ^113,^ ^116^ HIV prevalence in the enrolled study population was reported in 30 of 37 studies. Among the 14 studies that allowed enrollment of persons living with HIV, the prevalence of HIV ranged from 1.2 percent to 8 percent.^78,^ ^85,^ ^91–95,^ ^102,^ ^103,^ ^105,^ ^110,^ ^112,^ ^114,^ ^116^ Sixteen studies reported no enrolled persons with HIV,^73,^ ^87^-^90,^ ^97–99,^ ^104,^ ^106–109,^ ^111,^ ^113,^ ^115^ and the prevalence of HIV was not reported in the remainder of studies. Of the 14 studies reporting the prevalence of BCG vaccination within study populations, the prevalence ranged from 58 to 100 percent.^73,^ ^74,^ ^78,^ ^83,^ ^87,^ ^94,^ ^96,^ ^97,^ ^99,^ ^100,^ ^103,^ ^108,^ ^110,^ ^114^

The pooled sensitivity for T-SPOT.TB was 0.90 (95% CI, 0.87 to 0.92; 37 studies; 5,367 participants; I^2^=93.2%), Table 2, Figure 4). Although there was slightly lower sensitivity reported for studies using the FDA threshold for a positive test (0.86 [95% CI, 0.81 to 0.92]; I^2^=87.4%) as compared with the European threshold (0.92 [95% CI, 0.89 to 0.95]; I^2^=86.7%), we found no statistically significant or likely clinically meaningful differences in estimates based on test thresholds (Appendix F Figure 13). Because we found substantial heterogeneity overall, we conducted stratified analyses based on factors that could plausibly alter the sensitivity (Appendix F Figures 14–17). Compared with the last report, sensitivity estimates for countries with low TB burden were lower (0.89 compared with 0.98 in the prior report), but we observed no meaningful differences in sensitivity among low-, intermediate-, or high-TB-burden strata. We found no meaningful differences in sensitivity estimates when stratified by HIV prevalence, BCG vaccination prevalence, or timing of testing with respect to treatment, but these analyses were limited by few studies in some strata and a large number of studies not reporting these characteristics of interest. T-SPOT.TB tests returning borderline results ranged from 0 percent^73,^ ^81,^ ^83,^ ^86,^ ^89,^ ^95,^ ^98–101,^ ^104,^ ^105,^ ^108,^ ^109,^ ^111–113^ to 6.7 percent^90^ among those studies that explicitly reported borderline results. The rest of the studies either did not have any persons with borderline results or excluded such persons from the analysis.

Figure 4 Individual Study and Pooled Estimates of Sensitivity for the T-SPOT.TB Test for TB Infection

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; Int=Intermediate; N=number; NR=not reported; TB=tuberculosis.

Figure 4 displays a forest plot reporting individual study and pooled estimates of sensitivity for various thresholds of the T-SPOT.TB Test. The pooled estimate for the thirty-seven included studies was 0.90 (95% CI, 0.87 to 0.92).

##### QFT-GIT

QFT-GIT sensitivity was reported in 48 studies.^58,^ ^60,^ ^66,^ ^71,^ ^76–79,^ ^85,^ ^89,^ ^93,^ ^98,^ ^100,^ ^102,^ ^103,^ ^105,^ ^106,^ ^114,^ ^115,^ ^117–121,^ ^124,^ ^126–139,^ ^141–148,^ ^153^ Characteristics of studies are described in Appendix D Table 2. Thirteen studies were conducted among persons in countries with high TB burden,^58,^ ^77,^ ^79,^ ^100,^ ^126,^ ^130,^ ^133,^ ^135,^ ^136,^ ^141,^ ^145,^ ^147,^ ^153^ 25 studies reported on persons from countries with an intermediate TB burden,^60,^ ^71,^ ^76,^ ^85,^ ^89,^ ^98,^ ^102,^ ^105,^ ^106,^ ^115,^ ^119^-^121,^ ^124,^ ^127–129,^ ^131,^ ^132,^ ^134,^ ^137,^ ^139,^ ^143,^ ^146,^ ^148^ and seven studies reported on persons from countries with low TB burden.^66,^ ^78,^ ^103,^ ^114,^ ^118,^ ^142,^ ^144^ Three studies were conducted among persons that included a mix of low- and intermediate-TB-burden countries,^93,^ ^117,^ ^138^ including one study that reported data from the United States.^117^ Twenty-four studies administered tests to participants prior to or no more than within 7 days of initiating TB treatment,^58,^ ^60,^ ^66,^ ^76,^ ^78,^ ^100,^ ^102,^ ^103,^ ^114,^ ^120,^ ^124,^ ^126,^ ^129,^ ^130,^ ^133–135,^ ^139,^ ^141,^ ^143,^ ^144,^ ^146–148^ 10 studies tested no more than between 8 and 14 days of treatment initiation,^85,^ ^86,^ ^90–92,^ ^95,^ ^98,^ ^99,^ ^101,^ ^104,^ ^112,^ ^113,^ ^115^ and 14 studies did not report any data regarding timing of testing with respect to TB treatment.^71,^ ^85,^ ^98,^ ^118,^ ^119,^ ^127,^ ^128,^ ^131,^ ^132,^ ^136–138,^ ^145,^ ^153^ HIV prevalence was reported in 37 studies. Among the 12 studies that allowed enrollment of persons living with HIV, the prevalence of HIV ranged from 1 percent to 15.4 percent.^78,^ ^85,^ ^93,^ ^102,^ ^103,^ ^105,^ ^114,^ ^117,^ ^134,^ ^136,^ ^139,^ ^141^ Twenty-four studies did not enroll any persons living with HIV;^58,^ ^60,^ ^66,^ ^71,^ ^76,^ ^77,^ ^79,^ ^89,^ ^98,^ ^106,^ ^115,^ ^120,^ ^126,^ ^127,^ ^129,^ ^130,^ ^132,^ ^133,^ ^135,^ ^143–147^ the remainder of studies did not report HIV prevalence among the enrolled population. Of the 22 studies reporting the prevalence of BCG vaccination among study populations, 10 studies reported a prevalence less than 50 percent,^66,^ ^77,^ ^127,^ ^128,^ ^133–136,^ ^141,^ ^148^ and 12 studies reported a prevalence above 50 percent.^58,^ ^76,^ ^78,^ ^79,^ ^100,^ ^103,^ ^114,^ ^124,^ ^126,^ ^130,^ ^131,^ ^153^

The pooled sensitivity for QFT-GIT was 0.81 (95% CI, 0.79 to 0.84; 48 studies; 7,055 participants; I^2^=89.9%; Table 2, Figure 5). In stratified analyses, we found no meaningful differences in sensitivity estimates by country TB burden, HIV or BCG vaccination prevalence of the enrolled population, or timing of testing with respect to Appendix F Figures 18–21). Similar to studies reporting on T-SPOT.TB tests, stratified analyses were limited by a large number of studies that did not report information on key study characteristics. QFT-GIT assays returning indeterminate results among those with confirmed TB ranged from 0 percent^58,^ ^66,^ ^76,^ ^105,^ ^106,^ ^118,^ ^119,^ ^133,^ ^136,^ ^138,^ ^143–145,^ ^147^ to 19.4 percent^135^ among studies explicitly reporting indeterminate results. The rest of the studies either did not have any persons with indeterminate results or excluded such persons from the analysis.

Figure 5 Individual Study and Pooled Estimates of Sensitivity for the QFT-GIT Test for TB Infection

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immimodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis.

Figure 5 displays a forest plot reporting individual study and pooled estimates of sensitivity for various thresholds of QuantiFERON-TB® Gold In-Tube Test. The pooled estimate for the forty-eight included studies was 0.81 (95% CI, 0.79 to 0.84).

##### QFT-Gold Plus

The sensitivity of QFT-Gold Plus was reported in 11 studies.^105,^ ^106,^ ^115,^ ^117–121,^ ^123–125^ Characteristics of studies are described in Appendix D Table 2. One study^123^ was conducted among persons in a country with high TB burden, and eight studies^105,^ ^106,^ ^115,^ ^119^-^121,^ ^124,^ ^125^ were conducted among persons from countries with an intermediate TB burden. One study was conducted among persons in a low-TB-burden country.^118^ One study was conducted among persons from a mix of low- and intermediate-TB-burden countries, including the United States.^117^ In three studies, testing occurred prior to or no more than within 7 days of initiating TB treatment.^120,^ ^123,^ ^124^ In five studies,^105,^ ^106,^ ^115,^ ^117,^ ^121^ testing was performed no more than 8 to 14 days after TB treatment initiation. In one study, testing was performed either before treatment or no more than 30 days after TB treatment initiation,^125^ and in two studies,^118,^ ^119^ the timing of testing relative to the initiation of TB treatment was not reported. Among the three studies that allowed enrollment of persons living with HIV, the HIV prevalence ranged from 1.3 percent to 20 percent.^105,^ ^117,^ ^123^ Three studies^106,^ ^115,^ ^120^ did not enroll any persons living with HIV, and the prevalence of HIV was not reported in the remainder of studies. No studies reported BCG vaccination status among study participants.

The pooled sensitivity for QFT-Gold Plus was 0.89 (95% CI, 0.84 to 0.94; 11 studies; 939 participants; I^2^=87.9%; Table 2, Figure 6). Stratified analyses by study characteristics previously described were limited by too few studies in each stratum for most analyses (Appendix F Figures 22–24). No studies using QFT-Gold Plus reported on indeterminate results.

Figure 6 Individual Study and Pooled Estimates of Sensitivity for the QFT-Gold Plus Test for TB Infection

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis.

Figure 6 displays a forest plot reporting individual study and pooled estimates of sensitivity for various thresholds of QuantiFERON-TB® Gold Plus Test. The pooled estimate for the eleven included studies was 0.89 (95% CI, 0.84 to 0.94).

#### Specificity of Screening Tests

##### TST

Twelve studies estimated specificity of TST using various thresholds for a positive test;^54,^ ^56,^ ^59,^ ^61–65,^ ^67,^ ^68,^ ^70,^ ^72^ study characteristics are described in Appendix D Table 2. Three studies reported specificity using a 5-mm induration threshold,^56,^ ^61,^ ^70^ eight studies reported specificity using a 10-mm induration threshold,^54,^ ^56,^ ^61,^ ^63,^ ^67,^ ^68,^ ^70,^ ^72^ and 10 studies reported specificity using a 15-mm induration threshold.^54,^ ^56,^ ^59,^ ^61,^ ^62,^ ^64,^ ^65,^ ^67,^ ^68,^ ^70^ All studies were conducted in countries with a low TB burden, including nine in the United States.^54,^ ^56,^ ^59,^ ^62,^ ^64,^ ^65,^ ^67,^ ^68,^ ^72^ In four studies, the HIV prevalence of the specificity population was reported to be 0 percent,^62,^ ^63,^ ^65,^ ^72^ and the remaining eight studies did not report HIV prevalence. In six studies, the prevalence of BCG vaccination was 0 percent;^59,^ ^61–63,^ ^67,^ ^68^ in three studies, the BCG vaccination prevalence ranged from 2 percent to 4 percent;^54,^ ^56,^ ^72^ in one study where specificity subjects were Greek army recruits, all had been vaccinated with BCG;^70^ and two studies did not report BCG vaccination prevalence.^64,^ ^65^

The pooled estimate for specificity of TST was 0.95 (95% CI, 0.94 to 0.97; 3 studies; 5,149 participants) at the 5-mm threshold, 0.98 (95% CI, 0.97 to 0.99; 8 studies; 9,604 participants) at the 10-mm threshold, and 0.99 (95% CI, 0.98 to 0.99; 10 studies; 9,563 participants) at the 15-mm threshold (Table 2, Figure 7). These estimates were essentially unchanged from the prior report.

Figure 7 Individual Study and Pooled Estimates of Specificity for Various Thresholds of the TST and IGRA Tests for TB Infection

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; QFT-GIT=QuantiFERON-TB Gold-In-Tube^®^ test (3rd-generation test); QFT-Plus=QuantiFERON-TB Gold Plus^®^ test (4th generation test); T-SPOT.TB=Commercial ELISpot Assay; TST=tuberculin skin test.

Figure 7 displays a forest plot reporting individual study and pooled estimates of specificity for various thresholds of the Tuberculin Skin Test and Interferon-Gamma Release Assay Tests. The pooled estimate for the three included studies for the 5mm induration threshold for the TST was 0.95 (95% CI, 0.94 to 0.97). The pooled estimate for the eight included studies for the 10mm induration threshold for the TST was 0.98 (95% CI, 0.97 to 0.99). The pooled estimate for the ten included studies for the 15mm induration threshold for the TST was 0.99 (95% CI, 0.98 to 0.99). The pooled estimate for the two included studies for the T-SPOT.TB test was 0.97 (95% CI, 0.96 to 0.98). The pooled estimate for the three included studies for the QuantiFERON-TB® Gold In-Tube Test was 0.99 (95% CI, 0.98 to 0.99). The estimate for the one included study for the QuantiFERON-TB® Gold Plus Test was 0.98 (95% CI, 0.95 to 0.99).

##### IGRA Tests

Four studies reported specificity data for IGRA tests; all were conducted in the United States. Two studies reported on T-SPOT.TB,^72,^ ^154^ two studies reported on QFT-GIT,^54,^ ^140^ and one study reported on QFT-Gold Plus.^122^ Characteristics of these studies are described in Appendix D Table 4. BCG vaccination prevalence among three studies ranged from 0 percent to 3.5 percent and was not reported in the fourth study.^140^ The prevalence for HIV was 0 percent in one study^72^ and not reported in the other three studies.

The pooled estimates for specificity are summarized in Table 2 and Figure 7. Analyses were limited by the small number of available studies reporting IGRA specificity data, which precluded quantitative analyses for some tests. The two studies reporting on T-SPOT.TB reported specificities of 0.95 (95% CI, 0.91 to 0.97)^72^ and 0.97 (95% CI, 0.96 to 0.98).^54^ The pooled estimate for specificity of QFT-GIT was 0.99 (95% CI, 0.98 to 0.99; 3 studies; 2,090 participants). The specificity estimates of the lone study reporting specificity of QFT-Gold Plus was 0.98 (95% CI, 0.95 to 0.99).^122^ The number of IGRA tests returning borderline or indeterminate results ranged 0 to 4.5 percent for studies reporting this information.

#### Reliability of Screening Tests

We did not identify any new studies reporting on the reliability of various screening tests for this update. The prior review identified nine studies of good or fair quality assessing the reliability of at least one of the included screening tests.^54,^ ^67,^ ^68,^ ^74,^ ^149–151,^ ^155,^ ^156^

##### Study Characteristics

Study characteristics are shown in Appendix D Table 5. Three studies assessed the interrater reliability of TST.^54,^ ^67,^ ^68^ Two studies assessed the interrater reliability of T-SPOT.TB,^74,^ ^155^ one assessed the interrater reliability of QFT-GIT,^150^ and one assessed the interlaboratory reliability of QFT-GIT.^149^ Two studies assessed the test-retest reliability of T-SPOT.TB and QFT-GIT 1 to 4 weeks after an initial test.^151,^ ^156,^ ^157^ Eight studies were conducted in countries with a low TB burden (7 in the United States and 1 in the Netherlands), one study was conducted in a country with an intermediate TB burden^74^ (Turkey), and one study enrolled Nepalese military recruits who had left Nepal and recently entered the United Kingdom.^156^ Two studies reported the percentage of the study population that had HIV; less than 1 percent in both studies were HIV positive.^151,^ ^156^ In two studies, the majority of participants were BCG vaccinated.^74,^ ^156^

##### Results

Interrater reliability. Three studies (N=1,826,^54^ N=1,189,^67^ and N=127^68^) measured the interrater reliability of TST results by reporting the kappa statistic for agreement by TST reaction size; results ranged from 0.55 to 0.79, indicating moderate to substantial agreement between two observers. One study (N=91) found substantial agreement between two observers for manually reading T-SPOT.TB results (kappa=0.92) and manual vs. automatic enzyme-linked immunosorbent spot (ELISpot) readings (kappa=0.73).^74^ One study (N=313) evaluated agreement among six individual ELISpot readers; all kappa values were greater than 0.6.^155^ One study (N=146) assessed interrater reliability for manual vs. automated enzyme-linked immunosorbent assay readings for QFT-GIT; each study participant had two blood draws, and each sample was sent for both automated and manual readings.^150^ Across all samples, 88.6 percent of results were concordant and 11.0 percent were discordant; the discordance rates for specific comparisons were 4.8 percent (between two different automated readings, kappa=0.85), 6.9 percent (between two different manual readings, kappa=0.80), and 3.4 percent (manual compared with automated readings, kappa ranged from 0.73 to 0.90 across comparisons).^150^

Interlaboratory reliability. One study (N=91) evaluated the interlaboratory reliability of QFT-GIT by sending three blood specimens from each participant to three different laboratories noted to have extensive experience and proficiency with IGRA testing and interpretation.^149^ Across all three laboratories, 7.7 percent of participants had discordant results (none had indeterminate results); kappas of pairwise laboratory sample comparisons ranged from 0.87 to 0.93.^149^

Reproducibility and test-retest reliability. One study (N=130) assessed the reliability of IGRA results by processing two blood samples from each study participant (using the same laboratory and same type of test interpretation); 5.8 percent of participants had discordant results for QFT-GIT and 6.5 percent had discordant results for T-SPOT.TB.^151^ Two studies measured the test-retest reliability of QFT-GIT. One study enrolled U.S. healthcare workers,^151^ and one enrolled a population from a country with a high TB burden (Nepal).^156^, ^157^ In the study (N=130) enrolling healthcare workers, 8 percent of baseline T-SPOT.TB negative tests changed to positive and 53 percent of positive tests changed to negative on repeat testing at 2 weeks; for QFT-GIT, 8 percent of negative tests changed to positive and 33 percent of positive tests changed to negative.^151^ Finally, in the study enrolling a Nepalese population, the kappa statistic for agreement between initial QFT-GIT test and retest at 1 week was 0.48 (95% CI, 0.26 to 0.70) and was 0.66 (95% CI, 0.50 to 0.83) for T-SPOT.TB.^156^

### KQ 2b What Are the Accuracy and Reliability of Sequential Screening Strategies That Use TST and IGRA in Asymptomatic Adults Who Are at Increased Risk for Developing Active TB Disease, Including Among Specific Populations of Interest?

We found no eligible studies that addressed this question.

### KQ 3 What Are the Benefits of Treatment for LTBI with CDC-Recommended Pharmacotherapy Regimens, Including Among Specific Populations of Interest?

We included five RCTs^158–162^ that assessed treatment of LTBI and met all eligibility criteria (Appendix D Table 6) and one network meta-analysis.^163^ One compared INH with placebo, two compared RIF with INH, and two compared RPT plus INH with INH alone. Two of the articles describing RCTs^160,^ ^162^ and the network meta-analysis^163^ were new in this update.

We identified four additional RCTs^164–167^ that compared INH with placebo that did not meet all eligibility criteria but were used in sensitivity analyses (Appendix D Table 7). These were included in the prior report for the USPSTF, and we did not identify new studies to add to this sensitivity analysis. For RCTs to be included in sensitivity analyses, we required that they either confirmed LTBI for subjects to be eligible (e.g., by enrolling only those who were tuberculin positive), reported data for subjects with confirmed LTBI (e.g., for the tuberculin-positive subset of subjects), or that the vast majority of subjects (>75%) were tuberculin positive. These trials met many of our eligibility criteria but used a longer duration of treatment than is currently recommended by the CDC (i.e., ≥1 year of INH), and some used lower or higher doses than currently recommended or did not require LTBI confirmation for subjects to be eligible. One of the four trials was rated poor quality for high risk of selection bias, attrition bias, confounding, and measurement bias.

The prior report on this topic and our update searches identified additional RCTs (e.g., that compared INH with placebo), which we excluded from this review. Reasons for excluding studies from this review are listed in Appendix C. Reasons for excluding studies from the prior report are listed in the Appendix of the prior report. For example, several trials focused on the use of INH among household contacts of active TB cases but did not require LTBI confirmation for study entry, some enrolled a large proportion of children, some evaluated ineligible populations (e.g., persons with silicosis), some evaluated 1 year or more of INH treatment, and some used doses not currently recommended by the CDC.^168–172^ Two other trials randomized households or villages in Greenland^173^ or Alaska^174^ for the purpose of evaluating the prophylactic use of INH. Greenland and Alaska both had a high prevalence of active TB at the time of the study. These two trials did not require LTBI confirmation for study entry. One of them evaluated an unusual isoniazid regimen (400 mg for 3 months, nothing for 3 months, then 400 mg for 3 months);^173^ the other evaluated 1 year of INH and included many children.^174^

#### INH Compared With Placebo

The International Union Against Tuberculosis (IUAT) trial was the single trial meeting all eligibility criteria that compared INH with placebo.^158^ It was included in the prior review for the USPSTF. It randomized 27,830 adults from seven European countries with fibrotic pulmonary lesions but not active TB or previous antituberculosis treatment to four groups: INH 300 mg daily for 12 weeks, INH 300 mg daily for 24 weeks, INH 300 mg daily for 52 weeks, or placebo. Participants were required to have an induration of 6 mm or larger on TST. The median age was 50 years and 53 percent were men.

After 5 years of followup, 76 (1.1%), 34 (0.5%), 24 (0.3%), and 97 (1.4%) participants developed active TB in the four groups, respectively (Appendix D Table 8). The relative risks (RRs) for developing active TB compared with placebo were 0.79 (95% CI, 0.58 to 1.06), 0.35 (95% CI, 0.24 to 0.52), and 0.25 (95% CI, 0.16 to 0.39), respectively. For the 24-week CDC-recommended regimen (among the current CDC alternative regimens), we calculated a number needed to treat of 112 to prevent one case of active TB. Our sensitivity analyses using data from the 24- and 52-week groups from the IUAT trial and four additional RCTs, including a total of 36,823 participants, found an RR of 0.31 (95% CI, 0.24 to 0.41) and no statistical heterogeneity in effects between studies (I^2^=0.0%) (Appendix F Figure 25).

The IUAT trial found that persons with larger fibrotic pulmonary lesions had a greater risk of developing active TB. The incidence of active TB in the placebo group was half as great among persons with lesions smaller than 2 cm^2^ (11.6 cases per 1,000 population) than among persons with larger lesions (21.3 cases per 1,000 population).

There were no deaths due to TB in any of the INH groups in the IUAT trial; three persons died from TB in the placebo group. The RR for death due to TB was 0.14 (95% CI, 0.01 to 2.78) for each of the INH groups compared with placebo. All-cause mortality was not reported separately for the four groups. The trial reported benefit-to-risk ratios (defined as cumulative TB cases prevented/cumulative hepatitis cases incurred) of 1.2, 2.6, and 2.1 for the INH groups compared with placebo, respectively.

#### RIF Compared With INH

We included two RCTs making this comparison. The first was an open-label Phase 2 clinical trial (Menzies 2008) conducted in Canada, Brazil, and Saudi Arabia that randomized 847 participants to 4 months of RIF or 9 months of INH to compare adverse events and treatment completion.^160^ Because this RCT was focused largely on adverse events, it is described in greater detail with the results for KQ 5. We mention it briefly in this section because it reported zero deaths from TB in either group. It also reported all-cause mortality with zero deaths in the RIF group and one in the INH group.

The second article was new in this update (Menzies 2018) and was conducted by the same primary author. It was an open-label, Phase 3 clinical trial completed in Australia, Benin, Brazil, Canada, Ghana, Guinea, Indonesia, Saudi Arabia, and South Korea.^160^ It randomized 6,063 participants to 4 months of RIF (now a CDC-preferred regimen, strong recommendation) or 9 months of INH (now an alternative CDC regimen). The primary objective was to compare the rates of confirmed active TB in the two groups. Participants included were at increased risk of progression to active TB. Most had a history of close contact (70.7%) or casual contact (12.4%) with an active TB case; fewer had HIV (4.0%) or an immunosuppressive condition (3.2%).

Over 95 percent of participants randomized completed 28 months of followup. In the INH group, nine participants developed active TB compared with eight in the RIF group. This total does include patients who progressed to active TB in the Phase 2 clinical trial completed by the same authors. The RIF therapy was found to be noninferior to the INH, but not superior.

#### RPT Plus INH Compared With INH Alone

Two of the included RCTs made this comparison. The first, the PREVENT TB study (Sterling 2011^161^), was included in the prior report for the USPSTF and was an open-label, noninferiority trial conducted in the United States, Canada, Brazil, and Spain that randomized 7,731 persons age 12 years or older to directly observed once-weekly RPT (900 mg) plus INH (900 mg) for 3 months or to daily self-administered INH (300 mg) for 9 months.^161^ The primary endpoint was development of confirmed TB. Subjects were primarily from the United States and Canada (89% of those randomized) and were high-risk persons with a positive TST. Most (71%) had a close contact with a patient with culture-confirmed, active TB within the past 2 years; 25 percent were included solely because of recent conversion to TST positivity. Less than 3 percent of participants were HIV positive; the participants with HIV were not required to have a positive TST. Risk factors for TB included a history of incarceration (5.1%), history of injection drug use (3.7%), and homelessness (27.8%).

Almost 90 percent of subjects randomized completed 33 months of followup. Active TB developed in seven persons in the combination therapy group and in 15 persons in the INH-only group. The combination therapy group was found to be noninferior to the INH-only group. The trial identified 70 deaths from any cause (31 vs. 39 deaths; p=0.22).

From among the 7,731 randomized, we obtained data from the CDC for the subset of participants most directly relevant for this review: the 6,886 adults (age ≥18 years) who were HIV negative and TST or IGRA positive. The median age for this subset was 37 years, 54.2 percent were male, and 57 percent were White persons. For this subset, active TB developed in five persons in the combination therapy group and in 10 persons in the INH-only group. The combination therapy group was found to be noninferior to the INH-only group. Overall mortality was similar for the two groups (30 vs. 34 deaths, respectively; p=0.42).

The second RCT (Sun 2018), new in this update, was an open-label multicenter trial completed in Taiwan that randomized 283 participants (263 of those were included in analyses) age 12 years or older to either 3 months of once-weekly directly observed RPT plus INH or 9 months of daily directly observed INH alone.^162^ The endpoints were treatment completion and incidence of severe adverse drug reactions, so this study is discussed in more detail in the KQ 5 results. However, it did report zero deaths from either TB or all-cause mortality in either group.

#### Previously Published Network Meta-Analysis

The network meta-analysis (53 included studies) used a mixed-treatment comparison methodology focused on two prespecified endpoints: prevention of active TB (covered in KQ 3) and hepatotoxicity (covered in KQ 5).^163^ It found that the shorter-duration recommended regimens are efficacious for preventing active TB (e.g., rifampicin for 3 to 4 months, RPT plus INH combination, INH for 6 months) and may have fewer adverse effects and higher completion rates.^163^ This analysis included studies among children; HIV-infected persons; household or close contacts of persons with active TB without confirmed LTBI; and persons with renal transplant, silicosis, or rheumatoid arthritis who were taking immunosuppressive biologic medication, which are all populations excluded from the present review. The network metaanalysis also included treatment regimens not eligible for our review. For prevention of active TB, it reported that multiple regimens were efficacious compared with placebo or no treatment, including INH regimens of 6 months (odds ratio [OR], 0.65 [95% credible interval {CrI}, 0.50 to 0.83] vs. placebo) or longer, rifampicin-INH regimens of 3 to 4 months (OR, 0.53 [CrI, 0.36 to 0.78] vs. placebo), and weekly RPT-INH regimens (OR, 0.36 [CrI, 0.18 to 0.73] vs. no treatment). The network meta-analysis also noted that it found no conclusive evidence that HIV status altered treatment efficacy.

### KQ 4 Are Harms Associated With Screening for LTBI, Including Among Specific Populations of Interest?

KQ 4a Do These Harms Differ by Screening Method or Strategy?
KQ 4b Do These Harms Differ by Population?

We found no eligible studies that addressed this question.

### KQ 5 What Are the Harms Associated With Treatment of LTBI With CDC-Recommended Pharmacotherapy Regimens, Including Among Specific Populations of Interest?

We included nine RCTs (described in 11 articles) and one network meta-analysis assessing harms associated with the treatment of LTBI that met eligibility criteria (Appendix D Tables 6 and 9).^158–163,^ ^175–180^ Among the RCTs, one compared INH with placebo,^158^ four compared RIF with INH (although participants of the Menzies [2008] Phase 2 trial were included in the Menzies [2018] Phase 3 trial),^159,^ ^160,^ ^176,^ ^177^ two compared RPT plus INH with INH alone,^162,^ ^178^ one compared RIF plus INH to RPT plus INH,^179^ and one compared weekly RPT plus INH with twice-weekly RPT plus INH.^180^ Four of the RCTs (described in 6 articles, including 2 post hoc analyses of previously included trials) and the network meta-analysis were new in this update.^160,^ ^160,^ ^162,^ ^175,^ ^178–181^

We identified five additional RCTs that evaluated harms associated with treatment of LTBI that did not meet all eligibility criteria but were used in sensitivity analyses. The criteria for RCTs to be included in sensitivity analyses for KQ 5 were the same as those described for KQ 3. The five additional trials met many of our eligibility criteria, but four of the five trials used a longer duration of treatment than is currently recommended by the CDC (i.e., ≥1 year of INH), one used a shorter duration than is currently recommended by the CDC (3 months of INH), and some used a lower dose than currently recommended or did not require LTBI confirmation for subjects to be eligible. We rated two of these trials as fair quality and the other three as poor quality.

From this body of evidence, we were able to quantitatively synthesize harms related to hepatotoxicity and discontinuation of medication due to adverse events. Studies also reported a variety of gastrointestinal (GI) adverse events, but we were unable to quantitatively synthesize these outcomes because of heterogeneity in how they were measured across included studies. For example, GI adverse events were reported as a single combined value per treatment arm in one study, as rates of treatment discontinuation due to GI events in another study, and by separate types of GI events (i.e., nausea, clay-colored stools, or anorexia) with no summary rate in another study.

#### INH Compared With Placebo

The IUAT trial was the single trial meeting all eligibility criteria that compared INH with placebo.^158,^ ^182^ Study characteristics for this trial were previously described (see KQ 3 results); the quality of this study was rated as fair for KQ 5 outcomes because harm outcomes were not prespecified and ascertainment techniques were not adequately described, except for the hepatotoxicity outcomes.

##### Hepatotoxicity

The IUAT trial reported rates of hepatotoxicity development (Appendix D Table 9).^158^ The RRs for developing hepatotoxicity associated with INH compared with placebo were 3.45 (95% CI, 1.49 to 7.99) for 12 weeks of treatment, 4.59 (95% CI, 2.03 to 10.39) for 24 weeks of treatment, and 6.21 (95% CI, 2.79 to 13.79) for 52 weeks of treatment (Appendix F Figure 26). For the study arms comparing the 24-week CDC-approved regimen with placebo (N=13,955), we calculated that one case of hepatotoxicity would result from treating 279 persons with INH (i.e., a number needed to harm [NNH] of 279). Our sensitivity analyses using data from the IUAT trial (3 treatment arms combined) and three additional RCTs, including a total of 35,161 participants, found an RR of 5.04 (95% CI, 2.50 to 10.15) and no statistical heterogeneity among studies (I^2^=0.0%; p=0.630) (Appendix F Figure 27).^183–185^

The one RCT included in the main analysis (i.e., the IUAT trial) comparing INH with placebo for treatment of LTBI reported mortality rates from hepatotoxicity of 0.03 percent, 0.0 percent, and 0.01 percent for the 12-, 24-, and 52-week INH treatment groups, respectively. This study had zero deaths from hepatotoxicity among placebo-treated patients. The authors reported that the mortality rate from hepatitis associated with INH was 0.14 deaths per 1,000 persons receiving INH, for a calculated RR of 2.35 (95% CI, 0.12 to 45.46; NNH, 6,947).

##### Treatment Discontinuation Because of Adverse Events

Rates of treatment discontinuation because of adverse events in the IUAT trial were presented only for all three INH treatment groups combined. A total of 345 patients (1.8%) receiving INH discontinued treatment because of adverse events compared with 84 patients (1.2%) receiving placebo. The RR of discontinuation due to adverse events among patients treated with INH vs. placebo was 1.50 (95% CI, 1.18 to 1.89; 1 RCT; N=27,830; NNH, 167). Our sensitivity analysis using data from the IUAT trial and three additional RCTs, including a total of 55,398 participants, found an RR of 1.58 (95% CI, 1.00 to 2.49) (Appendix F Figure 28).^164,^ ^166,^ ^185^

##### GI Adverse Events

The IUAT trial reported that 1.2 percent of INH patients and 0.9 percent of placebo patients discontinued treatment due to GI distress (RR, 1.33 [95% CI, 1.01 to 1.75]).^182^ Among studies included in sensitivity analyses, one reported GI adverse events (0.7% in INH group vs. 0.3% in placebo group) and one reported nausea (3.3% in INH group vs. 1.7% in placebo group), clay-colored stools (10.0% in INH group vs. 5.0% in placebo group), and anorexia (8.3% in both INH and placebo groups).^164,^ ^185^

##### Other Harms

No other adverse events were reported in the IUAT trial. A variety of other adverse events were reported in the RCTs included in sensitivity analyses. Rates of other adverse events were generally similar among INH and placebo patients (Appendix D Table 9). One study reported an increased risk for rash (0.9% of INH patients and 0.3% of placebo patients; RR, 2.7 [95% CI, 1.27 to 5.73]).^165,^ ^167^

#### INH Compared With RIF

We included four open-label RCTs that compared RIF with INH (Appendix D Table 6).^159,^ ^160,^ ^176,^ ^177^ Additionally, a post hoc safety analysis of two of these RCTs was included. ^175^ One trial conducted in Canada (N=116) compared 4 months of RIF (10 mg/kg of body weight, up to 600 mg/day) with 9 months of INH (5 mg/kg, up to 300 mg/day).^176^ A later Phase 2 trial by the same authors conducted in Canada, Brazil, and Saudi Arabia randomized 847 participants to the same two treatments.^159^ A third study (a Phase 3 trial, new in this update) by the same authors conducted in Australia, Benin, Brazil, Canada, Ghana, Guinea, Indonesia, Saudi Arabia, and South Korea (N=6,063) compared the same treatments.^160^ In all three studies, participants were age 18 years or older with documented LTBI. Adverse event data for the second and third studies were reported together (i.e., the Phase 3 trial included some data from the Phase 2 trial). Over half of the participants in the first two studies were male, but the third study included a greater proportion of females. The fourth trial randomized inmates (N=364) in the San Francisco City and County Jail diagnosed with LTBI at jail entry to 9 months of INH (900 mg twice per week) or 4 months of RIF (600 mg/day). Ninety-three percent of study participants were male.^177^

##### Hepatotoxicity

All four RCTs presented hepatotoxicity data; one trial combined its data with the data from an earlier study by the same authors. Rates of hepatotoxicity in these RCTs among patients receiving INH were 5.2 percent,^176^ 1.9 percent,^160^ and 11.4 percent.^177^ Rates of hepatotoxicity among RIF-treated patients were 0.0 percent, 0.3 percent, and 4.4 percent, respectively. Our meta-analysis of three RCTs (total N=7,339) found a greater risk of hepatotoxicity for patients treated with INH than for those treated with RIF (RR, 4.22 [95% CI, 2.21, 8.06]; I^2^=28.7%) (Appendix F Figure 29). All studies reported zero deaths from hepatotoxicity.

##### Treatment Discontinuation Because of Adverse Events

Rates of discontinuation because of adverse events were reported in all four included RCTs, but one trial combined its data with the data from an earlier Phase 2 study by the same author. Rates were 13.8 percent (INH) and 3.4 percent (RIF),^176^ 2.3 percent (INH) and 0.9 percent (RIF),^160^ and 0.0 percent (INH) and 1.1 percent (RIF).^177^ Our meta-analysis found no statistically significant difference between treatments (RR, 2.25 [95% CI, 0.90 to 5.59]; I^2^=35.2%; N=7,339) (Appendix F Figure 30).

##### GI Adverse Events

Among the four included RCTs, one reported GI adverse events in 3.4 percent of the study population, not separated by treatment arm.^176^ One, which includes the data from two of these RCTs, reported GI intolerance of 0.03 percent among patients treated with INH and 0.09 percent among those treated with RIF (calculated RR: 0.34 [95% CI, 0.03, 3.23]).^160^ The third study reported more GI adverse events among patients treated with INH than with RIF (calculated RR: 1.16 [95% CI, 0.62 to 2.19]).^177^

##### Other Harms

The four RCTs in the main analysis reported on various other harms, including hematologic, drug interactions, and rash. The post hoc safety analysis reviewing two of these RCTs found a total of 199 adverse events due to the study drugs, and 68 (34.2%) of these were in the RIF arms and 131 (65.8%) in the INH arms.^175^ In the RIF arm, 1.5 percent of participants experienced a Grade 1–2 rash or any Grade 3–5 adverse events, compared with 2.7 percent of participants in the INH arm.

#### RPT Plus INH Compared With INH Alone

Two included RCTs made this comparison, as well as one companion trial that provided a more detailed review of systemic drug reactions (SDRs).^161,^ ^162,^ ^178^ The PREVENT TB study (included in the 2016 review for USPSTF) was an open-label, noninferiority trial conducted in the United States, Canada, Brazil, and Spain that randomized 7,731 persons age 12 years or older to directly observed once-weekly RPT at 900 mg plus INH at 900 mg for 3 months or to daily self-administered INH at 300 mg for 9 months.^161^ More details regarding this study are presented in the results section on benefits of treatment (KQ 3). A post hoc analysis was later completed to examine the participants with SDRs.^178^ One study site was excluded from the SDR analysis because of discrepancies regarding receipt of study drug and DOT.

The second RCT was an open-label multicenter trial completed in Taiwan that randomized 263 participants age 12 years or older to either 3 months of weekly directly observed RPT 15 mg/kg plus INH 15 mg/kg (3HP) or 9 months of daily directly observed INH 5 mg/kg alone (9H).^162^ All subjects had close contact with an active TB case and had a positive TST within 1 month after exposure. The mean age was 32 years and 58 percent of the subjects were male. Participants who completed treatment were followed for an additional 2 years. The endpoints evaluated were treatment completion and incidence of severe adverse drug reactions. Compared with the 9H regimen, the 3HP regimen had a higher completion rate with lower hepatotoxicity rates but higher rates of SDRs.

##### Hepatotoxicity

Both studies reported hepatotoxicity data, but one reported these data based on elevation of aspartate aminotransferase (AST) and alanine aminotransferase (ALT), while the other reported hepatotoxicity as a severity grade. Rates of Grade 3 and 4 hepatotoxicity in the PREVENT TB study were 4.9 percent and 1.0 percent in the RPT plus INH arm and 5.5 percent and 1.1 percent in the INH-only arm.^161^ The RR for Grade 3 or 4 hepatotoxicity was 0.90 (95% CI, 0.75 to 1.08). The post hoc analysis completed by the same authors found a total of 114 cases of hepatotoxicity attributable to the study drug in the PREVENT TB study, with 17 of these in the RPT plus INH arm (0.43% of those who received 3HP) and 97 in the INH arm (2.70% of those who received 9H) (RR, 0.16 [95% CI, 0.10 to 0.28]).^178^

The trial conducted in Taiwan reported elevations of AST and ALT greater than 3 times the upper limit of normal in 4.5 percent of the RPT plus INH group and in 9.9 percent in the INH-alone group (RR, 0.46 [95% CI, 0.18 to 1.17]) and reported clinically relevant hepatotoxicity in 1.5 percent vs. 5.3 percent (RR, 0.28 [95% CI, 0.06 to 1.34]).

The trial conducted in Taiwan reported zero deaths from hepatotoxicity in either group.

##### Treatment Discontinuation Because of Adverse Events

Both studies reported on discontinuation due to adverse events. Rates of discontinuation because of adverse events were higher in the RPT plus INH arms in both studies (5.2% and 9.1% in PREVENT TB and the trial conducted in Taiwan, respectively) than in the INH-only arms (4.1% and 5.3%) (RR, 1.28 [95% CI, 1.03 to 1.59] in PREVENT TB and RR, 1.70 [95% CI, 0.69 to 4.19] in the trial conducted in Taiwan).

##### GI Adverse Events

The trial conducted in Taiwan reported on GI adverse events. Overall, 21.2 percent of subjects in the RPT plus INH arm experienced GI adverse events compared with 12.2 percent of the subjects in the INH-alone group (RR, 1.74 [95% CI, 0.99 to 3.05]). Specific side effects included abdominal pain (3.0% vs. 2.3%; RR, 1.32 [95% CI, 0.30 to 5.80]), diarrhea (1.5% vs. 2.3%; RR, 0.66 [95% CI, 0.11 to 3.90]), nausea (9.1% vs. 6.9%; RR, 1.32 [95% CI, 0.58 to 3.03]), and vomiting (7.6% vs. 0.8%; RR, 9.92 [95% CI, 1.29 to 76.4]).

##### Other Harms

The studies evaluated various other harms, including possible hypersensitivity, SDR, and flu-like symptoms. Possible hypersensitivity was reported in 4.1 percent of INH plus RPT patients and 0.5 percent of INH-only patients in the PREVENT TB study.^5^ The RR of possible hypersensitivity for RPT plus INH vs. INH-only patients was 8.04 (95% CI, 4.88 to 13.26).

Among the 7,552 participants who received at least one dose of the study drugs in the PREVENT TB study, 153 had a clinically significant SDR attributed to study drugs. The post hoc analysis of PREVENT TB reviewed the 153 SDRs and found that 138 were in the RPT plus INH arm vs. 15 in the INH-only arm (RR, 8.7 [95% CI, 5.1 to 14.7]). Of the 138, presentations of symptoms included flu-like (n=87, 63%), cutaneous (n=23, 17%), GI (n=7, 5%), respiratory (n=5, 4%), and not defined (n=16, 12%). Thirteen of these events were severe with four resulting in hospitalization. In the INH-only arm, SDRs included cutaneous (n=9, 60%), flu-like (n=2, 13%), GI (n=1, 7%), and not defined (n=3, 20%). One of these events was severe and resulted in hospitalization. None of the participants who developed an SDR completed study treatment.

The trial conducted in Taiwan reported SDRs in 3.8 percent of the RPT plus INH participants and 0 percent of the INH-only participants (RR, 10.9 [95% CI, 0.6 to 195.5]). It also reported flu-like symptoms in 40.1 percent of the RPT plus INH participants and 16.8 percent of the INH-only group. Adverse drug reactions aside from hepatotoxicity occurred in 49.2 percent of the RPT plus INH group and 25.2 percent of the INH-only group.

#### RIF Plus INH Compared With RPT Plus INH

The single study, the HALT LTBI pilot study, that made this comparison was an open-label pilot RCT completed at two TB clinics in London that randomized 52 participants ages 16 to 65 years with LTBI to self-administered RIF plus INH daily for 90 days or RPT plus INH weekly for 12 weeks.^179^ The mean age of subjects within these groups was 32.5 years and 38.2 years, respectively, and 50 percent were male. Participants were followed for a total of 16 weeks to evaluate the primary outcome of treatment completion. The only specific harms reported by this study were related to hepatotoxicity. Elevated ALT or AST (defined as above the normal range) was reported in four participants (16%) in the RIF plus INH group and in three participants (11%) in the RPT plus INH group. There were zero deaths from hepatotoxicity in the study, but one participant (4%) in the rifampicin plus INH arm was withdrawn from the trial due to liver function tests greater than 3 times the upper limit of normal accompanied by symptoms of hepatotoxicity.

#### RPT Plus INH Compared With RPT Plus INH

The one included study making this comparison was an open-label trial conducted in China that randomized 3,738 persons ages 50 to 69 years to directly observed once-weekly INH up to 900 mg and RPT up to 900 mg for 12 weeks (the 3HP regimen), directly observed twice-weekly INH up to 600 mg and RPT up to 600 mg for 8 weeks (the 2H_2_P_2_ regimen), or to an untreated control group.^180^ Among randomized subjects, 45 percent were female. Because of the high incidence of adverse events in the study, the 3HP regimen was shortened to 8 weeks, and the 2H_2_P_2_ regimen was shortened to 6 weeks. The trial reported hepatotoxicity, discontinuation because of adverse events, GI adverse events, hypersensitivity or allergy events, and flu-like symptoms.

Hepatotoxicity, defined as AST or ALT elevated more than 3 times the upper limit of normal along with accompanying symptoms or AST or ALT elevated more than 5 times the upper limit of normal without symptoms, occurred in 13 participants (1.02%) in the 3HP group and 15 participants (1.17%) in the 2H_2_P_2_ group (p=0.704) (RR, 0.88 [95% CI, 0.42 to 1.84]). There were zero deaths from hepatotoxicity and no deaths attributed to LTBI treatment. The discontinuation rate due to adverse events was similar in the two treatment arms of the study (77 vs. 82 participants, 6.0% vs. 6.3%, RR, 0.95 [95% CI, 0.70 to 1.28]). The rate of GI adverse events was significantly higher in the 3HP group than in the 2H_2_P_2_ treatment group (110 vs. 66 participants; 8.6% vs. 5.2%, p=0.006; RR, 1.69 [95% CI, 1.26 to 2.27]) as were influenza-like symptoms (46 vs. 29 participants; 3.6% vs. 2.3%; RR, 1.60 [95% CI, 1.01 to 2.54]), whereas hypersensitivity or allergy events were less common in the 3HP group than in the 2H_2_P_2_ group (43 vs. 65 participants; 3.4% vs. 5.1%; RR, 0.67 [95% CI, 0.46 to 0.98]).

#### Meta-Analysis Comparison

The network meta-analysis used a mixed-treatment comparison methodology and focused on two prespecified endpoints: prevention of active TB (covered in KQ 3) and hepatotoxicity (covered in KQ 5). The meta-analysis found greater odds of hepatotoxicity with longer duration of therapy and regimens containing INH only (OR vs. no treatment [95% CrI]: INH 6 months, OR 1.10 [0.40, 3.17]; INH 9 months, OR 1.70 [0.35, 8.05]; INH 12 to 72 months, OR 2.72 [0.96, 7.44]) than with other regimens currently recommended by the CDC (OR vs. no treatment [95% CrI]: INH plus RPT, 0.52 [0.13, 2.15], RIF 3 to 4 months 0.14 [0.02 to 0.81], INH plus RIF 3 to 4 months, 0.72 [0.21, 2.37]).^163^ Although data on hepatotoxicity were limited, CrIs were wide (estimates were imprecise), and findings were based on relatively few events. This analysis included studies among children; HIV-infected persons; household or close contacts of persons with active TB without confirmed LTBI; and persons with renal transplant, silicosis, or rheumatoid arthritis who were taking immunosuppressive biologic medication, which were all populations excluded from the present review. The meta-analysis also included treatment regimens not eligible for our review. The authors noted that stratifying hepatotoxicity results by HIV status, immunosuppression, and TB incidence did not affect the conclusions.