# Chapter 2 Methods

## Key Questions and Analytic Framework

The scope and key questions (KQs) were developed by the Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers. The analytic framework and KQs that guided the review are shown in Figure 1. Five KQs were developed for this review:

Figure 1 Analytic Framework

Abbreviations: IGRA=interferon-gamma release assay; LTBI=latent tuberculosis infection; TB=tuberculosis; TST=tuberculin skin test.

Figure 1 depicts the key questions within the context of the eligible populations, screenings/interventions, comparisons, outcomes, and settings. On the left, the population of interest is asymptomatic adults belonging to populations with increased risk for latent tuberculosis infection (LTBI). Moving from left to right, the figure illustrates the overarching question: Does targeted screening for LTBI in primary care settings in asymptomatic adults at increased risk for developing active tuberculosis disease (TB) improve quality of life or reduce active TB disease incidence, transmission of TB, or disease-specific or overall mortality (KQ1)? The figure depicts the pathway from screening to reduction in the development of active TB, transmission, quality of life and mortality of LTBI to illustrate the questions: What is the accuracy and reliability of the tuberculin skin test (TST) or interferon gamma release assay (IGRA) for screening asymptomatic adults at increased risk for developing active TB and what is the accuracy and reliability of sequential screening strategies that use TST and IGRA (KQ2a/KQ2b). Screening may result in harms (KQ4). After detection of LTBI, the figure illustrates the following questions: Does treatment of LTBI with Centers for Disease Control and Prevention recommended pharmacotherapy regimens improve quality of life or reduce progression to active TB disease, transmission of TB, or disease-specific or overall mortality (KQ3)? Treatment may result in harms (KQ5).

1 What are the benefits of targeted screening for LTBI in primary care settings in asymptomatic adults who are at increased risk for developing active tuberculosis (TB), including among specific populations of interest?
2a What are the accuracy and reliability of the tuberculin skin test (TST) or interferon-gamma release assay (IGRA) for screening in asymptomatic adults who are at increased risk for developing active TB disease, including among specific populations of interest?
2b What are the accuracy and reliability of sequential screening strategies that use TST and IGRA in asymptomatic adults who are at increased risk for developing active TB disease, including among specific populations of interest?
3 What are the benefits of treatment for LTBI with Centers for Disease Control and Prevention (CDC)-recommended pharmacotherapy regimens, including among specific populations of interest?
4a Are harms associated with screening for LTBI, including among specific populations of interest?
4b Do these harms differ by screening method or strategy?
4c Do these harms differ by population?
5 What are the harms associated with treatment of LTBI with CDC-recommended pharmacotherapy regimens, including among specific populations of interest?

For all KQs, this review looked for evidence on whether results differ for specific populations of interest, including those defined by age, sex, race/ethnicity, pregnancy, and higher risk for developing TB. In addition to addressing the KQs, this review looked for evidence related to one CQ that focused on risk assessment tools available for use in primary care to identify adults to screen for LTBI. The CQ was not part of this systematic review. CQs are intended to provide additional background information. Literature addressing the CQ is summarized in Appendix A.

## Data Sources and Searches

We searched PubMed/MEDLINE and the Cochrane Library for English-language articles published from January 30, 2015, through December 3, 2021. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, tests, interventions, outcomes, and study designs. Complete search terms and limits are listed in Appendix B. Targeted searches for unpublished literature were conducted by searching ClinicalTrials.gov. To supplement electronic searches, the reference lists of pertinent review articles and studies that met the inclusion criteria were reviewed. Studies suggested by peer reviewers or public comment respondents were also reviewed and, if appropriate, incorporated into the final review. Since December 3, 2021, ongoing surveillance was conducted through article alerts and targeted searches of journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and the related USPSTF recommendation. The last surveillance was conducted on January 20, 2023. All literature search results were managed using EndNote^™^ version 9.2 (Thomson Reuters, New York, NY).

## Study Selection

We selected studies based on inclusion and exclusion criteria for populations, interventions, comparators, outcomes, timing, settings, and study designs that we developed with input from the USPSTF (Appendix B). In addition to studies identified in the update searches, we reassessed all studies included in the previous review for the USPSTF against the updated study selection criteria. We included relevant English-language studies of good or fair quality and excluded studies in which more than 25 percent of the study population was younger than age 18 years or known to be HIV positive, unless results were stratified by these characteristics.

For KQ 1, randomized, controlled trials (RCTs) or prospective cohort studies were eligible if they compared screening with no screening and focused on asymptomatic adults belonging to populations at increased risk for developing active TB (e.g., persons who inject drugs, persons experiencing homelessness or residing in homeless shelters, persons residing in correctional facilities, persons born in or former residents of countries with high TB prevalence, and persons who work with such individuals). We excluded studies of close contacts of persons with active TB because testing and treatment of such populations is considered part of contact tracing for public health as opposed to a primary care function. We also excluded studies of persons with underlying immunosuppression and for whom LTBI screening and treatment would be part of standard disease management (e.g., persons with HIV, head and neck cancer, leukemia or lymphoma, silicosis, history of or planned organ transplant, planned or active use of tumor necrosis factor-alpha inhibitors, and planned or active use of chemotherapy) because testing and treatment typically need to be individualized and managed with respect to the patient’s comorbidities and medication regimens.

For KQ 2, because there is no direct test for LTBI, we relied on data from studies of persons with bacteriologic-confirmed, active TB who had not yet received treatment (or who had received no more than a few weeks of treatment) to determine sensitivity and studies of healthy subjects known to be at low risk for TB and free of TB exposure to determine specificity. We included studies assessing the accuracy or reliability of three commercially available IGRAs (T-SPOT.TB, QFT-GIT, and QFT-Gold Plus) using the manufacturers’ specified thresholds, but also reported results based on other thresholds when available. For studies assessing the accuracy of the TST using the Mantoux method, we required the use of intermediate-strength PPD and use of standard thresholds for a positive test (i.e., 5 mm, 10 mm, or 15 mm).

For KQs 3 and 5, we included systematic reviews, meta-analyses, and RCTs of persons with LTBI comparing a CDC-recommended treatment (medication, dose, and duration) with placebo, delayed treatment, no treatment, or another CDC-recommended treatment. For KQ 5, prospective cohort studies and case-control studies were also eligible. For KQ 4, systematic reviews, RCTs, and prospective cohort studies reporting false-positive results leading to unnecessary testing (e.g., chest X-ray) or treatment, labeling, stigma, anxiety, or cellulitis were eligible.

For KQs 1, 3, 4, and 5, we included studies conducted in settings considered to be applicable to primary care and conducted in countries categorized as “very high” or “high” on the Human Development Index (as defined by the United Nations Human Development Programme).^46^ Study settings considered applicable to primary care included homeless shelters, correctional facilities, college health settings, long-term care facilities, and public health clinics. For KQ 2 sensitivity outcomes (that enrolled persons with active TB disease), we did not set any exclusion criteria based on setting or country; for KQ 2 specificity outcomes (that enrolled persons at low risk for TB), we excluded studies conducted in countries with a high or intermediate TB burden as defined by the WHO (Appendix B2).^4^

Two investigators independently reviewed titles and abstracts; those marked for potential inclusion by either reviewer were retrieved for evaluation of the full text. Two investigators independently reviewed the full texts to determine final inclusion or exclusion. Disagreements were resolved by discussion and consensus.

## Quality Assessment and Data Abstraction

We assessed the quality of studies as good, fair, or poor, using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B). Two independent investigators assigned quality ratings for each study. Disagreements were resolved by discussion. Only studies rated as having good or fair quality were included.

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. All data extractions were checked by a second investigator for completeness and accuracy.

## Data Synthesis and Analysis

We summarized findings for each KQ in tabular and narrative format. We assessed the overall strength of the evidence for each KQ as high, moderate, low, or insufficient based on the overall quality of the studies, consistency of results between studies, precision of findings, risk of reporting bias, and limitations of the body of evidence, using methods developed for the USPSTF (and the EPC program).^47^ Additionally, the applicability of the findings to U.S. primary care populations and settings was assessed. We resolved discrepancies in strength of evidence grades through consensus discussion.

To determine whether meta-analyses were appropriate, we assessed the clinical and methodological heterogeneity of the studies according to established guidance.^48^ The populations, tests, treatments, comparators, outcomes, and study designs were assessed qualitatively, looking for similarities and differences. When at least three similar studies were available, we conducted quantitative syntheses using random-effects models with the inverse-variance weighted method of DerSimonian and Laird to generate pooled estimates.^49,^ ^50^ For KQ 2, we generated separate pooled estimates of sensitivity and specificity because these accuracy data were collected from independent samples. We also generated pooled estimates of sensitivity and specificity stratified by potentially important covariates such as country TB burden, prevalence of BCG vaccination in the study population, timing of testing with respect to the initiation of pharmacotherapy (for sensitivity only), and prevalence of persons with HIV infection. For KQ 2, we assessed statistical heterogeneity through visual inspection of the forest plots because the I^2^ statistic has limitations when used for evaluating heterogeneity in diagnostic accuracy studies.^51,^ ^52^ For KQs 3 and 5, statistical heterogeneity was assessed using the I^2^ statistic when pooled estimates were available. Results for benefits and harms of treatment (KQs 3 and 5) were considered statistically significant if the P value was less than 0.05 based on two-sided testing. All quantitative analyses were conducted using Stata^™^ version 17 (StataCorp, College Station, TX).

## Expert Review and Public Comment

A draft research plan for this topic was posted on the USPSTF website for public comment from March 11, 2021, to April 7, 2021. In response to comments, the USPSTF revised the KQs to clarify intentions and expanded the eligibility criteria to include countries categorized as both “high” and “very high” on the Human Development Index. The final version of the research plan was posted on the USPSTF website on June 17, 2021. The draft evidence review was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers and was revised based on comments received, mainly to clarify some information in the background. The draft evidence review was posted for public comment from November 22, 2022, through January 3, 2023. Minor revisions were made based on comments received, and references suggested by reviewers were evaluated for inclusion/exclusion. In particular, the report was edited to clarify which of the CDC-recommended LTBI treatment regimens should be administered via DOT.

## USPSTF and AHRQ Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and key questions and to resolve issues related to scope for the final evidence synthesis.

AHRQ staff provided oversight for the project, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.