# Chapter 1 Introduction

## Scope and Purpose

This report will be used by the United States Preventive Services Task Force (USPSTF) to inform an update of its recommendation on screening for latent tuberculosis infection (LTBI) in adults. In 2016, the USPSTF recommended screening for LTBI in asymptomatic adults at increased risk (B recommendation).^1^ The purpose of this report is to review the current evidence on targeted screening for and treatment of LTBI in populations and settings relevant to primary care in the United States.

This review was scoped to inform an updated recommendation about LTBI screening in asymptomatic adults in settings relevant to primary care. The review does not cover testing of close contacts of persons with active tuberculosis (TB) (usually managed by public health programs) or high-risk populations for whom LTBI testing is considered part of standard disease management (e.g., persons with HIV, head and neck cancer, leukemia or lymphoma, silicosis, a history of or planned organ transplant, planned or active use of tumor necrosis factor-alpha inhibitors or other targeted immune modulators, and planned or active use of chemotherapy).

## Condition Definition

Mycobacterium tuberculosis is the bacteria that causes TB. TB usually affects the lungs but can also affect other parts of the body, such as the brain, kidneys, or spine. When a person with active pulmonary TB coughs or sneezes, droplet nuclei containing M. tuberculosis are expelled into the air and can be spread to others by airborne transmission. If another person inhales air containing these droplet nuclei, three outcomes are possible: clearance of the bacteria with no resulting infection; onset of active disease (primary TB disease); or LTBI—that is, potential dissemination and containment of the bacteria by the immune system at various sites without apparent signs, symptoms, or radiographic or bacteriologic evidence of TB disease.^2^ Persons with LTBI are not infectious to others. LTBI can later progress to active TB disease when previously dormant M. tuberculosis bacteria overcome immune containment, proliferate, and progress. Persons with active TB disease have symptoms such as cough (often producing sputum or blood), fevers, chills, weight loss, and night sweats.

## Prevalence and Burden of Disease/Illness

TB is a substantial health issue globally with an estimated 1.7 billion infected with LTBI (23% of the world’s population) in 2014; there were approximately 10 million cases of active TB with 1.5 million TB-related deaths worldwide in 2020.^3,^ ^4^ In the United States, active TB is a more limited health problem with cases declining in recent decades. In 2019, 8,904 new active TB cases were reported in the United States, corresponding to an incidence rate of 2.7 cases per 100,000 population.^5^ There were 526 deaths from TB disease in the United States in 2019.^6^ In 2020, the incidence rate was down to 2.2 cases per 100,000 (7,174 new active TB cases).^7^ Although factors related to the COVID-19 pandemic may be responsible for some of that decrease from 2019 to 2020, the incidence rate and number of deaths from TB have steadily declined over the past 40 years.

In 2020 in the United States, 5,127 active TB cases occurred among persons born outside the US (71.5% of all cases), for a rate of 11.7 cases per 100,000 population compared with 2,018 cases and a rate of 0.7 cases per 100,000 population among U.S.-born persons.^8^ The top five countries of birth among persons born outside the US in the United States with new TB in 2020 were Mexico (18.0%), the Philippines (12.5%), India (10.4%), Vietnam (8.2%), and China (5.1%), accounting for 54.2 percent of total cases.^9^ Most of these cases are thought to be due to progression of latent infection (to active TB disease) rather than new transmission within communities.^10–15^ Active TB rates also vary by race/ethnicity: about 89 percent of all TB cases occur among racial and ethnic minority groups.^16^ Compared with White persons, TB case rates per 100,000 in 2020 were 47 times higher among Native Hawaiians/Pacific Islander persons, 33 times higher for Asian persons, 9 times higher for Hispanic or Latino persons, 8 times higher for American Indians/Alaska Native persons, and 8 times higher for Black/African American persons.^17,^ ^18^ In 2020, among the 5,127 persons born outside the US with active TB, 9.7 percent were diagnosed within 1 year after arrival in the United States, 17.8 percent were diagnosed from 1 to 4 years after initial arrival, and 32.3 percent were diagnosed at least 20 years after arrival.^19^

The incidence of active TB in the United States also varies by geographic location and living accommodations. Whereas the overall U.S. TB rate for 2020 was 2.2 cases per 100,000, State-specific rates ranged from 0.0 (Wyoming) to 7.9 (Alaska).^20^ Although seven States and the District of Columbia reported TB rates higher than the national average (Alaska, California, Hawaii, Maryland, New Jersey, New York, Texas, and Washington, DC), four States accounted for about 50 percent of all U.S. TB cases (California, Texas, New York, and Florida).^20^

Although the World Health Organization (WHO) estimates that one quarter of the world population has LTBI, estimating the prevalence of LTBI overall and among higher-risk groups is challenging because no direct test for latent M. tuberculosis exists, and latent infection is not required to be reported to the Centers for Disease Control and Prevention’s (CDC’s) National Notifiable Disease Surveillance System.^21,^ ^22^ However, LTBI has standardized case definitions; jurisdictions are free to report LTBI cases to CDC if they choose, and latent infection may require reporting to local or State public health authorities.^23^ Unlike active TB disease, which is diagnosed on the basis of clinical signs and symptoms and usually confirmed by identification of M. tuberculosis from fluid or tissue specimens, tests to help determine if a person has LTBI measure memory T-cell response, an indirect measure of host sensitization to M. tuberculosis.^24^ In general, estimates of the prevalence of LTBI are based on studies using tuberculin skin test (TST) or interferon-gamma release assay (IGRA) to define infection.

The largest nationally representative prevalence studies of LTBI use data from the National Health and Nutrition Examination Survey (NHANES) of the civilian, noninstitutionalized U.S. population to estimate the prevalence based on an induration of 10 mm or larger on the TST or a positive IGRA. Using 2011–2012 NHANES data, the population prevalence of LTBI among persons age 6 years or older is 4.7 percent (95% confidence interval [CI], 3.4 to 6.3) based on a positive TST alone, 5.0 percent (95% CI, 4.2 to 5.8) based on a positive IGRA alone, and 2.1 percent (95% CI, 1.5 to 2.8) based on a positive TST and IGRA. Among persons born outside the US who are age 6 years or older, the prevalence of LTBI is 20.5 percent (95% CI, 16.1 to 25.8) based on a positive TST alone, 15.9 percent (95% CI, 13.5 to 18.7) based on a positive IGRA alone, and 9.3 percent (95% CI, 7.4 to 11.7) based on a positive TST and IGRA.^25^ Other than persons born outside the US, NHANES does not include enough persons at higher risk for TB in the sample; thus, nationally representative population estimates among higher-risk groups other than persons born outside the US are not available. Other researchers have estimated the prevalence of LTBI in the United States using verified TB cases for 2011 through 2015 from the U.S. National TB Surveillance System, the 2010 U.S. Census results, and previously reported estimates of reactivated TB, to conclude the U.S. prevalence rate for LTBI during those years was 3.1 percent (uncertainty limits 2.2% to 5.2% based on higher or lower reactivation assumptions), corresponding to 8.9 (6.3 to 14.8) million infected persons.^26^ Of the 3,143 counties across the United States, prevalence estimates varied widely: estimated prevalence was 0 to 1 percent in 63 percent of counties, 1 to 3 percent in 21 percent of counties, and greater than 3 percent in 12 percent of counties. States with the most clusters of counties with the highest prevalence estimates were located primarily in the U.S. Southeast and Southwest regions, plus Hawaii, Alaska, and the southern half of California.^26^

Published estimates of LTBI prevalence among higher-risk groups may have limited generalizability based on the specific population(s) used to collect the estimates, the number of participants included, the tests and definitions for a positive test, and whether studies were conducted within a single or multicenter setting. For example, a retrospective study estimated the LTBI prevalence among persons experiencing homelessness in New York City over the years 1992 through 2005 to be 27.1 percent based on convincing self-reported history of positive TST, but prevalence based on actual testing with TST (threshold for positivity was not specified) was 12.5 percent.^27^ A review published in May 2015 offered LTBI prevalence and active TB disease incidence estimates by high-risk categories based on studies published in English, French, or Spanish between 2009 and 2014. These estimates varied by test used (TST or IGRA) and, in some cases, were based on a single study (Appendix A Contextual Question [CQ] 1 provides additional information on the estimates and risk assessment tools).^24^

## Etiology and Natural History

After exposure to M. tuberculosis, approximately 30 percent of persons are thought to develop LTBI, as diagnosed based on a positive TST.^28,^ ^29^ Five to 10 percent of healthy, immunocompetent persons with a positive TST will progress from LTBI to active TB disease in their lifetime. This estimate is based on epidemiologic data and data from placebo arms of treatment trials conducted before treatment of LTBI was routinely recommended.^30,^ ^31^ However, this range underestimates the risk of progression to active TB for some patients and overestimates the risk for others because risks vary greatly according to age, the recency of exposure, the size of the TST reaction, and the presence or absence of specific medical conditions.^32^

An observational study of contacts of persons with active TB in Amsterdam who were diagnosed with LTBI between 2002 and 2011 reported a 5-year risk of incident TB of 2.4 percent (95% CI, 1.2 to 4.7) among those who did not take preventive therapy.^33^ A report using 2006 through 2008 U.S. data (not reporting whether patients had taken preventive therapy for LTBI) estimated the rate of progression to active TB among persons with LTBI as 0.084 cases per 100 person-years (95% CI, 0.083 to 0.085).^34^ Rates of progression to active TB were higher among persons born outside the US (0.098 cases per 100 person-years [95% CI, 0.096 to 0.100]) than among those born in the United States (0.082 cases per 100 person-years [95% CI, 0.080 to 0.083]).

## Risk Factors

Risk factors for TB are typically divided into those associated with risk of exposure and initial infection and those associated with progression to active disease. Both of these categories of risk factors are considered important for addressing TB, including through targeted screening, thresholds for a positive screen, and efforts to eliminate TB in the United States. More specifically, the CDC suggests targeted LTBI screening for those at high risk for TB based on temporary or permanent residence in a country with a high TB rate, current or planned immunosuppression, or close contact with someone who has infectious TB.^35^ In addition, the CDC has identified different thresholds for a positive TST based on individual risk factors.^35,^ ^36^ Although there is considerable overlap in the risk factors for exposure, initial infection, and progression to active TB disease, these risk factors are often described separately. Many studies that address risk are older and may reflect different background infection rates and practice patterns than today.

Risk factors for initial infection generally include exposure, immunosuppression, and socioeconomic and behavioral factors. A recent synthesis of the literature conducted by the American Thoracic Society (ATS), Infectious Diseases Society of America (IDSA), and the CDC provided recommendations on diagnostic testing based on many of these risk factors.^37^ More specifically, these recommendations detail risk hierarchies for 1) those with increased risk of infection and 2) those with increased risk of progression to TB if infected in order to guide recommendations for diagnostic testing and interpretation of results. In addition, they combine these risk levels to create a tiered LTBI testing strategy. They categorize levels of risk of infection from lowest to highest as follows:^37^ (a) no risk factors, (b) residents and employees of high-risk congregate settings (e.g., prisons), (c) immigrants from high-burden countries (>20 cases of active TB per 100,000 persons in the population), (d) persons who work in mycobacteriology laboratories, and (e) household contacts with or recent exposure to an active TB case. The ATS/IDSA/CDC guidelines describe low, intermediate, and high risk levels for developing active TB if infected.^37^ Low risk involves having no risk factors. Intermediate risk is defined as having a clinical predisposition because of diabetes, chronic renal failure, or intravenous drug use. High risk is designated for persons age 5 years or younger, with HIV infection, on immunosuppressive therapy, with an abnormal CXR (chest radiograph) consistent with prior TB, or with silicosis.

## Rationale for Screening/Screening Strategies

The rationale for screening for LTBI is to identify persons who may benefit from treatment of latent infection to prevent it from progressing to active TB disease, which can result in morbidity and mortality for the infected person and pose a risk for transmission to others. The prevention of active TB by treating LTBI is a cornerstone of the public health strategy for eliminating TB in the United States.^38^ The WHO has also recognized the prevention of active TB as an essential component of worldwide TB elimination efforts.^4^

The diagnosis of LTBI is based on a clinical assessment and is not based on any single test. If screening tests for LTBI are positive, a medical and social history, symptom assessment, physical examination, imaging tests (typically chest radiographs), and sometimes sputum sampling and other laboratory tests are used to exclude active TB disease (screening tests alone cannot differentiate LTBI from TB disease). Available screening tests for LTBI do not directly determine the presence of M. tuberculosis, for example, with cultures or nucleic acid assays as is typically done when screening for other infections. Instead, available screening tests assess the immune response following an exposure to M. tuberculosis antigens. The TST and IGRA are the two categories of tests widely available for screening for LTBI. Because these tests are indirect markers of infection, they cannot be used to distinguish persons with latent infection, active disease, or convalescing patients. Further, because the diagnosis of LTBI is clinical, no reference diagnostic tests are available for confirming an LTBI diagnosis. Thus, the evaluation of screening test accuracy of TST and IGRA requires case-control study designs, also known as two-gate designs, where the sensitivity of the tests is evaluated among persons with confirmed active TB disease, and the specificity of the tests is evaluated among healthy individuals from low-TB-incidence areas and without known exposure or TB risks (i.e., persons with presumptive absence of LTBI).

### TST

The TST, also known as the Mantoux test, has been the standard screening test for LTBI for many years.^37^ This test involves the intradermal placement of a standardized tuberculin antigen (e.g., 5 units of purified protein derivative [PPD-S2] in the United States, 2 units of PPD-RT-23 in other regions of the world), typically on the ventral surface of the forearm followed by clinical measurement of the delayed hypersensitivity reaction, if any, by a trained observer 48 to 72 hours after placement.^37,^ ^39^ The observer measures the transverse diameter of any palpable induration and records its size in millimeters. Indurations of 5 mm or more are considered positive for close contacts of active TB cases; immunosuppressed individuals, including those with HIV; persons receiving tumor necrosis factor blocking agents; and persons with clinical or radiographic evidence of current or prior TB. An induration of 10 mm or more is considered a positive test for persons born in countries with high TB incidence, those with occupational exposure to TB, and those with medical conditions that increase the risk of progression from LTBI to active TB disease (e.g., diabetes, chronic renal failure). For all other persons, an induration of 15 mm or more is considered a positive test. Benefits of the TST include its low cost, no requirement for blood draw or laboratory or complex equipment, and years of established use with standardized definitions for positive tests.^37^ However, TST requires trained personnel to administer and interpret the test, requires two visits, and may result in false-positive results because of cross-reactivity with the Bacille Calmett-Guérin (BCG) vaccine and nontuberculous mycobacteria and may result in false-negative results in children and in individuals with immunosuppression.^39^

### IGRAs

IGRAs are in vitro laboratory tests that can also be used for screening for LTBI. These tests measure the CD4 T-cell response specific to M. tuberculosis antigens and do not react in response to most nontuberculous strains of mycobacteria, including the M. bovis strains associated with the BCG vaccine (although actual M. bovis infection can cause a positive IGRA). Two commercial platforms for conducting IGRAs are Food and Drug Administration (FDA) approved: QuantiFERON-TB^®^ (QFT) and T-SPOT^®^.TB. QFT offers two whole-blood enzyme-linked immunosorbent assays: the QFT-Gold in tube (QFT-GIT, approved in 2007) and the QFT-Gold Plus (approved in 2017). The T-SPOT.TB test (approved in 2010) is an enzyme-linked immunospot assay that is conducted on separated monocytes and lymphocytes. In clinical practice, the results of the QFT and T-SPOT.TB tests are interpreted qualitatively as positive or negative based on whether the quantitative result is above or below a specific threshold; however, results may also be reported as borderline (T-SPOT.TB only) or indeterminate.^37^ Quantitative results may be useful for clinical decision making in individual cases, in combination with risk factors. Benefits of IGRAs include increased specificity for M. tuberculosis and lack of need for a return visit for interpretation. However, IGRAs are more costly than TST; require a blood draw; and require proper and timely specimen collection, storage, and processing.

## Treatment Approaches

Individuals who screen positive for LTBI and in whom active infection has been excluded are generally offered treatment with antimycobacterial medications based on trials that demonstrate reduced progression to active TB by treating latent infections.^36^ For decades, isoniazid (INH) was the only medication used for treating LTBI, based on trials demonstrating its effectiveness for preventing progression to active TB and its low cost. However, concerns about hepatoxicity and low treatment completion rates for regimens as long as 6 to 12 months prompted the evaluation of alternative regimens. Since then, several preferred regimens have emerged that include INH and drugs in the rifamycin class (rifampin [RIF] and rifapentine [RPT]). In 2020, the CDC issued new recommendations (Table 1) based on findings from a systematic review and meta-analysis of newer clinical trials of rifamycin-based regimens to treat LTBI, which demonstrated equivalent efficacy and superior safety and completion rates for shorter rifamycin-based regimens compared with the standard comparator regimen of daily INH for 9 months.^40^ The three rifamycin-based regimens (once-weekly INH plus RPT for 3 months, daily RIF for 4 months, and daily INH plus RIF for 3 months) were designated as preferred because they have excellent tolerability and efficacy, shorter treatment duration, and higher completion rates. Daily INH for 6 months was designated as an alternative regimen because of its excellent efficacy but longer treatment duration and lower completion rates (and therefore lower real-world effectiveness). Daily INH for 9 months was designated as a conditional alternative regimen because of the potential for increased risk of hepatotoxicity with its longer duration and unclear increase in effectiveness. The CDC notes that intermittent regimens of INH (twice weekly) should be provided by directly observed therapy (DOT).

Table 1 CDC (2020) Recommended LTBI Treatment Regimens

Priority^*^ | Recommendation Strength^†^ | Drug(s) | Duration | Dose | Frequency | Total Doses
Preferred | Strong | INH and RPT | 3 months | INH: 15 mg/kg rounded up to the nearest 50 or 100 mg; 900 mg maximum; RPT: 10.0–14.0 kg 300 mg; 14.1–25.0 kg 450 mg; 25.1–32.0 kg 600 mg; 32.1–49.9 kg 750 mg; ≥50.0 kg 900 mg maximum | Once weekly | 12
Preferred | Strong | RIF | 4 months | 10 mg/kg; Maximum dose: 600 mg | Daily | 120
Preferred | Conditional | INH and RIF | 3 months | INH: 5 mg/kg rounded up to the nearest 50 or 100 mg; 300 mg maximum; RIF: 10 mg/kg; 600 mg maximum | Daily | 90
Alternative | Strong (HIV negative) | INH | 9 months | 5 mg/kg; Maximum dose: 300 mg | Daily | 270
Alternative | Conditional (HIV positive) | INH | 9 months | 15 mg/kg; Maximum dose: 900 mg | Twice weekly^‡^ | 76
Alternative | Conditional | INH | 6 months | 5 mg/kg; Maximum dose: 300 mg | Daily | 180
Alternative | Conditional | INH | 6 months | 15 mg/kg; Maximum dose: 900 mg | Twice weekly^‡^ | 52

Information is from CDC (2020) recommended regimens.^30^

* Preferred: Excellent tolerability and efficacy, shorter treatment duration, higher completion rates than longer regimens and therefore higher effectiveness; alternative: excellent efficacy but concerns regarding longer treatment duration, lower completion rates, and therefore lower effectiveness.

† Strong indicates benefits outweigh risks and evidence quality is at least moderate; conditional indicates it is uncertain whether benefits outweigh risks.

‡ Intermittent regimens must be provided via directly observed therapy (i.e., healthcare worker observes the ingestion of medication).

Abbreviations: CDC=Centers for Disease Control and Prevention; HIV=human immunodeficiency virus; INH=isoniazid; LTBI=latent TB infection; RIF=rifampin; RPT=rifapentine.

## Clinical Practice in the United States and Recommendations of Other Organizations

In developed countries with a low prevalence of TB such as the United States, most authorities recommend that LTBI screening be done only among high-risk groups and when treatment is feasible (Appendix A Table 1).^37^ Recommendations for targeted—rather than routine—LTBI screening for specific high-risk populations have mostly remained unchanged in recent years. The CDC recommends that those at increased risk for LTBI and TB disease should be tested for LTBI.^37,^ ^41^ The CDC provides a three-item example TB risk assessment tool to help identify those who should be tested, based on a tool from the California Department of Public Health.^35^ The tool includes three of the major risk factor categories: temporary or permanent residence of 1 month or greater in a country with a high TB rate, current or planned immunosuppression, and close contact during lifetime with someone who has had infectious TB disease. CQ 1 in Appendix A provides additional information about risk assessment tools.

In 2017, the CDC, in collaboration with the ATS and IDSA, revised joint recommendations for LTBI screening, which are largely consistent with prior recommendations.^37^ TST remained the preferred method of LTBI testing for children under the age of 5 years. In individuals older than 5 years, an IGRA was recommended over TST for patients likely to be infected with M. tuberculosis and who have low or intermediate risks for disease progression, especially among those with prior BCG vaccinations or who might not return to have TSTs read (e.g., persons experiencing homelessness). In individuals older than 5 years who are likely to be infected with M. tuberculosis with a high risk for disease progression, TST or an IGRA can be used without preference. Of note, the Red Book from the American Academy of Pediatrics indicates that an IGRA can be used for children 2 years or older.^42^

The CDC discourages the use of TST and IGRA tests for LTBI among individuals and populations at low risk for TB infection and discourages a testing approach that is independent of a risk assessment.^37^ Although the recommendation is not to test individuals at low risk for M. tuberculosis infection, in cases where LTBI testing is otherwise required (e.g., by law), use of an IGRA is preferred over TST. For all scenarios among individuals older than 5 years, if an IGRA is not available, is cost prohibitive, or is too burdensome, TST remains a reasonable alternative. For testing done among individuals at low risk (e.g., when required by law), a second confirmatory test is recommended for individuals older than 5 years for whom the first test is positive; in such cases, latent infection is confirmed only if both tests are positive and active TB disease is ruled out.^37^ The second test may be either an IGRA or TST.^37^

Many of the WHO guidelines are largely targeted toward TB control programs and public health authorities in low- and middle-income countries.^43,^ ^44^ In 2018, the WHO reaffirmed their recommendation for asymptomatic individuals of all ages in countries with a low TB incidence who are household contacts of persons with active TB to be systematically tested and treated for LTBI.^45^ The WHO endorses the use of TST or IGRAs as LTBI screening methods.^45^ The WHO also states that systematic testing for and treatment of LTBI may be considered in countries with a low TB incidence for persons residing in correctional facilities, health workers, immigrants from countries with a high TB burden, persons experiencing homelessness, and persons who use illicit drugs.^45^