# Appendix F Additional Figures

Appendix F Figure 1 Sensitivity for TST at 5-mm Threshold, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 1 displays a forest plot reporting the individual and pooled estimates of the Tuberculin Skin Test (TST) at 5mm induration threshold, stratified by country TB burden of the study setting. For low TB burden countries, the pooled estimate for the six included studies is 0.83 (95% CI, 0.74 to 0.92). For intermediate TB burden countries, the pooled estimate for the three included studies is 0.75 (95% CI, 0.60 to 0.91). For high TB burden countries, the pooled estimate for the three included studies is 0.79 (95% CI, 0.65 to 0.94).

Appendix F Figure 2 Sensitivity for TST at 5-mm Threshold, Stratified by Timing of Testing With Respect to Antituberculosis Treatment

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 2 displays a forest plot reporting the individual and pooled estimates of the Tuberculin Skin Test (TST) at 5mm induration threshold, stratified by the timing of testing with respect to antituberculosis treatment. For the five studies with testing within seven days of treatment, the pooled estimate is 0.78 (95% CI, 0.68 to 0.88). For the one individual study with testing between 8 days and 14 days of treatment, the estimate is 0.86 (95% CI, 0.81 to 0.90). For the two studies with testing between 15 days and 30 days of treatment, the pooled estimate is 0.85 (95% CI, 0.76 to 0.93). For the four studies that did not report timing with respect to treatment, the pooled estimate is 0.79 (95% CI, 0.65 to 0.94).

Appendix F Figure 3 Sensitivity for TST at 5-mm Threshold, Stratified by HIV Prevalence of the Study Population

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 3 displays a forest plot reporting the individual and pooled estimates of the Tuberculin Skin Test (TST) at 5mm induration threshold, stratified by HIV prevalence of the study population. For the six studies with an HIV prevalence of 0%, the pooled estimate is 0.77 (95% CI, 0.62 to 0.92). For the four studies with an HIV prevalence greater than 0%, the pooled estimate is 0.87 (95% CI, 0.82 to 0.92). For the two studies that did not report HIV prevalence, the pooled estimate is 0.76 (95% CI, 0.68 to 0.84).

Appendix F Figure 4 Sensitivity for TST at 5-mm Threshold, Stratified by BCG Vaccination Prevalence of the Study Setting

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 4 displays a forest plot reporting the individual and pooled estimates of the Tuberculin Skin Test (TST) at 5mm induration threshold, stratified by BCG vaccination prevalence of the study population. For the five studies with a BCG vaccination prevalence greater than 50%, the pooled estimate is 0.83 (95% CI, 0.75 to 0.91). For the three studies with a BCG vaccination prevalence less than 50%, the pooled estimate is 0.83 (95% CI, 0.63to 1.03). For the four studies that did not report BCG vaccination prevalence, the pooled estimate is 0.75 (95% CI, 0.63 to 0.87).

Appendix F Figure 5 Sensitivity for TST at 10-mm Threshold, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 5 displays a forest plot reporting the individual and pooled estimates of the Tuberculin Skin Test (TST) at 10mm induration threshold, stratified by country TB burden of the study setting. For low TB burden countries, the pooled estimate for the four included studies is 0.86 (95% CI, 0.75 to 0.96). For intermediate TB burden countries, the pooled estimate for the eight included studies is 0.74 (95% CI, 0.62 to 0.86). For high TB burden countries, the pooled estimate for the three included studies is 0.90 (95% CI, 0.80 to 0.99).

Appendix F Figure 6 Sensitivity for TST at 10-mm Threshold, Stratified by Timing of Testing With Respect to Antituberculosis Treatment

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 6 displays a forest plot reporting the individual and pooled estimates of the Tuberculin Skin Test (TST) at 10mm induration threshold, stratified by the timing of testing with respect to antituberculosis treatment. For the five studies with testing within seven days of treatment, the pooled estimate is 0.73 (95% CI, 0.62 to 0.84). For the two studies with testing between 8 days and 14 days of treatment, the pooled estimate is 0.90 (95% CI, 0.87 to 0.93). For the one individual study with testing between 15 days and 30 days of treatment, the estimate is 0.84 (95% CI, 0.67 to 0.93). For the seven studies that did not report timing with respect to treatment, the pooled estimate is 0.84 (95% CI, 0.77 to 0.92).

Appendix F Figure 7 Sensitivity for TST at 10-mm Threshold, Stratified by HIV Prevalence of the Study Population

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 7 displays a forest plot reporting the individual and pooled estimates of the Tuberculin Skin Test (TST) at 10mm induration threshold, stratified by HIV prevalence of the study population. For the eight studies with an HIV prevalence of 0%, the pooled estimate is 0.80 (95% CI, 0.71 to 0.89). For the four studies with an HIV prevalence greater than 0%, the pooled estimate is 0.82 (95% CI, 0.72 to 0.92). For the three studies that did not report HIV prevalence, the pooled estimate is 0.83 (95% CI, 0.68 to 0.97).

Appendix F Figure 8 Sensitivity for TST at 10-mm Threshold, Stratified by BCG Vaccination Prevalence of the Study Setting

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2=^the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 8 displays a forest plot reporting the individual and pooled estimates of the Tuberculin Skin Test (TST) at 10mm induration threshold, stratified by BCG vaccination prevalence of the study population. For the three studies with a BCG vaccination prevalence greater than 50%, the pooled estimate is 0.90 (95% CI, 0.82 to 0.97). For the nine studies with a BCG vaccination prevalence less than 50%, the pooled estimate is 0.77 (95% CI, 0.67 to 0.88). For the three studies that did not report BCG vaccination prevalence, the pooled estimate is 0.83 (95% CI, 0.74 to 0.92).

Appendix F Figure 9 Sensitivity for TST at 15-mm Threshold, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2=^the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 9 displays a forest plot reporting the individual and pooled estimates of the Tuberculin Skin Test (TST) at 15mm induration threshold, stratified by country TB burden of the study setting. For low TB burden countries, the pooled estimate for the two included studies is 0.78 (95% CI, 0.73 to 0.82). For intermediate TB burden countries, the pooled estimate for the four included studies is 0.41 (95% CI, 0.21 to 0.61). For high TB burden countries, the pooled estimate for the three included studies is 0.76 (95% CI, 0.55 to 0.97).

Appendix F Figure 10 Sensitivity for TST at 15-mm Threshold, Stratified by Timing of Testing With Respect to Antituberculosis Treatment

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2=^the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 10 displays a forest plot reporting the individual and pooled estimates of the Tuberculin Skin Test (TST) at 15mm induration threshold, stratified by the timing of testing with respect to antituberculosis treatment. For the two studies with testing within seven days of treatment, the pooled estimate is 0.50 (95% CI, 0.43 to 0.58). For the two studies with testing between 8 days and 14 days of treatment, the pooled estimate is 0.89 (95% CI, 0.85 to 0.92). For the one individual study with testing between 15 days and 30 days of treatment, the estimate is 0.26 (95% CI, 0.14 to 0.43). For the four studies that did not report timing with respect to treatment, the pooled estimate is 0.57 (95% CI, 0.35 to 0.80).

Appendix F Figure 11 Sensitivity for TST at 15-mm Threshold, Stratified by HIV Prevalence of the Study Population

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2=^the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 11 displays a forest plot reporting the individual and pooled estimates of the Tuberculin Skin Test (TST) at 15mm induration threshold, stratified by HIV prevalence of the study population. For the five studies with an HIV prevalence of 0%, the pooled estimate is 0.61 (95% CI, 0.42 to 0.79). For the three studies with an HIV prevalence greater than 0%, the pooled estimate is 0.69 (95% CI, 0.42 to 0.96). For the one individual study that did not report HIV prevalence, the estimate is 0.26 (95% CI, 0.14 to 0.43).

Appendix F Figure 12 Sensitivity for TST at 15-mm Threshold, Stratified by BCG Vaccination Prevalence of the Study Setting

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2=^the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 12 displays a forest plot reporting the individual and pooled estimates of the Tuberculin Skin Test (TST) at 15mm induration threshold, stratified by BCG vaccination prevalence of the study population. For the three studies with a BCG vaccination prevalence greater than 50%, the pooled estimate is 0.79 (95% CI, 0.66 to 0.91). For the six studies with a BCG vaccination prevalence less than 50%, the pooled estimate is 0.50 (95% CI, 0.31 to 0.70).

Appendix F Figure 13 Sensitivity for T-SPOT.TB Test, Stratified by Threshold Used for Positive Test

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2=^the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; T-SPOT.TB=commercial ELISPOT assay; TST=tuberculin skin test.

Figure Note: The FDA-approved labeling uses a threshold of 8 or more spots for a positive test and 4 or fewer spots for a negative test (unless the total number of spots is less than 20); 5, 6 or 7 spots are considered borderline or equivocal. The labeling approved for use in European and other countries uses a threshold of 6 or more spots for a positive test and a negative test is 5 or fewer spots.

Appendix F Figure 13 displays a forest plot reporting the individual and pooled estimates of the T-SPOT.TB test, stratified by the threshold used for positive test. For the ten studies using the FDA threshold, the pooled estimate is 0.86 (95% CI, 0.81 to 0.92). For the nineteen studies using the European threshold, the pooled estimate is 0.92 (95% CI, 0.89 to 0.95). For the eight studies that did not report threshold, the pooled estimate is 0.89 (95% CI, 0.85 to 0.93).

Appendix F Figure 14 Sensitivity for T-SPOT.TB Test, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2=^the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; T-SPOT.TB=commercial ELISPOT assay; TST=tuberculin skin test.

Appendix F Figure 14 displays a forest plot reporting the individual and pooled estimates of the T-SPOT.TB test, stratified by country TB burden of the study setting. For low TB burden countries, the pooled estimate for the seven included studies is 0.89 (95% CI, 0.82 to 0.95). For mixed low/intermediate TB burden countries, the pooled estimate for the two studies is 0.92 (95% CI, 0.86 to 0.97). For intermediate TB burden countries, the pooled estimate for the sixteen included studies is 0.89 (95% CI, 0.86 to 0.93). For high TB burden countries, the pooled estimate for the twelve included studies is 0.91 (95% CI, 0.88 to 0.94).

Appendix F Figure 15 Sensitivity for T-SPOT.TB Test, Stratified by Timing of Testing With Respect to Antituberculosis Treatment

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2=^the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; T-SPOT.TB=commercial ELISPOT assay; TST=tuberculin skin test.

Appendix F Figure 15 displays a forest plot reporting the individual and pooled estimates of the T-SPOT.TB test, stratified by the timing of testing with respect to antituberculosis treatment. For the sixteen studies with testing within seven days of treatment, the pooled estimate is 0.90 (95% CI, 0.88 to 0.92). For the six studies with testing between 8 days and 14 days of treatment, the pooled estimate is 0.90 (95% CI, 0.84 to 0.97). For the two studies with testing between 15 days and 30 days of treatment, the pooled estimate is 0.92 (95% CI, 0.87 to 0.98). For the thirteen studies that did not report timing with respect to treatment, the pooled estimate is 0.90 (95% CI, 0.85 to 0.95).

Appendix F Figure 16 Sensitivity for T-SPOT.TB Test, Stratified by HIV Prevalence of the Study Population

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2=^the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; TB=tuberculosis; T-SPOT.TB=commercial ELISPOT assay; TST=tuberculin skin test.

Appendix F Figure 16 displays a forest plot reporting the individual and pooled estimates of the T-SPOT.TB test, stratified by HIV prevalence of the study population. For the sixteen studies with an HIV prevalence of 0%, the pooled estimate is 0.91 (95% CI, 0.88 to 0.93). For the fourteen studies with an HIV prevalence greater than 0%, the pooled estimate is 0.88 (95% CI, 0.84 to 0.91). For the seven studies that did not report HIV prevalence, the pooled estimate is 0.93 (95% CI, 0.89 to 0.98).

Appendix F Figure 17 Sensitivity for T-SPOT.TB Test, Stratified by BCG Vaccination Prevalence of the Study Setting

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2=^the proportion of variation in study estimates due to heterogeneity; Int=intermediate; N=number; NR=not reported; TB=tuberculosis; T-SPOT.TB=commercial ELISPOT assay; TST=tuberculin skin test.

Appendix F Figure 17 displays a forest plot reporting the individual and pooled estimates of the T-SPOT.TB test, stratified by BCG vaccination prevalence of the study population. For the fourteen studies with a BCG vaccination prevalence greater than 50%, the pooled estimate is 0.89 (95% CI, 0.86 to 0.92). For the twenty-three studies with a BCG vaccination prevalence not reported the pooled estimate is 0.91 (95% CI, 0.87 to 0.94).

Appendix F Figure 18 Sensitivity for QFT-Gold In-Tube (3rd Generation) Test, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2=^the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; QFT=QuantiFERON-TB; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 18 displays a forest plot reporting the individual and pooled estimates of the QuantiFERON Gold-in-Tube test, stratified by country TB burden of the study setting. For low TB burden countries, the pooled estimate for the seven included studies is 0.79 (95% CI, 0.72 to 0.86). For mixed low/intermediate TB burden countries, the pooled estimate for the three studies is 0.87 (95% CI, 0.79 to 0.95). For intermediate TB burden countries, the pooled estimate for the twenty-five included studies is 0.83 (95% CI, 0.79 to 0.86). For high TB burden countries, the pooled estimate for the thirteen included studies is 0.79 (95% CI, 0.73 to 0.85).

Appendix F Figure 19 Sensitivity for QFT-Gold In-Tube (3rd Generation) Test, Stratified by Timing of Testing With Respect to Antituberculosis Treatment

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2=^the proportion of variation in study estimates due to heterogeneity; Int=intermediate; N=number; NR=not reported; QFT=QuantiFERON-TB; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 19 displays a forest plot reporting the individual and pooled estimates of the QuantiFERON Gold-in-Tube test, stratified by the timing of testing with respect to antituberculosis treatment. For the twenty-four studies with testing within seven days of treatment, the pooled estimate is 0.78 (95% CI, 0.74 to 0.82). For the ten studies with testing between 8 days and 14 days of treatment, the pooled estimate is 0.84 (95% CI, 0.78 to 0.91). For the fourteen studies that did not report timing with respect to treatment, the pooled estimate is 0.85 (95% CI, 0.80 to 0.89).

Appendix F Figure 20 Sensitivity for QFT-Gold In-Tube (3rd Generation) Test, Stratified by HIV Prevalence of the Study Population

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2=^the proportion of variation in study estimates due to heterogeneity; Int=intermediate; N=number; NR=not reported; QFT=QuantiFERON-TB; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 20 displays a forest plot reporting the individual and pooled estimates of the QuantiFERON Gold-in-Tube test, stratified by HIV prevalence of the study population. For the twenty-four studies with an HIV prevalence of 0%, the pooled estimate is 0.82 (95% CI, 0.78 to 0.86). For the thirteen studies with an HIV prevalence greater than 0%, the pooled estimate is 0.78 (95% CI, 0.72 to 0.83). For the eleven studies that did not report HIV prevalence, the pooled estimate is 0.85 (95% CI, 0.79 to 0.92).

Appendix F Figure 21 Sensitivity for QFT-Gold In-Tube (3rd Generation) Test, Stratified by BCG Vaccination Prevalence of the Study Setting

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; hit=intermediate; N=number; NR=not reported; QFT=QuantiFERON-TB; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 21 displays a forest plot reporting the individual and pooled estimates of the QuantiFERON Gold-in-Tube test, stratified by BCG vaccination prevalence of the study population. For the ten studies with a BCG vaccination prevalence less than 50%, the pooled estimate is 0.77 (95% CI, 0.70 to 0.84). For the twelve studies with a BCG vaccination prevalence greater than 50%, the pooled estimate is 0.78 (95% CI, 0.73 to 0.83). For the twenty-six studies with a BCG vaccination prevalence less than 50%, the pooled estimate is 0.85 (95% CI, 0.81 to 0.88).

Appendix F Figure 22 Sensitivity for QFT-Gold Plus (4th Generation) Test, Stratified by Country TB Burden of the Study Setting

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; QFT=QuantiFERON-TB; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 22 displays a forest plot reporting the individual and pooled estimates of the QuantiFERON Gold Plus test, stratified by country TB burden of the study setting. For low TB burden countries, the estimate for the one included study is 0.96 (95% CI, 0.80 to 0.99). For mixed low/intermediate TB burden countries, the estimate for the one included study is 0.89 (95% CI, 0.83 to 0.93). For intermediate TB burden countries, the pooled estimate for the eight included studies is 0.89 (95% CI, 0.83 to 0.95). For high TB burden countries, the estimate for the one included study is 0.77 (95% CI, 0.61 to 0.88).

Appendix F Figure 23 Sensitivity for QFT-Gold Plus (4th Generation) Test, Stratified by Timing of Testing With Respect to Antituberculosis Treatment

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; QFT=QuantiFERON-TB; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 23 displays a forest plot reporting the individual and pooled estimates of the QuantiFERON Gold Plus test, stratified by the timing of testing with respect to antituberculosis treatment. For the three studies with testing within seven days of treatment, the pooled estimate is 0.75 (95% CI, 0.64 to 0.86). For the five studies with testing between 8 days and 14 days of treatment, the pooled estimate is 0.93 (95% CI, 0.88 to 0.97). For the one study with testing between 15 days and 30 days, the estimate was 0.90 (95% CI, 0.77 to 0.96). For the two studies that did not report timing with respect to treatment, the pooled estimate is 0.96 (95% CI, 0.90 to 1.02).

Appendix F Figure 24 Sensitivity for QFT-Gold Plus (4th Generation) Test, Stratified by HIV Prevalence of the Study Population

Abbreviations: BCG=Bacille Calmett-Guérin; CI=confidence interval; HIV=human immunodeficiency virus; I^2^=the proportion of variation in study estimates due to heterogeneity; N=number; NR=not reported; QFT=QuantiFERON-TB; TB=tuberculosis; TST=tuberculin skin test.

Appendix F Figure 24 displays a forest plot reporting the individual and pooled estimates of the QuantiFERON Gold Plus test, stratified by HIV prevalence of the study population. For the three studies with an HIV prevalence of 0%, the pooled estimate is 0.87 (95% CI, 0.74 to 1.00). For the three studies with an HIV prevalence greater than 0%, the pooled estimate is 0.88 (95% CI, 0.83 to 0.93). For the five studies that did not report HIV prevalence, the pooled estimate is 0.91 (95% CI, 0.87 to 0.95).

Appendix F Figure 25 Isoniazid Compared With Placebo: Relative Risk of Progression to Active Tuberculosis, Sensitivity Analysis

Notes: Marker size indicates relative sample size and contribution to pooled estimate. For Thompson (IUAT trial),^158^ we included data from the 24- and 52-week groups. For Bush,^164^ we only used data for those ≥20 years of age. For Falk,^165^ we used data for the subset with no previous TB therapy for participants in the isoniazid 1-year group (we did not include data for the isoniazid 2-year group). For Ferebee,^31^ we used only the subset that was tuberculin positive; we were unable to get adult-only data to enter here (for the full study sample, 34 of the 51 cases in the placebo am were among adults, and it was not reported how many of the 19 total cases in the isoniazid am of the study were among adults).

For RCTs other than the IUAT trial to be included in this sensitivity analysis, we required that they either confirmed LTBI for subjects to be eligible, reported data for those with confirmed LTBI, or that the vast majority of subjects (over 75 percent) were tuberculin positive. These trials met many of our eligibility criteria, but they all used a longer duration of treatment than is currently recommended by the CDC (i.e., they used 1 year or longer of isoniazid), and some used lower or higher doses than currently recommended or did not require LTBI confirmation for subjects to be eligible ^31,^ ^164,^ ^165^ One of the four trials was rated poor quality.^167^

Abbreviations: CI=confidence interval; INH=isoniazid; mths=months; RR=relative risk.

Appendix F Figure 25 displays a forest plot reporting the relative risk of developing active tuberculosis in those treated with isoniazid versus those treated with placebo. The pooled estimate of the five included studies presented a relative risk of 0.31 (95% CI, 0.24 to 0.41).

Appendix F Figure 26 Isoniazid Compared With Placebo: Relative Risk of Developing Hepatotoxicity in the IUAT Trial

Notes: For Thompson, 1982^135^ (IUAT trial), we included data from the 12-, 24-, and 52-week groups. A definition for hepatotoxicity (presented as “hepatitis” in this study) was not reported.

Abbreviations: CI=confidence interval; INH=isoniazid; IUAT=International Union Against Tuberculosis; RR=relative risk.

Appendix F Figure 26 displays a forest plot reporting the relative risk of developing hepatotoxicity in those treated with isoniazid versus those treated with placebo from the IUAT trial. The relative risk of hepatotoxicity for those taking isoniazid was 3.45 (95% CI, 1.49 to 7.99) at 12 weeks, 4.59 (95% CI, 2.03 to 10.39) at 24 weeks, and 6.21 (95% CI, 2.79 to 13.79) at 52 weeks.

Appendix F Figure 27 Isoniazid Compared With Placebo, Relative Risk of Developing Hepatotoxicity: Sensitivity Analysis Including Data From Four Randomized, Controlled Trials

Notes: For Thompson, 1982 (IUAT trial),^158^ we included data from the 12-, 24-, and 52-week groups. A definition for hepatotoxicity (presented as “hepatitis” in this study) was not reported for this study. For Bailey, 1974,^184^ and Byrd, 1977,^185^ hepatotoxicity was defined as SGOT >100 mU/ml. For Falk, 1978,^165^ hepatotoxicity was defined only as “mild hepatitis.”

Abbreviations: CI=confidence interval; INH=isoniazid; IUAT=International Union Against Tuberculosis; RR=relative risk; SGOT=serum glutamic-oxaloacetic transaminase.

Appendix F Figure 27 displays a forest plot reporting the relative risk of developing hepatotoxicity in those treated with isoniazid versus those treated with placebo for four RCTs included in our sensitivity analysis. The pooled estimate of the five included studies presented a relative risk of 5.04 (95% CI, 2.50 to 10.15).

Appendix F Figure 28 Isoniazid Compared With Placebo, Relative Risk of Treatment Discontinuation Due to Adverse Events: Sensitivity Analysis Including Data From Four Randomized, Controlled Trials

Notes: For Thompson, 1982 (IUAT trial), rates of discontinuation due to adverse events were reported only as a combined value across the three treatment duration groups (12-, 24-, and 52-week). For Bush, 1965, treatment discontinuation due to adverse events was categorized as gastrointestinal, rash, and other. For Byrd, 1977, treatment discontinuation was due to “symptomatology,” which included hepatotoxicity and mild nausea/abdominal cramps. For Ferebee, 1963, discontinuation due to adverse events corresponded to participants stopping medication due to being “sick” from pills.

Abbreviations: CI=confidence interval; INH=isoniazid; IUAT=International Union Against Tuberculosis; RR=relative risk.

Appendix F Figure 28 displays a forest plot reporting the relative risk of treatment discontinuation due to adverse event in those treated with isoniazid versus those treated with placebo. The pooled estimate of the four studies presented a relative risk is 1.56 (95% CI, 1.00 to 2.49).

Appendix F Figure 29 Isoniazid Compared With Rifampin: Relative Risk of Developing Hepatotoxicity, Data From Three Randomized, Controlled Trials

Abbreviations: CI=confidence interval; INH=isoniazid; RR=relative risk.

Appendix F Figure 29 displays a forest plot reporting the relative risk of developing hepatotoxicity in those treated with isoniazid versus those treated with rifampin. The pooled estimate of the three included studies presented a relative risk of 4.22 (95% CI, 2.21 to 8.06).

Appendix F Figure 30 Isoniazid Compared With Rifampin: Relative Risk of Treatment Discontinuation Due to Adverse Events, Data From Three Randomized, Controlled Trials

Abbreviations: AE=adverse event; CI=confidence interval; INH=isoniazid; RIF=rifampin; RR=relative risk.

Appendix F Figure 30 displays a forest plot reporting the relative risk of treatment discontinuation due to adverse events in those treated with isoniazid versus those treated with rifampin. The pooled estimate of the three studies presented a relative risk of 2.25 (95% CI, 0.90 to 5.59).