# Appendix E Quality Ratings

Appendix E Table 1 Quality Ratings for Studies of Accuracy and Reliability of Screening Tests for TB (KQ 2)

First Author, Year | Were selection criteria (for patients) clearly described? | Was the spectrum of patients included in the study representative of the patients who will receive the test in primary care? | Were withdrawals and missing data from the study adequately explained or not present? | Was the screening test relevant and adequately described? | Was the reference test performed regardless of screening test result? | Were the reference standard and screening test interpreted independently (i.e., each test interpreted blinded to the result of the other)? | Were methods for calculating accuracy (e.g. sensitivity/specificity) clearly reported and valid? | Did the study provide raw data on indeterminate results or enough information to understand how indeterminate results were handled? | Quality Rating
Adetifa, 2007^136^ | Partially | NA | Partially | Partially | Yes | NR | NA | Yes | Fair
Aggerbeck, 2019^79^ | Yes | NA | Yes | Yes | Yes | NR | Yes | Yes | Fair
Ak, 2009^75^ | Yes | NA | NA | Yes | Yes | NR | Yes | Yes | Good
Akashi, 2020^119^ | Yes | NA | Yes | Yes | Yes | NR | Yes | Yes (in the discussion) | Fair
Altet, 2017^78^ | Yes | NA | NR | Yes | Yes | NR | Yes | Yes | Fair
Bae, 2016^102^ | Yes | NA | NR | Yes | Yes | NR | Yes | Yes | Fair
Balcells, 2018^216^ | Yes | NA | No; high missing data for the portion relevant for this review and is not explained (38/72 missing) | Yes | Yes | NR | No (unclear why many active TB cases were not in the calculations for positive cases) | No | Poor
Bellete, 2002^64^ | Partially | Yes | Yes | Yes | NA | NA | NA | NA | Fair
Berkel, 2005^61^ | Yes | No | NA | No | No | NR | Partially | NA | Fair
Bienek, 2009^72^ | Yes | Partially | Yes | Yes | NA | NR | Partially | Yes | Fair
Bocchino, 2010^66^ | Partially | NA | NA | No | Yes | NR | NA | Yes | Fair
Boyd, 2011^91^ | Yes | NA | NA | Yes | Yes | Yes | Yes | Yes | Good
Bua, 2007^217^ | No | NR | NA | Partially | NA | NR | NA | Yes | Fair
Chedid, 2020^218^ | Partially | NA | No | Yes | Yes | NR | NA | No | Poor
Chee, 2008^89^ | Yes | NA | Yes | Yes | Yes | NR | NA | Yes | Good
Chen, 2016^219^ | No (retrospective, and all it provides is “consecutive pregnant women with suspected TB”) | NA | No | No (no description of how testing was done) | NR | NR | NA | No | Poor
Cho, 2011^90^ | Yes | NA | NA | Partially | Yes | Yes | Yes | Yes | Good
Choi, 2015^80^ | Yes | NA | NR | Yes (but QFT-G is not eligible) | NR | NR (but unlikely in retrospective study) | NA (raw data given) | Yes (13 persons excluded for indeterminate results) | Fair
Cummings, 2009^157^ | No | Partially | No | Yes | NA | NR | No | Yes | Poor
Dewan, 2007^220^ | Yes | NA | Partially | Yes | Yes | NR | Yes | Yes | Fair
Di, 2018^101^ | Yes | NA | Yes | Yes | Yes | NR | NA (raw data given) | No | Fair
Dilektasli, 2010^74^ | Yes | Partially | Yes | Partially | Yes | Partially | NA | Yes | Fair
Dorman, 2014^151^ | Yes | No | Yes | Yes | NA | NR | Yes | Yes | Good
Du, 2018^100^ | Yes | NA | Yes | Yes | Yes | NR | NA (raw data given) | Yes (indeterminate number reported) | Fair
Erdem, 2014^138^ | No | NA | NA | Yes | No | NR | No | NR | Fair
Eum, 2008^221^ | Partially | NA | No | Yes | Yes | NR | Partially | No | Poor
Feng, 2013^127^ | Partially | NA | Yes | Yes | Partially | NR | NA | Yes | Fair
Fietta, 2003^63^ | Yes | Yes | NA | Yes | NR | NR | NA | NA | Fair
Franken, 2007^222^ | No | No | No | Partially | NA | NR | Partially | No | Poor
Franken, 2009^155^ | Yes | Partially | NA | Yes | NA | NR | NA | Yes | Fair
Fukushima, 2021^125^ | Yes | NA, NR | Yes | Yes | Yes | NR | NA | Yes | Good
Goletti, 2006^87^ | Yes | NA | NR | Partially | Yes | Yes | Yes | Partially | Fair
Han, 2016^223^ | No | NA | No | No (not adequately described) | NR | NR | NA (raw data reported) | No | Poor
Harada, 2008^134^ | Yes | NA | NA | Yes | Yes | NR | NA | Yes | Good
He, 2015^224^ | Yes | NA | Yes | Yes | Yes | NR | Partially | No | Fair
Higuchi, 2009^96^ | Partially | NA | Yes | Yes | Yes | NR | NA | Yes | Fair
Hoff, 2016^77^ | Yes | NA | Yes | Yes | Yes | NR (double-blind between TST and another skin test that was not eligible, but NR for our comparisons of interest) | NA (raw data reported) | Yes | Fair
Hoffmann, 2016^118^ | Yes | NA | Yes | Yes | NR | NR | NA (raw data reported) | Yes (they call them invalid) | Fair
Horne, 2018^117^ | Yes | NA | NR | Yes | Yes | NR | NA (raw data reported) | Yes | Fair
Huang, 2019^148^ | Partially, unclear timing of testing with respect to treatment | NA | Yes | Yes | Yes | NR | NA | Yes | Fair; blinding NR
Janssens, 2007^88^ | Yes | NA | NA | Yes | Yes | NR | Yes | No | Fair
Jeon, 2013^129^ | Yes | NA | NA | Yes | Yes | NR | NA | No | Fair
Jeon, 2017^143^ | Partially, unclear timing of testing with respect to treatment | NA | Unclear, retrospective analysis based on available data | Yes | Yes | NR | NA | Yes | Fair; blinding NR, unclear missing data
Jung, 2021^125^ | Yes | NA | Yes | Yes | Yes | NR | NA | Yes | Good
Kalantri, 2009^225^ | No | NA | NA | Yes | Yes | NR | NA | No | Poor
Kamiya, 2013^226^ | No | NA | Partially | Yes | Partially | NR | Yes | NA | Poor
Kang, 2005^57^ | Partially | NA | NR | Yes | Partially | No | Partially | Yes | Fair
Kang, 2007^227^ | Partially | NA | NA | Partially | Partially | NR | No | No | Poor
Kang, 2018^99^ | Yes | NA | Yes; not present | Yes | Yes | NR | NA, raw data provided | NR | Fair
Katsenos, 2010^70^ | Yes | Partially | NA | Yes | NA | Yes | Yes | Yes | Good
Kiazyk, 2016^144^ | Yes | NA | Yes | Yes | Yes | NR | NA | Yes | Fair; blinding NR
Kim, 2011^60^ | Yes | NA | NA | Yes | Yes | NR | NA | Partially | Good (QFT-GIT) Poor (TST)
Kim, 2013^131^ | Partially | Yes | NA | Yes | Partially | NR | Yes | Yes | Fair
Kim, 2014^139^ | Yes | NA | Yes | Yes | Yes | NR | Yes | Yes | Good
Kim, 2018^112^ | Yes | NA | Yes | Yes | Yes | Yes | NA | Yes | Good
Kobashi, 2008^228^ | Partially | NA | Yes | Yes | Yes | NR | NA | Yes | Fair
Kobashi, 2008^229^ | Partially | NA | NA | Yes | Yes | NR | NA | Yes | Fair
Kobashi, 2008^97^ | Yes | NA | NA | Yes | Yes | NR | NA | Yes | Good
Kobashi, 2009^230^ | No | NA | NA | Partially | Yes | NR | NA | No | Poor
Kobashi, 2009^231^ | Partially | NA | NA | Yes | Yes | NR | No | Partially | Fair
Kobashi, 2012^98^ | Yes | NA | Yes | Partially | Yes | NR | Yes | Yes | Fair
Kwon, 2015^146^ | Yes | NA | Unclear; retrospective analysis with QFT testing up to individual clinician | Yes | Yes | NR | NA | Yes | Fair; blinding NR, unclear missing data
La Distia Nora, 2018^232^ | Yes | NA | No (data missing for 21% of TST) | Yes | No (micro exams only done in selected cases) | NR | NA | NA | Poor; missing data; lack of blinding, not all persons got same reference standard
Lai, 2011^85^ | Partially | NA | NA | Partially | Yes | NR | NA | Yes | Fair
Lai, 2011^92^ | Partially | No | NA | Yes | Yes | NR | Yes | Yes | Fair
Lee, 2011^233^ | Partially | No | NA | Partially | Yes | NR | NA | NR | Fair
Lee, 2012^132^ | Partially | NA | NA | Yes | Yes | Yes | Yes | Yes | Good
Lee, 2019^120^ | Yes | NA | Yes; not present | Yes | Yes | NR | NA, raw data provided | Yes, raw data and enough information on handling | Fair
Lee, 2021^124^ | Yes | NA | Yes | Yes | Yes | NR | NA | Yes | Fair
Legesse, 2010^135^ | Yes | No | NA | Yes | Yes | NR | Yes | Yes | Fair
Lempp, 2015^140^ | No | NA | NA | Yes | No | NR | No | NR | Fair
Li, 2012^234^ | Partially | NA | NA | Partially | No | Partially | Yes | Yes | Poor
Li, 2019^235^ | Partially; timing of testing with respect to treatment was NR | NA | No (retrospective analysis and 23% of subjects were missing T-SPOT.TB tests) | Yes | Yes | NR | NA | Yes | Poor; missing data, blinding NR
Lian, 2017^113^ | Partially; unclear timing of testing with respect to treatment | NA | Yes | Yes | Yes | NR | NA | Yes | Fair; blinding NR
Liu, 2020^236^ | Yes | NA | Partially | Yes | Unclear | NR | No | No | Poor
Liu, 2021^237^ | Yes | NA | No; high missingness | Yes | Yes; required in inclusion criteria | NR | NA | Partially | Poor
Lombardi, 2019^142^ | Yes | NA | Yes | Yes | Yes | NR | NA | Yes | Fair; blinding NR
Losi, 2007^86^ | Partially | NA | NA | Partially | Yes | NR | Yes | Partially | Fair
Lui, 2011^238^ | Yes | No | NA | Yes | Partially | Partially | Yes | Yes | Fair
Mancuso, 2012^54^ | Partially | No | Yes | Yes | NA | Yes | Partially | No | Fair
Manngo, 2019^123^ | Yes | NA | Yes | Yes | Yes | Unclear | NA | Yes | Fair
Mazurek, 2001^65^ | Yes | Yes | NA | Yes | NA | NA | NA | NA | Good
Mazurek, 2007^55^ | Yes | NA | Yes | Yes | Yes | NR | Yes | Yes | Good
Mazurek, 2007^56^ | Yes | Yes | Yes | Yes | NA | NR | No | No | Fair
Memish, 2000^239^ | No | NA | NA | No | NR | NR | NA | NA | Poor
Metcalfe, 2010^240^ | Yes | NA | Yes | Yes | Partially | NR | Partially | Yes | Fair
Min, 2013^128^ | No | NR | NA | Yes | Yes | NR | Yes | Partially | Poor (Sp) Fair (Sn)
Niguse, 2018^141^ | Yes | NA | No | Yes | Yes | NR | NA | Yes | Fair; 213 enrolled, but only 202 described in the analysis without any explanation; blinding NR
O’Shea, 2014^156^ | Yes | No | NA | Yes | Yes | NR | Yes | Partially | Fair
Ozekinci, 2007^241^ | Partially | Yes | NA | No | Yes | NR | No | Yes | Poor
Pai, 2007^133^ | Yes | NA | Yes | Yes | Yes | NR | Yes | Yes | Good
Painter, 2013^53^ | Yes | NA | Partially | Yes | Yes | Yes | Partially | No | Fair
Palazzo, 2008^242^ | Partially | Partially | No | No | Yes | NR | Partially | No | Poor
Pan, 2015^109^ | Yes | NA | Yes | Yes | Yes | NR | NA | Yes (appears no indeterminates were observed) | Fair; blinding NR
Park, 2009^71^ | Partially | Partially | Yes | Partially | Partially | NR | Partially | Yes | Fair
Park, 2017^83^ | Yes | NA | Unclear, retrospective analysis so only persons with data available were included | Yes for T.SPOT.TB; no for TST | Yes | NR | NA | No | Fair; blinding NR; no description of TST; retrospective analysis so no data on withdrawals/missing data
Pasticci, 2021^243^ | Yes | NA | No | Yes | Yes | NR | NA | No | Poor
Pathakumari, 2015^147^ | Partially (limited information provided, specifically timing of testing vs. starting of treatment) | NA | Yes | Yes | Yes | NR | NA | Yes | Fair; blinding NR; limited information about study subjects
Peña, 2015^84^ | Yes | NA | Yes | Yes | Yes | No (administered by medical staff so unlikely they would have been blinded) | NA | NA | Fair; lack of blinding
Piotrowski, 2018^244^ | Partial | Partial | Yes | Yes | NA | NR | NA | No; although methods state they looked at indeterminate results, only positives and negatives were reported. | Poor; a small sample, handling of indeterminate results could have major effect on estimate
Qian, 2013^126^ | Yes | NA | NA | Yes | Yes | NR | NA | No | Fair
Qiu, 2015^111^ | Yes | NA | Yes | Yes | No | Yes | NA | Yes | Fair; appears less than half met bacteriologic criteria
Ra, 2011^245^ | Partially | No | NA | Partially | Yes | NR | No | Yes | Fair (QFT-G) Poor (TST)
Ruhwald, 2011^93^ | Yes | Partially | NA | Yes | Yes | NR | NA | Yes | Good
Salindri, 2019^246^ | Partially (retrospective analysis so no information on timing of testing with respect to treatment) | NA | No (only 68% had TST results and additional persons excluded for incomplete followup with respect to treatment outcomes) | Yes | Yes | No (retrospective study so staff administering TST unlikely to have been blinded to status) | NA | NA | Poor
Seibert, 1991^69^ | Partially | NA | Partially | Yes | Yes | NR | NA | NA | Fair
Shalabi, 2009^247^ | Partially | NR | NA | No | Yes | NR | NA | NA | Poor
Shangguan, 2020^116^ | Yes | NA | Yes; adequately explained ~10% | Yes | Yes; required in inclusion criteria | NR | NA | Yes | Fair
Shrestha, 2011^248^ | No | NA | NA | Partially | Yes | NR | NA | Yes | Poor
Siegel, 2018^122^ | Yes | Yes | Yes | Yes | NA | NR | NA | Yes | Fair; blinding NR
Soysal, 2008^73^ | Yes | Partially | No | Yes | Yes | NR | Partially | Partially | Fair
Sun, 2016^110^ | Yes | NA | Yes | Yes | Yes | NR | NA | Yes | Fair; blinding NR
Taggart, 2004^62^ | Partially | Yes | Yes | Yes | NA | NA | NR | NA | Fair
Taggart, 2006^59^ | Yes | Partially | NA | Yes | NA | NR | Partially | No | Fair
Takasaki, 2018^106^ | Yes | No; TB-specific hospital, mostly female, mostly young | Yes; not present | Yes | Yes | NR | NA; raw data provided | Yes; adequately explained | Fair
Takeda, 2020^105^ | Partially | NA | Yes; not present | Partially; yes for T-SPOT.TB, unclear for IGRAs | Yes | NR | NA; raw data provided | Yes; indeterminate results were excluded, but only 3% of total | Fair
Taki-Eddin, 2012^137^ | Partially | NA | NA | Yes | Yes | NR | NA | NR | Fair
Takwoingi, 2019^103^ | Yes | NA | Yes; adequately explained | Yes | Yes | Yes | NA; raw data provided | Yes; adequately explained | Good
Tan, 2010^95^ | Partially | NA | NA | Yes | Yes | NR | NA | Yes | Fair
Tang, 2020^249^ | Partially | NA | No; study merely states missing data were “due to the influence of objective conditions and personal will of subjects.” Only 30 of 37 ATB had QFT+ results. | Yes | Yes | NR | No | No | Poor; missing data not explained; most of population was HCWs, no information on blinding of test interpreters
Telisinghe, 2017^250^ | Yes | NA | Yes; not present | Yes | Yes | NR | NA; raw data provided | Yes | Fair
Tsiouris, 2006^58^ | Yes | NA | NR | Yes | Yes | Yes | Yes | Yes | Good
Turtle, 2012^251^ | No | NA | Partially | Partially | NR | NR | No | No | Poor
Villarino, 1999^68^ | Partially | Partially | Yes | Yes | NA | Partially | NA | Partially | Fair
Villarino, 2000^67^ | Partially | Partially | Yes | Partially | NA | Yes | NA | Yes | Fair
Walsh, 2011^94^ | Yes | NA | NA | Partially | NR | NR | No | Yes | Fair
Wang, 2013^130^ | Yes | NA | NA | Yes | Yes | NR | Yes | No | Fair
Wang, 2015^252^ | Partially | NA | Partially | Yes | No | NR | NA; raw data provided | Yes; indeterminate results were excluded, but <3% of cases | Poor
Wang, 2018^108^ | Yes | NA | Yes | Yes | Yes | Yes | NA | Yes | Good
Wang, 2018^253^ | Yes | NA | Yes; not present | Yes | Yes | NR | NA; raw data provided | No; indeterminate results were excluded from the start, unclear how many | Fair
Warria, 2020^254^ | Yes | NA | No; too high, 24.5% missing for TST | Yes | Yes | NR | NA; raw data provided | Unclear | Poor
Waruk, 2015^145^ | Partially, Unclear timing of testing with respect to treatment | NA | Yes | Yes | Yes | NR | NA | Yes | Fair; blinding NR
Wawrocki, 2019^255^ | Partially | Partially | Yes; not present | Partially | Yes | NR | NA; raw data provided | NR | Poor
Whitworth, 2012^149^ | Partially | NA | NA | Yes | Yes | NR | Yes | Yes | Good
Whitworth, 2014^150^ | Partially | Yes | NA | Yes | NA | NR | Yes | Yes | Fair
Whitworth, 2019^114^ | Yes | NA | Yes | Yes | Yes | Yes | NA | Yes | Fair
Wlodarczyk, 2014^76^ | Partially | Partially | Yes | Yes | NA | NR | Yes | Yes | Good
Xu, 2017^256^ | Yes | NA | Yes; not present | Yes | Yes | NR | NA; raw data provided | Yes; raw data | Fair
Xuan, 2017^104^ | Partially | NA | Partially | Yes | Yes | NR | NA; raw data provided | Yes; indeterminate results were excluded, but <2% of cases | Fair for T.SPOT.TB Poor for TST
Yi, 2016^121^ | Yes | Yes | Yes; adequately explained | Yes | Yes | NR | Yes | Yes; indeterminate results were excluded, but only 3% of cases | Fair; blinding NR
Yu, 2015^82^ | Yes | NA | Yes; not present | Yes | Yes | Yes | NA; raw data provided | NA | Good
Zhang, 2017^107^ | Yes | NA | Yes; adequately explained | Yes | Yes | Yes | NA; raw data provided | Yes, indeterminate results were excluded, but only 5.2% of cases | Good
Zhu, 2019^81^ | Partially | NA | Yes | Yes | Yes | NR | NA | Yes | Fair; blinding NR

Abbreviations: ATB=active tuberculosis; HCW=healthcare worker; KQ=key question; NA=not available; NR=not reported; QFT=QuantiFERON-TB; QFT-G=QuantiFERON TB Gold test (2nd generation test); QFT-GIT=QuantiFERON-TB Gold-In-Tube test (3rd-generation test); Sp=specificity; Sn=sensitivity; TB=tuberculosis; T-SPOT.TB=commercial ELISPOT assay; TST=tuberculin skin test; vs.=versus.

Appendix E Table 2 Quality Ratings for Randomized, Controlled Trials (KQs 3 and 5): Main Analysis, Part 1

First Author, Year Trial Name N | Was randomization adequate? | Was allocation concealment adequate? | Were groups similar at baseline? | Was adherence to the intervention adequate? | What was the overall attrition? | What was the differential attrition?
Denholm, 2017^257^; SIRCLE; 80 | Yes | Unclear | Partially; authors did not do the statistical comparison but a few characteristics look different (female, ALT, region, and immunosuppression) | Likely; suggest that 85% 9H group and 90% 3HP group “completed therapy”; however, the mean time to discontinuation is relatively short compared with the treatment duration | Did not complete: 10 (12.5) | Did not complete: 9H: 6 (15%) 3HP: 4 (10%); Differential attrition rate: 5%
Gao, 2018^180^; 3,738 | Yes (detail in supplement) | Yes | Yes, for most characteristics (although, statistically significant difference for pulmonary fibrotic lesions, small magnitude, of unclear clinical significance) | Probably yes (85% completed the modified regimen A); although high frequency of adverse effects limited completion of LTBI regimens for many | Unclear for 2-year outcomes (NR in study flow diagram); for short term harms data, they report 2.6% (33/1,284) unreachable in Group A and 3.9% (51/1,299) unreachable in Group B. | Unclear for 2-year outcomes
Menzies, 2004^176^; 116 | Yes | Partially | Yes | Yes, RIF: 53 (91) took 80% of doses, 50 (86) took more than 90% of doses within 20 weeks INH: 44 (76) took 80% of doses; 36 (62) took 90% doses for 43 weeks; 80% doses: RR: 1.2 (95% CI, 1.02 to 1.4) 90% of doses: RR: 1.4 (95% CI, 1.1 to 1.7) | Did not complete: 19 (16.4); Dropout/default: 9 (7.8) RR: 0.5 (95% CI, 0.1 to 1.9) | Total did not complete:; RIF: 5 (9); INH: 14 (24); Dropout/default:; RIF: 3 (4); INH: 6 (10); RR: 0.5 (95% CI, 0.1 to 1.9)
Menzies, 2008^159^; 847 | Yes | Yes | Yes | Yes | Not included in primary analyses for serious AEs: 8 (0.9%); Stopped therapy early and were followed; nonprotocol adherent: 205 (24%); Stopped therapy early and were followed; protocol adherent: 45 (5.3%); Did not complete therapy: 264 (31%) | Not included in primary analyses for serious AEs:; RIF 2 (0.5%); INH 6 (1.4%); Stopped therapy early and were followed; nonprotocol adherent:; RIF 72 (17%); INH 133 (31%); Stopped therapy early and were followed; protocol adherent:; RIF 17 (4.0%); INH 28 (6.6%); Did not complete therapy:; RIF 92 (22%); INH 172 (40%)
Menzies, 2018^160^; 6,012 | Yes | Unclear | Yes | Partially INH: 1,890 (63.2) took 80% of doses, 1,099 (36.8) took <80% of doses; RIF: 2,382 (78.8) took 80% of doses, 641 (21.2) took <80% of doses | Treatment not completed for any reason: 1,740 (28.9); Death during treatment: 3 (0.1); Diagnosis of active TB: 2 (<0.1); Treatment stopped permanently for Grade 1–4 event: 211 (3.5); Treatment started, but participant decided to stop: 1,208 (20.1) | Treatment not completed for any reason:; INH: 1,099 (36.8); RIF: 641 (21.2); Differential: 15.6; Death during treatment:; INH: 3 (0.1); RIF: 0 (0); Differential: 0.1; Diagnosis of active TB:; INH: 1 (<0.1); RIF: 1 (<0.1); Differential: 0; Treatment stopped permanently for Grade 1–4 event:; INH: 143 (4.8); RIF: 68 (2.2); Differential: 2.6; Treatment started, but participant decided to stop:; INH: 772 (25.8); RIF:436 (14.4); Differential: 11.4
Sterling, 2011^161^*; PREVENT TB; 6,886 | Partially | NR | Yes | Yes | Treatment completion:* 2,895 (80.8%) 2,264 (68.2%) | Differential treatment completion:* 12.6%
Sterling, 2015^178^; PREVENT TB; 7,552 | Yes | Yes | Yes | Yes; Overall: 75.8%; 9H: 69.0%; 1,160 did not complete regimen/3,745 eligible for MITT; 3HP: 82.2% 713 did not complete regimen/3,986 eligible for MITT | Did not complete 33 months of followup: 1,008 (13.0%) | Differential attrition: 2%; Did not complete 33 months of followup:; 9H: 450 (12.0%); 3HP: 558 (14.0%)
Sun, 2018^162^; 263 | Yes | Yes | Yes | Yes; Poor adherence:; 3HP: 0 (0); 9H: 16 (12.2) | Noncompletion: 33 (12.5); Adverse drug reactions: 19 (7.2); Consent withdrawal: 24 (9.1) | Noncompletion:; 3HP: 14 (10.6); 9H: 29 (22.1); Differential: 11.5; Adverse drug reactions:; 3HP: 12 (9.1); 9H: 7 (5.3); Differential: 3.8; Consent withdrawal:; 3HP: 2 (1.5); 9H: 22 (16.8); Differential: 15.3
Surey, 2021^179^; HALT LTBI pilot study; 52 | Yes | Unclear | Partially; Groups looked mostly similar but no formal statistical comparison. Authors say “no evidence of major imbalance.” | Yes; 76.9% received at least 90% of prescribed doses | Failed to complete trial: 12 (23.1) | Failed to complete trial:; 3HP: 6 (22.2); 3HR: 6 (24)
Thompson, 1982^158^; IUAT; 27,830 | Yes | Yes | Unclear | Yes | 5-year followup not complete for 781 (2.8%) | <5%
White, 2012^177^; 364 | Yes | Partially | Yes | No; nearly 1/2 participants started on either INH or RIF were lost to followup by transfer to another facility or deportation; Adherence higher for those who remained in jail:; RIF: (79); INH: (83) | Did not complete: 257 (70.6) | Did not complete:; RIF:120 (66.7); INH: 137 (74.5); Lost/withdrawn:; RIF: 33 (18.3); INH: 44 (23.9); Deported/transferred:; RIF: 85 (47.2); INH: 93 (50.5); Withdrawn by physician:; RIF: 2 (1.1); INH: 0 (0)

Abbreviations: 3HP=rifapentine plus INH; 3HP=3 months of weekly INH and RIF; 9H=9 months of daily directly observed INH alone; AE=adverse event; ALT=alanine aminotransferase; CI=confidence interval; INH=isoniazid; IUAT=International Union Against Tuberculosis; KQ=key question; LTBI=latent tuberculosis infection; MITT=modified intention to treat; NR=not reported; RIF=rifampin; RR=relative risk; SIRCLE=short-court isoniazid and rifapentine for cost-effective latent tuberculosis eradication trial; TB=tuberculosis.

Appendix E Table 3 Quality Ratings for Randomized, Controlled Trials (KQs 3 and 5): Main Analysis, Part 2

Author, Year Trial Name N | Were outcome measurements equal, valid, and reliable? | Were patients masked? | Were providers masked? | Were outcome assessors masked? | Was the duration of followup adequate to assess the outcome? | Was an appropriate method used to handle missing data? | Did the study use an ITT analysis? | Did the study use acceptable statistical methods? | Quality Rating | Comments
Denholm, ^257^; SIRCLE; 80 | Unclear | No | No | No | Unclear | Unclear | Unclear | Unclear | Poor | Lack of masking; unclear allocation concealment; focus of study is on cost analysis and not on our outcomes of interest; unclear outcome ascertainment methods (not described)
Gao, 2018^180^; 3,738 | Yes | No (open label) | No | Yes (expert panel was blinded to treatment assignment) | Yes | Unclear | Yes (and had a per-protocol analysis) | Yes | Fair | Open label; study planned for 3-month regimen but shortened it because of adverse effects
Menzies, ^176^; 116 | Yes | No | No | No | No | Yes | Yes | Yes | Fair | Open label; authors stated unblinded study justified because the primary study outcome, treatment completion, was likely strongly influenced by duration of therapy; Primary outcome % prescribed doses taken as measured by electronic device in the pill container cap; patient compliance may be overestimated; Duration of treatment may have influenced judgment of severity of more subjective AEs (e.g., fatigue, nausea)
Menzies, ^159^; 847 | Yes | No | No | Yes; blinded review panel | Yes | Yes | Yes | Yes | Good | Open label, but used fairly rigorous methods with masked review panel to ascertain AEs
Menzies, ^160^; 6,012 | Yes | No | No | Partially | Yes | Unclear | Yes | Yes | Fair | Note: This study included data from the Phase 2 and Phase 3 trials, some from ineligible countries
Sterling, ^161^; PREVENT TB; 6,886 | Yes | NR | NR | NR | Yes | Yes | Yes | Yes | Fair | Masking unclear and higher overall attrition
Sterling, ^178^; PREVENT TB; 7,552 | Yes | No | No | No | Yes | Unclear | Yes (based on previous study) | Yes | Fair | Used an older paper from this trial for much of this information
Sun, ^162^; 263 | Yes | No | No | No | Yes | Unclear | Yes | Yes | Fair | Differential attrition, mostly due to poor adherence but likely a product of the different length of treatments
Surey, ^179^; HALT LTBI pilot study; 52 | Yes | No | No | No | Yes | Unclear | No | Partially | Fair | Some lack of information on the analysis
Thompson, ^158^; IUAT; 27,830 | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Yes | Good (for KQ 3) Fair (for KQ 5) | -
White, ^177^; 364 | Yes | No | No | No | No | Yes | Yes | Yes | Fair | Open label; nearly half of participants started on either INH or RIF were lost to followup by transfer to another facility or deportation. However, those who remained in jail had higher adherence

Abbreviations: AE=adverse event; INH=isoniazid; IUAT=International Union Against Tuberculosis; KQ=key question; LTBI=latent tuberculosis infection; NR=not reported; RIF=rifampin; SIRCLE=short-court isoniazid and rifapentine for cost-effective latent tuberculosis eradication trial; TB=tuberculosis.

Appendix E Table 4 Quality Assessment of Systematic Reviews, Network Meta-Analyses, and IPD Meta-Analyses (KQs 3, 5)

First Author, Year | Were the study eligibility criteria adequate? | Were the methods of study identification and selection adequate? | Was data collection adequate? | Were the synthesis methods adequate? | Quality Rating
Zenner, 2017^163^ | Yes | Yes | Yes | Yes | Good

Abbreviations: IPD=individual patient data; KQ=key question.

Appendix E Table 5 Additional Quality Ratings for Randomized, Controlled Trials for Harms (KQ 5)

First Author, Year Trial Name N | Were harms prespecified and defined? | Were ascertainment techniques for harms adequately described? | Were ascertainment techniques for harms equal, valid, and reliable? | Was duration of followup adequate for harms assessment? | Harms Quality Rating | Comments
Denholm, ^257^; SIRCLE; 80 | Unclear | No | Unclear | Yes | Poor | Lack of masking; unclear allocation concealment; focus of study was on cost analysis and not on the outcomes of interest; unclear outcome ascertainment methods (not described); insufficient description of analysis
Gao, ^180^; 3,738 | Yes | Yes | Yes | Yes | Fair | Open label; study planned for 3-month regimen but shortened it because of adverse effects
Menzies, ^176^; 116 | Yes | Yes | Partially | No | Fair | Followup likely insufficient; some AEs subject to judgment of severity (e.g., fatigue, nausea)
Menzies, ^159^; 847 | Yes | Yes | Yes | Yes | Good | -
Menzies, ^160^; 6,012 | yes | Yes | Yes | Yes | Fair | Open label; unclear allocation concealment
Sterling, ^161^; PREVENT TB; 6,886 | Yes | Yes | Yes | Yes | Fair | -
Sterling, ^178^; PREVENT TB; 7,552 | yes | Yes | Unclear | Yes | Fair | Open label; used Naranjo scale (but modified it), defined what is considered severe; unclear if ascertainment techniques were equal across study arms because classification of whether adverse effects were attributed to medications was determined by local prescribing physicians
Sun, ^162^; 263 | Yes | Yes | Yes, valid and reliable; not equal because monitoring certain blood tests for adverse effects was during treatment (and treatment duration differed for the groups, 3 months vs. 9 months) | Adequate during treatment, but no posttreatment assessment described | Fair | Open label; used Naranjo scale with defined cutoffs; also defined clinically relevant hepatic elevations
Surey, ^179^; 52 | Yes | Yes | Yes | Yes | Fair | Open label; unclear if ascertainment techniques were equal across study arms because classification of whether adverse effects were related to study regimen was determined by prescribing physicians
Thompson, ^158^; IUAT; 27,830 | Partially; INH-induced hepatotoxicity was prespecified; NR how it was defined; unclear for other harms | Partially; specific criteria for ascertaining/confirming hepatotoxicity NR | They were equal. Unclear how valid and reliable (dispensary staff were told to be particularly alert for symptoms of INH-induced hepatitis; participants were advised to call the dispensary if they had any unexpected reactions) | Yes | Fair | -
White, ^177^; 364 | Yes | Yes | Yes | No | Fair | Nearly one half of participants who started were lost to followup by transfer to another facility or deportation, thus unable to adequately track harms

Abbreviations: AE=adverse event; INH=isoniazid; IUAT=International Union Against Tuberculosis; KQ=key question; NR=not reported; TB=tuberculosis.

Appendix E Table 6 . Quality Ratings for Observational Studies for Harms (KQ 5): Main Analysis, Part 1

Author, Year Trial Name N | Were eligibility criteria clearly described? | Were subjects representative of the overall source population? | Did the study apply inclusion/exclusion criteria uniformly to all comparison groups of the study? | Did the study avoid inappropriate exclusions? | Is the selection of the comparison group appropriate, after taking into account feasibility and ethical considerations? | Did the study guard against risk of survivor bias? | Were groups similar at baseline? | Were outcome assessors masked to the exposure status of participants? | What was the differential attrition? | Did the study have a high attrition raising concern for bias?
Schein, ^258^ | Partially | No | NR | Yes | Yes | Yes | NR | No | 0 | No

Abbreviations: KQ=key question; N=number; NR=not reported.

Appendix E Table 7 Quality Ratings for Observational Studies for Harms (KQ 5): Main Analysis, Part 2

Author, Year Trial Name N | Were harms pre-specified and defined? | Were ascertainment techniques for harms adequately described? | Were ascertainment techniques (outcome measures) for harms equal, valid, and reliable? | Was the duration of followup adequate to assess the outcome? | Does the analysis control for baseline differences between groups? | Does the analysis control for potential confounders? | Was an appropriate method used to handle missing data? | Did the study use appropriate statistical methods? | Quality Rating | Comments
Schein, 2018^258^ | NR | No | NR | Yes | No | No | Yes | Yes | Poor | Unclear inclusion criteria; no masking of outcomes assessors; unclear process of collection of harms data; partial harms data reported only (only if it led to treatment interruption or termination)

Abbreviations: KQ=key question; N=number; NR=not reported.