# Appendix D Evidence Tables

Appendix D Table 1 Studies of Sensitivity of TST for TB (KQ 2)

Appendix D Table 2 Studies of Sensitivity of IGRA Tests for TB (KQ 2)

Appendix D Table 3 Studies of Specificity of TST for TB (KQ 2)

Appendix D Table 4 Studies of Specificity of IGRA for TB (KQ 2)

Appendix D Table 5 Studies of Reliability of Screening Tests for Tuberculosis (KQ 2)

Appendix D Table 6 Characteristics of Included Randomized, Controlled Trials (KQs 3, 5), Main Analysis

Appendix D Table 7 Characteristics of Randomized, Controlled Trials Used Only in Sensitivity Analyses for Benefits (KQ 3)

Appendix D Table 8 Results of Included Randomized, Controlled Trials for Benefits (KQ 3), Main Analysis

Appendix D Table 9 Results of Included Randomized, Controlled Trials for Harms (KQ 5), Main Analysis