# Appendix C Excluded Studies

X1: Not Original Research

X2: Ineligible Population

X3: Ineligible Intervention

X4: Ineligible Comparator

X5: Ineligible Outcomes

X6: Ineligible Study Design

X7: Ineligible Language

X8: Ineligible Country

X9: Poor Quality

1 Adams S, Ehrlich R, Baatjies R, Evaluating latent tuberculosis infection test performance using latent class analysis in a TB and HIV endemic setting. Int JEnviron Res Public Health. 2019 Aug 14; 16(16)doi: 10.3390/ijerph16162912. PMID: 31416206. Exclusion Code: X2.31416206
2 Adane K, Spigt M, Dinant GJ. Tuberculosis treatment outcome and predictors in northern Ethiopian prisons: a five-year retrospective analysis. BMC Pulm Med. 2018 Feb 20;18(1):37. doi: 10.1186/sl2890-018-0600-1. PMID: 29463234. Exclusion Code: X2.29463234
3 Agarwal S, Nguyen DT, Lew JD, Discordance between the QuantiFERON Gold In-Tube and QuantiFERON Gold Plus assays associated with country of birth TB incidence. Tuberculosis (Edinb). 2019 May;116s:S2–s10. doi: 10.1016/j.tube.2019.04.005. PMID: 31060960. Exclusion Code: X5.31060960
4 Agarwal S, Nguyen DT, Lew JD, Differential positive TSPOT assay responses to ESAT-6 and CFP-10 in health care workers. Tuberculosis (Edinb). 2016 Dec;101s:S83–s91. doi: 10.1016/j.tube.2016.09.012. PMID: 27727133. Exclusion Code: X2.27727133
5 Ahmed A, Feng PI, Gaensbauer JT, Interferon-γ release assays in children <15 years of age. Pediatrics. 2020 Jan; 145(1)doi: 10.1542/peds.2019-1930. PMID: 31892518. Exclusion Code: X2.31892518
6 Allahyartorkaman M, Mirsaeidi M, Hamzehloo G, Low diagnostic accuracy of Xpert MTB/RIF assay for extrapulmonary tuberculosis: A multicenter surveillance. Sci Rep. 2019 Dec 6;9(1):18515. doi: 10.1038/s41598-019-55112-y. PMID: 31811239. Exclusion Code: X3.31811239
7 Almarzooqi F, Alkhemeiri A, Aljaberi A, Prospective cross-sectional study of tuberculosis screening in United Arab Emirates. Int J Infect Dis. 2018 May;70:81–5. doi: 10.1016/j.ijid.2018.03.001. PMID: 29526607. Exclusion Code: X2.29526607
8 Almufty HB, Abdulrahman IS, Merza MA. Latent tuberculosis infection among healthcare workers in Duhok Province: from screening to prophylactic treatment. Trop Med Infect Dis. 2019 May 23;4(2)doi: 10.3390/tropicalmed4020085. PMID: 31126022. Exclusion Code: X6.31126022
9 Altawallbeh G, Gabrielson D, Peters JM, Performance of an Advanced Interferon-Gamma Release Assay for Mycobacterium tuberculosis Detection. J Appl Lab Med. 2021 Sep 1;6(5):1287–92. doi: 10.1093/jalm/jfab012. PMID: 33829248. Exclusion Code: X5.33829248
10 Altet N, Dominguez J, Souza-Galvão ML, Predicting the development of tuberculosis with the tuberculin skin test and QuantiFERON testing. Ann Am Thorac Soc. 2015 May;12(5):680–8. doi: 10.1513/AnnalsATS.201408-394OC. PMID: 25699406. Exclusion Code: X2.25699406
11 Alvarez GG, Van Dyk D, Mallick R, The implementation of rifapentine and isoniazid (3HP) in two remote Arctic communities with a predominantly Inuit population, the Taima TB 3HP study. Int J Circumpolar Health. 2020 Dec;79(1):1758501. doi: 10.1080/22423982.2020.1758501. PMID: 32379538. Exclusion Code: X2.32379538
12 Alyaquobi F, AlMaqbali AA, Al-Jardani A, Screening migrants from tuberculosis high-endemic countries for latent tuberculosis in Oman: A cross sectional cohort analysis. Travel Med Infect Dis. 2020 Sep-Oct;37:101734. doi: 10.1016/j.tmaid.2020.101734. PMID: 32437967. Exclusion Code: X4.32437967
13 Amorim RF, Viegas ERC, Carneiro AJV, Superiority of interferon gamma assay over tuberculin skin test for latent tuberculosis in inflammatory bowel disease patients in Brazil. Dig Dis Sci. 2019 Jul;64(7):1916–22. doi: 10.1007/s10620-019-5475-3. PMID: 30673986. Exclusion Code: X2.30673986
14 Ananthakrishnan R, Richardson MD, van den Hof S, Successfully engaging private providers to improve diagnosis, notification, and treatment of TB and dragresistant TB: The EQUIP Public-Private Model in Chennai, India. Glob Health Sci Pract. 2019 Mar 22;7(1):41–53. doi: 10.9745/ghsp-d-18-00318. PMID: 30926737. Exclusion Code: X3.30926737
15 Arellano AL, Barriocanal AB, Valderrama A, Preliminary safety results of a double-blind, randomized, placebo-controlled, clinical trial with the probiotic nyaditum resae in adults with or without latent tuberculosis infection. Basic Clin Pharmacol Toxicol. 2014;115:25. doi: 10.1111/bcpt.12301. PMID: CN-01091868. Exclusion Code: X3.
16 Arguello Perez E, Seo SK, Schneider WJ, Management of latent tuberculosis infection among healthcare workers: 10-year experience at a single center. Clin Infect Dis. 2017 Nov 29;65(12):2105–11. doi: 10.1093/cid/cix725. PMID: 29020308. Exclusion Code: X2.29020308
17 Arias-Guillén M, Sánchez Menéndez MM, Alperi M, High rates of tuberculin skin test positivity due to methotrexate therapy: False positive results? Semin Arthritis Rheum. 2018 Dec;48(3):538–46. doi: 10.1016/j.semarthrit.2018.03.018. PMID: 29735171. Exclusion Code: X2.29735171
18 Armenta RF, Collins KM, Strathdee SA, Mycobacterium tuberculosis infection among persons who inject drugs in San Diego, California. Int J Tuberc Lung Dis. 2017 Apr 1;21(4):425–31. doi: 10.5588/ijtld.16.0434. PMID: 28284258. Exclusion Code: X5.28284258
19 Arya S, Kumar SK, Nath A, Synergy between tuberculin skin test and proliferative T cell responses to PPD or cell-membrane antigens of Mycobacterium tuberculosis for detection of latent TB infection in a high disease-burden setting. PLoS One. 2018;13(9):e0204429. doi: 10.1371/journal.pone.0204429. PMID: 30248144. Exclusion Code: X2.30248144
20 Asadi L, Heffernan C, Menzies D, Effectiveness of Canada's tuberculosis surveillance strategy in identifying immigrants at risk of developing and transmitting tuberculosis: a population-based retrospective cohort study. Lancet Public Health. 2017 Oct;2(10):e450–e7. doi: 10.1016/s2468-2667(17)30161-5. PMID: 29253429. Exclusion Code: X2.29253429
21 Auguste P, Tsertsvadze A, Pink J, Comparing interferon-gamma release assays with tuberculin skin test for identifying latent tuberculosis infection that progresses to active tuberculosis: systematic review and meta-analysis. BMC Infect Dis. 2017 Mar 9;17(1):200. doi: 10.1186/s12879-017-2301-4. PMID: 28274215. Exclusion Code: X2.28274215
22 Ayubi E, Doosti-Irani A, Sanjari Moghaddam A, Comparison of QuantiFERON-TB Gold In-Tube (QFT-GIT) and tuberculin skin test (TST) for diagnosis of latent tuberculosis in haemodialysis (HD) patients: a metaanalysis of κ estimates - Erratum. Epidemiol Infect. 2018 Apr;146(5):663. doi: 10.1017/s0950268817001261. PMID: 28675138. Exclusion Code: X1.28675138
23 Babu K, Bhat SS, Philips M, Review of results of QuantiFERON TB Gold test in presumed ocular tuberculosis in a South Indian patient population. Ocul Immunol Inflamm. 2016 Oct;24(5):498–502. doi: 10.3109/09273948.2015.1010094. PMID: 26173028. Exclusion Code: X2.26173028
24 Bae JH, Park SH, Ye BD, Development and validation of a novel prediction model for differential diagnosis between Crohn's disease and intestinal tuberculosis. Inflamm Bowel Dis. 2017 Sep;23(9):1614–23. doi: 10.1097/mib.0000000000001162. PMID: 28682807. Exclusion Code: X2.28682807
25 Baek SD, Jeung S, Kang JY. Nutritional adequacy and latent tuberculosis infection in end-stage renal disease patients. Nutrients. 2019 Sep 26;11(10)doi: 10.3390/nu11102299. PMID: 31561559. Exclusion Code: X5.31561559
26 Bailey WC, Weill H, DeRouen TA, The effect of isoniazid on transaminase levels. Ann Intern Med. 1974 Aug;81(2):200–2. PMID: 4843577. Exclusion Code: X3.4843577
27 Bajrami R, Mulliqi G, Kurti A, Comparison of GeneXpert MTB/RIF and conventional methods for the diagnosis of tuberculosis in Kosovo. J Infect Dev Ctries. 2016 Apr 28;10(4):418–22. doi: 10.3855/jidc.7569. PMID: 27131007. Exclusion Code: X3.27131007
28 Balcells ME, Ruiz-Tagle C, Tiznado C, Diagnostic performance of GM-CSF and IL-2 in response to long-term specific-antigen cell stimulation in patients with active and latent tuberculosis infection. Tuberculosis (Edinb). 2018 Sep;112:110–9. doi: 10.1016/j.tube.2018.08.006. PMID: 30205963. Exclusion Code: X9.30205963
29 Bao L, Li T, Diao N, Fluctuating behavior and influential factors in the performance of the QuantiFERON-TB Gold In-Tube Assay in the diagnosis of tuberculosis. PLoS One. 2015;10(8):e0103763. doi: 10.1371/journal.pone.0103763. PMID: 26287382. Exclusion Code: X6.26287382
30 Bapat PR, Husain AA, Daginawala HF, The assessment of cytokines in Quantiferon supernatants for the diagnosis of latent TB infection in a tribal population of Melghat, India. J Infect Public Health. 2015 Jul-Aug;8(4):329–40. doi: 10.1016/j.jiph.2015.02.003. PMID: 25824629. Exclusion Code: X2.25824629
31 Barcellini L, Borroni E, Brown J, First evaluation of QuantiFERON-TB Gold Plus performance in contact screening. Eur Respir J. 2016 Nov;48(5):1411–9. doi: 10.1183/13993003.00510-2016. PMID: 27390280. Exclusion Code: X2.27390280
32 Bastos ML, Campbell JR, Oxlade O, Health system costs of treating latent tuberculosis infection with four months of rifampin versus nine months of isoniazid in different settings. Ann Intern Med. 2020 Aug 4;173(3):169–78. doi: 10.7326/m19-3741. PMID: 32539440. Exclusion Code: X5.32539440
33 Bastos ML, Menzies D, Belo MT, Changes in QuantiFERON^®^-TB Gold In-Tube results during treatment for tuberculous infection. Int J Tuberc Lung Dis. 2013;17(7):909–16. doi: 10.5588/ijtld.12.0927. PMID: CN-01123101. Exclusion Code: X2.23743310
34 Batt J, Khan K. Responsible use of rifampin for the treatment of latent tuberculosis infection. CMAJ. 2019 Jun 24;191(25):E678–e9. doi: 10.1503/cmaj.190081. PMID: 31235488. Exclusion Code: X1.31235488
35 Bekele A, Ashenafi S, Aderay G, Latent tuberculosis among adult Ethiopian patients at chest clinic, Tikuranbessa Specialized Hospital, Addis Ababa, Ethiopia. Ethiop Med J. 2016 Oct;54(4):181–8. PMID: 29115115. Exclusion Code: X5.29115115
36 Belay M, Legesse M, Mihret A, IFN-γ and IgA against non-methylated heparin-binding hemagglutinin as markers of protective immunity and latent tuberculosis: Results of a longitudinal study from an endemic setting. J Infect. 2016 Feb;72(2):189–200. doi: 10.1016/j.jinf.2015.09.040. PMID: 26518056. Exclusion Code: X4.26518056
37 Belknap R, Holland D, Feng PJ, Self-administered versus directly observed once-weekly isoniazid and rifapentine treatment of latent tuberculosis infection: a randomized trial. Ann Intern Med. 2017 Nov 21;167(10):689–97. doi: 10.7326/m17-1150. PMID: 29114781. Exclusion Code: X4.29114781
38 Belknap R, Holland D, Feng PJ, Self-administered versus directly observed once-weekly isoniazid and rifapentine treatment of latent tuberculosis infection. Ann Intern Med. 2017;167(10):689–97. doi: 10.7326/M17-1150. PMID: CN-01431831. Exclusion Code: X3.29114781
39 Belo C, Naidoo S. Prevalence and risk factors for latent tuberculosis infection among healthcare workers in Nampula Central Hospital, Mozambique. BMC Infect Dis. 2017 Jun 8;17(1):408. doi: 10.1186/s12879-017-2516-4. PMID: 28595594. Exclusion Code: X2.28595594
40 Biraro IA, Egesa M, Kimuda S, Effect of isoniazid preventive therapy on immune responses to mycobacterium tuberculosis: an open label randomised, controlled, exploratory study. BMC Infect Dis. 2015 Oct 22;15:438. doi: 10.1186/s12879-015-1201-8. PMID: 26493989. Exclusion Code: X8.26493989
41 Bisognin F, Lombardi G, Re MC, QuantiFERON-TB Gold Plus with chemiluminescence immunoassay: do we need a higher cutoff? J Clin Microbiol. 2020 Sep 22;58(10)doi: 10.1128/jcm.00780-20. PMID: 32759352. Exclusion Code: X2.32759352
42 Bongomin F, Ssekamatte P, Nattabi G, Latent Tuberculosis Infection Status of Pregnant Women in Uganda Determined Using QuantiFERON TB Gold-Plus. Open Forum Infect Dis. 2021 Jun;8(6):ofab241. doi: 10.1093/ofid/ofab241. PMID: 34113689. Exclusion Code: X2.34113689
43 Bonini S, Riccelli MG, Goldoni M, Risk factors for latent tuberculosis infection (LTBI) in health profession's students of the University of Parma. Acta Biomed. 2017 Mar 14;88(1s):54–60. PMID: 28327495. Exclusion Code: X4.28327495
44 Boortalary T, Misra K, McNish S, Prevalence of positive QuantiFERON gold in-tube testing in hidradenitis suppurativa. J Dermatolog Treat. 2018 Sep;29(6):637–40. doi: 10.1080/09546634.2018.1425360. PMID: 29325465. Exclusion Code: X2.29325465
45 Bosco MJ, Hou H, Mao L, The performance of the TBAg/PHA ratio in the diagnosis of active TB disease in immunocompromised patients. Int J Infect Dis. 2017 Jun;59:55–60. doi: 10.1016/j.ijid.2017.03.025. PMID: 28392318. Exclusion Code: X4.28392318
46 Boyd R, Johnston V, Farmer B, Treatment of latent tuberculosis infections in the Darwin region. Med J Aust. 2017 Apr 17;206(7):306–207. doi: 10.5694/mja16.01209. PMID: 28403762. Exclusion Code: X4.28403762
47 Bozkanat E, Kaya H, Sezer O, Comparison of tuberculin skin test and quantiferon-TB gold in tube test for diagnosis of latent tuberculosis infection in health care workers: A cross sectional study. J Pak Med Assoc. 2016 Mar;66(3):270–4. PMID: 26968275. Exclusion Code: X2.26968275
48 Brinkmann F. [Not Available]. Kinderkrankenschwester. 2016 Aug;35(8):300–4. PMID: 30380244. Exclusion Code: X7.30380244
49 Broughton E, Haumba S, Calnan M, Screening in Maternity to Ascertain Tuberculosis Status (SMATS) study. BMC Infect Dis. 2017 Mar 6;17(1):191. doi: 10.1186/s12879-017-2285-0. PMID: 28264655. Exclusion Code: X2.28264655
50 Bua A, Molicotti P, Delogu G, QuantiFERON-TB Gold: a new method for latent tuberculosis infection. New Microbiol. 2007 Oct;30(4):477–80. PMID: 18080685. Exclusion Code: X3.18080685
51 Bua A, Ruggeri M, Zanetti S, Effect of teriflunomide on QuantiFERON-TB Gold results. Med Microbiol Immunol. 2017 Feb;206(1):73–5. doi: 10.1007/s00430-016-0482-x. PMID: 27704206. Exclusion Code: X4.27704206
52 Bukhary ZA, Amer SM, Emara MM, Screening of latent tuberculosis infection among health care workers working in Hajj pilgrimage area in Saudi Arabia, using interferon gamma release assay and tuberculin skin test. Ann Saudi Med. 2018 Mar-Apr;38(2):90–6. doi: 10.5144/0256-4947.2018.90. PMID: 29620541. Exclusion Code: X2.29620541
53 Bullarbo M, Barnisin M, Vukas Radulovic N, Low prevalence of active tuberculosis among high-risk pregnant and postpartum women in Sweden: a retrospective epidemiological cohort study using and evaluating TST as screening method. Infect Dis Obstet Gynecol. 2018;2018:3153250. doi: 10.1155/2018/3153250. PMID: 30154639. Exclusion Code: X2.30154639
54 Bush OB Jr., Sugimoto M, Fujii Y, Isoniazid prophylaxis in contacts of persons with known tuberculosis. Second report. Am Rev Respir Dis. 1965 Nov;92(5):732–40. PMID: 5321147. Exclusion Code: X2.5321147
55 Byrd RB, Horn BR, Griggs GA, Isoniazid chemoprophylaxis. Association with detection and incidence of liver toxicity. Arch Intern Med. 1977 Sep;137(9):1130–3. PMID: 332099. Exclusion Code: X3.332099
56 Campbell JR, Johnston JC, Sadatsafavi M, Cost-effectiveness of post-landing latent tuberculosis infection control strategies in new migrants to Canada. PLoS One. 2017;12(10):e0186778. doi: 10.1371/journal.pone.0186778. PMID: 29084227. Exclusion Code: X6.29084227
57 Castro AT, Mendes M, Freitas S, Incidence and risk factors of major toxicity associated to first-line antituberculosis drugs for latent and active tuberculosis during a period of 10 years. Rev Port Pneumol (2006). 2015 May-Jun;21(3):144–50. doi: 10.1016/j.rppnen.2014.08.004. PMID: 25926250. Exclusion Code: X2.25926250
58 Çavuşoğlu C, Yaşar-Duman M, Sezai Taşbakan M, Evaluation of the performance of QuantiFERON^®^-TB Gold plus test in active tuberculosis patients. J Clin Tuberc Other Mycobact Dis. 2021 May;23:100223. doi: 10.1016/j.jctube.2021.100223. PMID: 33665376. Exclusion Code: X2.33665376
59 Chandrasekaran P, Mave V, Thiruvengadam K, Tuberculin skin test and QuantiFERON-Gold In Tube assay for diagnosis of latent TB infection among household contacts of pulmonary TB patients in high TB burden setting. PLoS One. 2018;13(8):e0199360. doi: 10.1371/journal.pone.0199360. PMID: 30067752. Exclusion Code: X2.30067752
60 Che N, Yang X, Liu Z, Rapid detection of cell-free mycobacterium tuberculosis DNA in tuberculous pleural effusion. J Clin Microbiol. 2017 May;55(5):1526–32. doi: 10.1128/jcm.02473-16. PMID: 28275073. Exclusion Code: X3.28275073
61 Chedid C, Kokhreidze E, Tukvadze N, Relevance of QuantiFERON-TB Gold Plus and heparin-binding hemagglutinin interferon-γ release assays for monitoring of pulmonary tuberculosis clearance: a multicentered study. Front Immunol. 2020;11:616450. doi: 10.3389/fimmu.2020.616450. PMID: 33603746. Exclusion Code: X9.33603746
62 Chen G, Wu SQ, Feng M, Association of UGT2B7 polymorphisms with risk of induced liver injury by anti-tuberculosis drugs in Chinese Han. Int J Immunopathol Pharmacol. 2017 Dec;30(4):434–8. doi: 10.1177/0394632017733638. PMID: 28934901. Exclusion Code: X2.28934901
63 Chen Q, Guo X, Wang X, T-SPOT.TB in detection of active tuberculosis during pregnancy: a retrospective study in China. Med Sci Monit. 2016 Jan 6;22:57–60. doi: 10.12659/msm.896943. PMID: 26732770. Exclusion Code: X9.26732770
64 Chen Y, Jiang H, Zhang W, Diagnostic value of T-SPOT.TB test in cutaneous mycobacterial infections. Acta Derm Venereol. 2018 Nov 5;98(10):989–90. doi: 10.2340/00015555-3011. PMID: 30085325. Exclusion Code: X2.30085325
65 Cheng XH, Bian SN, Zhang YQ, Diagnostic value of T-cell interferon-γ release assays on synovial fluid for articular tuberculosis: a pilot study. Chin Med J (Engl). 2016 May 20;129(10):1171–8. doi: 10.4103/0366-6999.181958. PMID: 27174325. Exclusion Code: X2.27174325
66 Chien JY, Chiang HT, Lu MC, QuantiFERON-TB Gold Plus is a more sensitive screening tool than QuantiFERON-TB Gold In-Tube for latent tuberculosis infection among older adults in long-term care facilities. J Clin Microbiol. 2018 Aug;56(8)doi: 10.1128/jcm.00427-18. PMID: 29793966. Exclusion Code: X4.29793966
67 Chitnis AS, Robsky K, Schecter GF, Trends in tuberculosis cases among nursing home residents, California, 2000 to 2009. J Am Geriatr Soc. 2015 Jun;63(6): 1098–104. doi: 10.1111/jgs.13437. PMID: 26096384. Exclusion Code: X5.26096384
68 Chiu TF, Yen MY, Shie YH, Determinants of latent tuberculosis infection and treatment interruption in long-term care facilities: A retrospective cohort study in Taiwan. J Microbiol Immunol Infect. 2021 Oct 11doi: 10.1016/j.jmii.2021.09.013. PMID: 34686442. Exclusion Code: X4.34686442
69 Cho H, Kim YW, Suh CH, Concordance between the tuberculin skin test and interferon gamma release assay (IGRA) for diagnosing latent tuberculosis infection in patients with systemic lupus erythematosus and patient characteristics associated with an indeterminate IGRA. Lupus. 2016 Oct;25(12):1341–8. doi: 10.1177/0961203316639381. PMID: 26985011. Exclusion Code: X2.26985011
70 Choi S, Jung KH, Son HJ, Diagnostic usefulness of the QuantiFERON-TB gold in-tube test (QFT-GIT) for tuberculous vertebral osteomyelitis. Infect Dis (Lond). 2018 May;50(5):346–51. doi: 10.1080/23744235.2017.1410282. PMID: 29189087. Exclusion Code: X2.29189087
71 Chung J, Aronson AB, Srikantha R, Low conversion rate of QuantiFERON-TB Gold screening tests in patients treated with tumor necrosis factor inhibitors: A retrospective cohort study identifying an important practice gap. J Am Acad Dermatol. 2018 Jul;79(1):169–71. doi: 10.1016/j.jaad.2018.03.025. PMID: 29588247. Exclusion Code: X2.29588247
72 Cobelens F, Kik S, Esmail H, From latent to patent: rethinking prediction of tuberculosis. Lancet Respir Med. 2017 Apr;5(4):243–4. doi: 10.1016/s2213-2600(16)30419-2. PMID: 28017341. Exclusion Code: X1.28017341
73 Cohen DB, Meghji J, Squire SB. A systematic review of clinical outcomes on the WHO Category II retreatment regimen for tuberculosis. Int J Tuberc Lung Dis. 2018 Oct 1;22(10):1127–34. doi: 10.5588/ijtld.17.0705. PMID: 30236179. Exclusion Code: X3.30236179
74 Cojutti P, Duranti S, Isola M, Might isoniazid plasma exposure be a valuable predictor of drug-related hepatotoxicity risk among adult patients with TB? J Antimicrob Chemother. 2016 May;71(5):1323–9. doi: 10.1093/jac/dkv490. PMID: 26832752. Exclusion Code: X2.26832752
75 Collin SM, Wurie F, Muzyamba MC, Effectiveness of interventions for reducing TB incidence in countries with low TB incidence: a systematic review of reviews. Eur Respir Rev. 2019 Jun 30;28(152)doi: 10.1183/16000617.0107-2018. PMID: 31142548. Exclusion Code: X6.31142548
76 Collins JM, Onwubiko U, Holland DP. QuantiFERON-TB Gold versus tuberculin screening and care retention among persons experiencing homelessness: Georgia, 2015-2017. Am J Public Health. 2019 Jul;109(7):1028–33. doi: 10.2105/ajph.2019.305069. PMID: 31095412. Exclusion Code: X4.31095412
77 Collins LF, Geadas C, Ellner JJ. Diagnosis of latent tuberculosis infection: too soon to pull the plug on the tuberculin skin test. Ann Intern Med. 2016 Jan 19;164(2):122–4. doi: 10.7326/m15-1522. PMID: 26642354. Exclusion Code: X1.26642354
78 Corvino AR, Monaco MGL, Garzillo EM, Tuberculosis infection screening in 5468 Italian healthcare students: investigation of a borderline zone value for the QFT-Test. Int J Environ Res Public Health. 2020 Sep 17;17(18)doi: 10.3390/ijerph17186773. PMID: 32957500. Exclusion Code: X2.32957500
79 Cox V, de Azevedo V, Stinson K, Diagnostic accuracy of tuberculin skin test self-reading by HIV patients in a low-resource setting. Int J Tuberc Lung Dis. 2015 Nov;19(11):1300–4. doi: 10.5588/ijtld.15.0015. PMID: 26467581. Exclusion Code: X2.26467581
80 Cummings KJ, Smith TS, Shogren ES, Prospective comparison of tuberculin skin test and QuantiFERON-TB Gold In-Tube assay for the detection of latent tuberculosis infection among healthcare workers in a low-incidence setting. Infect Control Hosp Epidemiol. 2009 Nov;30(11):1123–6. doi: 10.1086/644754. PMID: 19803719. Exclusion Code: X9.19803719
81 Dabhi PA, Thangakunam B, Gupta R, Screening for prevalence of current TB disease and latent TB infection in type 2 diabetes mellitus patients attending a diabetic clinic in an Indian tertiary care hospital. PLoS One. 2020;15(6):e0233385. doi: 10.1371/journal.pone.0233385. PMID: 32502176. Exclusion Code: X4.32502176
82 de Paus RA, van Meijgaarden KE, Prins C, Immunological characterization of latent tuberculosis infection in a low endemic country. Tuberculosis (Edinb). 2017 Sep;106:62–72. doi: 10.1016/j.tube.2017.07.001. PMID: 28802407. Exclusion Code: X5.28802407
83 Della Bella C, Spinicci M, Alnwaisri HFM, LIOFeron^®^TB/LTBI: A novel and reliable test for LTBI and tuberculosis. Int J Infect Dis. 2020 Feb;91:177–81. doi: 10.1016/j.ijid.2019.12.012. PMID: 31877486. Exclusion Code: X3.31877486
84 den Boon S, Matteelli A, Getahun H. Rifampicin resistance after treatment for latent tuberculous infection: a systematic review and meta-analysis. Int J Tuberc Lung Dis. 2016 Aug;20(8):1065–71. doi: 10.5588/ijtld.15.0908. PMID: 27393541. Exclusion Code: X2.27393541
85 Deng Y, Liu Y, Li Y, Isolation measures and protection awareness are significant for latent tuberculosis infection: a cross-sectional study based on T-SPOT.TB among health care workers in China. Epidemiol Infect. 2019 Jan;147:e120. doi: 10.1017/s0950268818002777. PMID: 30868980. Exclusion Code: X2.30868980
86 Denholm JT, McBryde ES, Eisen D, SIRCLE: a randomised controlled cost comparison of self-administered short-course isoniazid and rifapentine for cost-effective latent tuberculosis eradication. Intern Med J. 2017 Dec;47(12):1433–6. doi: 10.1111/imj.13601. PMID: 29224209. Exclusion Code: X9.29224209
87 Dewan PK, Grinsdale J, Kawamura LM. Low sensitivity of a whole-blood interferon-gamma release assay for detection of active tuberculosis. Clin Infect Dis. 2007 Jan 1;44(1):69–73. doi: 10.1086/509928. PMID: 17143818. Exclusion Code: X3.17143818
88 Dian S, Yunivita V, Ganiem AR, Double-blind, randomized, placebo-controlled phase II dose-finding study to evaluate high-dose rifampin for tuberculous meningitis. Antimicrob Agents Chemother. 2018 Dec;62(12)doi: 10.1128/aac.01014-18. PMID: 30224533. Exclusion Code: X3.30224533
89 Dias de Oliveira R, da Silva Santos A, Reis CB, Primary prophylaxis to prevent tuberculosis infection in prison inmates: a randomized, double-blind, placebo-controlled trial. Am J Trop Med Hyg. 2020 Oct;103(4):1466–72. doi: 10.4269/ajtmh.20-0110. PMID: 32876010. Exclusion Code: X2.32876010
90 Dion R, Brisson M, Proulx JF, Results of a population screening intervention for tuberculosis in a Nunavik village, Quebec, 2015-2016. Can Commun Dis Rep. 2018 Oct 4;44(10):257–63. doi: 10.14745/ccdr.v44i10a04. PMID: 31524887. Exclusion Code: X2.31524887
91 Doan TN, Eisen DP, Rose MT, Interferon-gamma release assay for the diagnosis of latent tuberculosis infection: A latent-class analysis. PLoS One. 2017;12(11):e0188631. doi: 10.1371/journal.pone.0188631. PMID: 29182688. Exclusion Code: X6.29182688
92 Dobler CC, Martin A, Marks GB. Benefit of treatment of latent tuberculosis infection in individual patients. Eur Respir J. 2015 Nov;46(5):1397–406. doi: 10.1183/13993003.00577-2015. PMID: 26405292. Exclusion Code: X6.26405292
93 Du F, Zhang Z, Gao T, Diagnosis of latent tuberculosis by ELISPOT assay and tuberculin skin test. Med Mal Infect. 2016 May;46(3):150–3. doi: 10.1016/j.medmal.2016.02.011. PMID: 27021933. Exclusion Code: X5.27021933
94 Durovni B, Saraceni V, van den Hof S, Impact of replacing smear microscopy with Xpert MTB/RIF for diagnosing tuberculosis in Brazil: a stepped-wedge cluster-randomized trial. PLoS Med. 2014;11(12):e1001766. doi: 10.1371/journal.pmed.1001766. PMID: CN-01111772. Exclusion Code: X3.25490549
95 Eastment MC, McClintock AH, McKinney CM, Factors that influence treatment completion for latent tuberculosis infection. J Am Board Fam Med. 2017 Jul-Aug;30(4):520–7. doi: 10.3122/jabfm.2017.04.170070. PMID: 28720633. Exclusion Code: X6.28720633
96 Edathodu J, Varghese B, Alrajhi AA, Diagnostic potential of interferon-gamma release assay to detect latent tuberculosis infection in kidney transplant recipients. Transpl Infect Dis. 2017 Apr;19(2)doi: 10.1111/tid.12675. PMID: 28170135. Exclusion Code: X2.28170135
97 Edwards BD, Edwards J, Cooper R, Incidence, treatment, and outcomes of isoniazid mono-resistant Mycobacterium tuberculosis infections in Alberta, Canada from 2007-2017. PLoS One. 2020;15(3):e0229691. doi: 10.1371/journal.pone.0229691. PMID: 32155169. Exclusion Code: X2.32155169
98 El Amrani M, Asserraji M, Bahadi A, Tuberculosis in hemodialysis. Med Sante Trop. 2016 Aug 1;26(3):262–6. doi: 10.1684/mst.2016.0569. PMID: 27694081. Exclusion Code: X7.27694081
99 Eom JS, Kim I, Kim WY, Household tuberculosis contact investigation in a tuberculosis-prevalent country: Are the tuberculin skin test and interferon-gamma release assay enough in elderly contacts? Medicine (Baltimore). 2018 Jan;97(3):e9681. doi: 10.1097/md.0000000000009681. PMID: 29505017. Exclusion Code: X4.29505017
100 Erkens CG, Slump E, Verhagen M, Monitoring latent tuberculosis infection diagnosis and management in the Netherlands. Eur Respir J. 2016 May;47(5):1492–501. doi: 10.1183/13993003.01397-2015. PMID: 26917614.Exclusion Code: X4.26917614
101 Escalante P, Peikert T, Van Keulen VP, Combinatorial immunoprofiling in latent tuberculosis infection. Toward better risk stratification. Am J Respir Crit Care Med. 2015 Sep 1;192(5):605–17. doi: 10.1164/rccm.201412-2141OC. PMID: 26030344. Exclusion Code: X2.26030344
102 Eum SY, Lee YJ, Kwak HK, Evaluation of the diagnostic utility of a whole-blood interferon-gamma assay for determining the risk of exposure to Mycobacterium tuberculosis in Bacille Calmette-Guerin (BCG)-vaccinated individuals. Diagn Microbiol Infect Dis. 2008 Jun;61(2):181–6. doi: 10.1016/j.diagmicrobio.2008.01.002. PMID: 18296002. Exclusion Code: X9.18296002
103 Evans D, Schnippel K, Govathson C, Treatment initiation among persons diagnosed with drug resistant tuberculosis in Johannesburg, South Africa. PLoS One. 2017;12(7):e0181238. doi: 10.1371/journal.pone.0181238. PMID: 28746344. Exclusion Code: X2.28746344
104 Falk A, Fuchs GF. Prophylaxis with isoniazid in inactive tuberculosis. A Veterans Administration Cooperative Study XII. Chest. 1978 Jan;73(1):44–8. PMID: 340155. Exclusion Code: X3.340155
105 Fan T, Rogers A. Screening for latent tuberculosis infection in adults. Am Fam Physician. 2017 Nov 15;96(10):675–6. PMID: 29431394. Exclusion Code: X1.29431394
106 Feng JY, Huang WC, Lin SM, Safety and treatment completion of latent tuberculosis infection treatment in the elderly population-A prospective observational study in Taiwan. Int J Infect Dis. 2020 Jul;96:550–7. doi: 10.1016/j.ijid.2020.05.009. PMID: 32434083. Exclusion Code: X2.32434083
107 Feng JY, Pan SW, Huang SF, Depressed gamma interferon responses and treatment outcomes in tuberculosis patients: a prospective cohort study. J Clin Microbiol. 2018 Oct;56(10)doi: 10.1128/jcm.00664-18. PMID: 30068533. Exclusion Code: X2.30068533
108 Feng M, Sun F, Wang F, The diagnostic effect of sequential detection of ADA screening and T-SPOT assay in pleural effusion patients. Artif Cells Nanomed Biotechnol. 2019 Dec;47(1):3272–7. doi: 10.1080/21691401.2019.1647221. PMID: 31379209. Exclusion Code: X3.31379209
109 Ferebee SFI, Mount FW, Murray FJ, A controlled trial of isoniazid prophylaxis in mental institutions. Am Rev Respir Dis. 1963 Aug;88:161–75. PMID: 14045220. Exclusion Code: X2.14045220
110 Ferguson TW, Tangri N, Macdonald K, The diagnostic accuracy of tests for latent tuberculosis infection in hemodialysis patients: a systematic review and meta-analysis. Transplantation. 2015 May;99(5):1084–91. doi: 10.1097/tp.0000000000000451. PMID: 25286055. Exclusion Code: X6.25286055
111 Feris EJ, Encinales L, Awad C, High levels of anti-tuberculin (IgG) antibodies correlate with the blocking of T-cell proliferation in individuals with high exposure to Mycobacterium tuberculosis. Int JInfect Dis. 2016 Feb;43:21–4. doi: 10.1016/j.ijid.2015.12.004. PMID: 26686942. Exclusion Code: X5.26686942
112 Ferreira TF, Matsuoka Pda F, Santos AM, Diagnosis of latent Mycobacterium tuberculosis infection: tuberculin test versus interferon-gamma release. Rev Soc Bras Med Trop. 2015 Nov-Dec;48(6):724–30. doi: 10.1590/0037-8682-0258-2015. PMID: 26676497. Exclusion Code: X2.26676497
113 Fox GJ, Anh NT, Nhung NV, Latent tuberculous infection in household contacts of multidrug-resistant and newly diagnosed tuberculosis. Int J Tuberc Lung Dis. 2017 Mar 1;21(3):297–302. doi: 10.5588/ijtld.16.0576. PMID: 28225339. Exclusion Code: X4.28225339
114 Franken WP, Timmermans JF, Prins C, Comparison of Mantoux and QuantiFERON TB Gold tests for diagnosis of latent tuberculosis infection in Army personnel. Clin Vaccine Immunol. 2007 Apr;14(4):477-- 80. doi: 10.1128/cvi.00463-06. PMID: 17301213. Exclusion Code: X9.17301213
115 Fröberg G, Jansson L, Nyberg K, Screening and treatment of tuberculosis among pregnant women in Stockholm, Sweden, 2016-2017. Eur Respir J. 2020 Mar;55(3)doi: 10.1183/13993003.00851-2019. PMID: 31949114. Exclusion Code: X6.31949114
116 Galindo JL, Galeano AC, Suarez-Zamora DA, Comparison of the QuantiFERON-TB and tuberculin skin test for detection of latent tuberculosis infection in cancer patients in a developing country. ERJ Open Res. 2019 Oct;5(4)doi: 10.1183/23120541.00258-2018. PMID: 31637254. Exclusion Code: X2.31637254
117 Gamsky TE, Lum T, Hung-Fan M, Cumulative false-positive QuantiFERON-TB interferon-γ release assay results. Ann Am Thorac Soc. 2016 May;13(5):660–5. doi: 10.1513/AnnalsATS.201508-532OC. PMID: 26783649. Exclusion Code: X2.26783649
118 Gao L, Li X, Liu J, Incidence of active tuberculosis in individuals with latent tuberculosis infection in rural China: follow-up results of a population-based, multicentre, prospective cohort study. Lancet Infect Dis. 2017 Oct;17(10):1053–61. doi: 10.1016/s1473-3099(17)30402-4. PMID: 28716677. Exclusion Code: X5.28716677
119 Garg K, Saini V, Dhillon R, Isoniazid mono-resistant tuberculosis: time to take it seriously. Indian J Tuberc. 2019 Apr;66(2):247–52. doi: 10.1016/j.ijtb.2019.04.001. PMID: 31151492. Exclusion Code: X3.31151492
120 Gelalcha AG, Kebede A, Mamo H. Light-emitting diode fluorescent microscopy and Xpert MTB/RIF^®^ assay for diagnosis of pulmonary tuberculosis among patients attending Ambo hospital, west-central Ethiopia. BMC Infect Dis. 2017 Sep 11;17(1):613. doi: 10.1186/s12879-017-2701-5. PMID: 28893193. Exclusion Code: X3.28893193
121 Genestet C, Bernard-Barret F, Hodille E, Antituberculous drugs modulate bacterial phagolysosome avoidance and autophagy in Mycobacterium tuberculosis-infected macrophages. Tuberculosis (Edinb). 2018 Jul;111:67–70. doi: 10.1016/j.tube.2018.05.014. PMID: 30029917. Exclusion Code: X6.30029917
122 Getahun H, Matteelli A, Abubakar I, Management of latent Mycobacterium tuberculosis infection: WHO guidelines for low tuberculosis burden countries. Eur Respir J. 2015 Dec;46(6):1563–76. doi: 10.1183/13993003.01245-2015. PMID: 26405286. Exclusion Code: X6.26405286
123 Girish S, Kinikar A, Pardesh G, Utility of the Interferon-Gamma Release Assay for Latent Tuberculosis Infection Screening among Indian Health-Care Workers. Indian J Community Med. 2021 Apr-Jun;46(2):281–4. doi: 10.4103/ijcm.IJCM_761_20. PMID: 34321742. Exclusion Code: X2.34321742
124 Goebel KM, Tay EL, Denholm JT. Supplemental use of an interferon-gamma release assay in a state-wide tuberculosis contact tracing program in Victoria: a six-year review. Commun Dis Intell Q Rep. 2015 Jun 30;39(2):E191–6. PMID: 26234253. Exclusion Code: X4.26234253
125 González-Moreno J, García-Gasalla M, Losada-López I, IGRA testing in patients with immune-mediated inflammatory diseases: which factors influence the results? Rheumatol Int. 2018 Feb;38(2):267–73. doi: 10.1007/s00296-017-3852-9. PMID: 29051973. Exclusion Code: X2.29051973
126 Gonzślez-Moreno J, García-Gasalla M, Gállego-Lezaun C, Role of QuantiFERON(^®^)-TB Gold In-Tube in tuberculosis contact investigation: experience in a tuberculosis unit. Infect Dis (Lond). 2015 Apr;47(4):244–51. doi: 10.3109/00365548.2014.987813. PMID: 25692351. Exclusion Code: X2.25692351
127 Gorek Dilektasli A, Durukan E, Eyüboğlu F. Feasibility of the interferon-gamma enzyme-linked immunospot assay in chronic renal failure patients and immunocompetent subjects: a head-to-head comparison. Ren Fail. 2015 Mar;37(2):203–8. doi: 10.3109/0886022x.2014.979508. PMID: 25387208. Exclusion Code: X2.25387208
128 Gounder PP, Harris TG, Anger H, Risk for tuberculosis disease among contacts with prior positive tuberculin skin test: a retrospective cohort study, New York City. J Gen Intern Med. 2015 Jun;30(6):742–8. doi: 10.1007/s11606-015-3180-2. PMID: 25605533. Exclusion Code: X2.25605533
129 Gow N, Briggs S, Nisbet M. Screening for latent tuberculous infection in people living with HIV infection in Auckland, New Zealand. Int J Tuberc Lung Dis. 2017 Sep 1;21(9):1008–12. doi: 10.5588/jtld.17.0103. PMID: 28826450. Exclusion Code: X2.28826450
130 Grace AG, Mittal A, Jain S, Shortened treatment regimens versus the standard regimen for drug-sensitive pulmonary tuberculosis. Cochrane Database Syst Rev. 2019 Dec 12;12(12):Cd012918. doi: 10.1002/14651858.CD012918.pub2. PMID: 31828771. Exclusion Code: X2.31828771
131 Gray EL, Goldberg HF. Baseline abnormal liver function tests are more important than age in the development of isoniazid-induced hepatoxicity for patients receiving preventive therapy for latent tuberculosis infection. Intern Med J. 2016 Mar;46(3):281–7. doi: 10.1111/imj.12979. PMID: 26648478. Exclusion Code: X6.26648478
132 Grecchi C, Sarda C, Manciulli T, Screening program for latent tuberculosis infection in asylum seekers - a single center experience in Pavia, Italy. Ann Ig. 2020 Nov-Dec;32(6):682–8. doi: 10.7416/ai.2020.2388. PMID: 33175078. Exclusion Code: X4.33175078
133 Greenaway C, Pareek M, Abou Chakra CN, The effectiveness and cost-effectiveness of screening for latent tuberculosis among migrants in the EU/EEA: a systematic review. Euro Surveill. 2018 Apr;23(14)doi: 10.2807/1560-7917.es.2018.23.14.17-00543. PMID: 29637889. Exclusion Code: X6.29637889
134 Greenwald M, Ball J, Deodar A. A mode of error: Immunoglobulin binding protein (a subset of anti-citrullinated proteins) can cause false positive tuberculosis test results in rheumatoid arthritis. J Clin Tuberc Other Mycobact Dis. 2017 Dec;9:5–9. doi: 10.1016/j.jctube.2017.08.004. PMID: 31723711. Exclusion Code: X2.31723711
135 Groen-Hakan F, van Laar JAM, Bakker M, Prevalence of positive QuantiFERON-TB Gold In-Tube test in uveitis and its clinical implications in a country nonendemic for tuberculosis. Am J Ophthalmol. 2020 Mar;211:151–8. doi: 10.1016/j.ajo.2019.11.009. PMID: 31734135. Exclusion Code: X2.31734135
136 Gupta RK, Calderwood CJ, Yavlinsky A, Discovery and validation of a personalized risk predictor for incident tuberculosis in low transmission settings. Nat Med. 2020 Dec;26(12):1941–9. doi: 10.1038/s41591-020-1076-0. PMID: 33077958. Exclusion Code: X5.33077958
137 Hamada Y, Ford N, Schenkel K, Three-month weekly rifapentine plus isoniazid for tuberculosis preventive treatment: a systematic review. Int J Tuberc Lung Dis. 2018 Dec 1;22(12):1422–8. doi: 10.5588/ijtld.18.0168. PMID: 30606313. Exclusion Code: X2.30606313
138 Han J, Zeng F, Zhou Y. The value of T-SPOT.TB in early diagnosis of tracheobronchial tuberculosis. Sarcoidosis Vasc Diffuse Lung Dis. 2016 Jan 18;32(4):336–41. PMID: 26847101. Exclusion Code: X9.26847101
139 Han SS, Lee SJ, Yim JJ, Evaluation and treatment of latent tuberculosis infection among healthcare workers in Korea: a multicentre cohort analysis. PLoS One. 2019;14(9):e0222810. doi: 10.1371/journal.pone.0222810. PMID: 31536577. Exclusion Code: X6.31536577
140 He Y, Zhang W, Huang T, Evaluation of a diagnostic flow chart applying medical thoracoscopy, adenosine deaminase and T-SPOT.TB in diagnosis of tuberculous pleural effusion. Eur Rev Med Pharmacol Sci. 2015 Oct;19(19):3563–8. PMID: 26502844. Exclusion Code: X5.26502844
141 Hedges KNC, Borisov AS, Saukkonen JJ, Nonparticipation reasons in a randomized international trial of a new latent tuberculosis infection regimen. Clin Trials. 2020 Feb;17(1):39–51. doi: 10.1177/1740774519885380. PMID: 31690107. Exclusion Code: X5.31690107
142 Henderson M, Howard SJ. Screening for latent tuberculosis in UK health care workers. Occup Med (Lond). 2017 Dec 2;67(8):641–3. doi: 10.1093/occmed/kqx119. PMID: 29016903. Exclusion Code: X2.29016903
143 Hermans SM, Grant AD, Chihota V, The timing of tuberculosis after isoniazid preventive therapy among gold miners in South Africa: a prospective cohort study. BMC Med. 2016 Mar 23;14:45. doi: 10.1186/s12916-016-0589-3. PMID: 27004413. Exclusion Code: X6.27004413
144 Hermansen TS, Lillebaek T, Langholz Kristensen K, Prognostic value of interferon-γ release assays, a population-based study from a TB low-incidence country. Thorax. 2016 Jul;71(7):652–8. doi: 10.1136/thoraxjnl-2015-208228. PMID: 27030576. Exclusion Code: X2.27030576
145 Herzmann C, Sotgiu G, Bellinger O, Risk for latent and active tuberculosis in Germany. Infection. 2017 Jun;45(3):283–90. doi: 10.1007/s15010-016-0963-2. PMID: 27866367. Exclusion Code: X4.27866367
146 Hewitt RJ, Francis M, Singanayagam A, Screening tests for tuberculosis before starting biological therapy. BMJ. 2015 Mar 5;350:h1060. doi: 10.1136/bmj.h1060. PMID: 25742884. Exclusion Code: X6.25742884
147 Hu X, Xing B, Wang W, Diagnostic values of Xpert MTB/RIF, T-SPOT.TB and adenosine deaminase for HIV-negative tuberculous pericarditis in a high burden setting: a prospective observational study. Sci Rep. 2020 Oct 1;10(1):16325. doi: 10.1038/s41598-020-73220-y. PMID: 33004934. Exclusion Code: X2.33004934
148 Huang CC, Becerra MC, Calderon R, Isoniazid preventive therapy in contacts of multidrug-resistant tuberculosis. Am J Respir Crit Care Med. 2020 Oct 15;202(8):1159–68. doi: 10.1164/rccm.201908-1576OC. PMID: 32551948. Exclusion Code: X2.32551948
149 Huang HL, Lee MR, Cheng MH, Impact of age on outcome of rifapentine-based weekly therapy for latent tuberculosis infection. Clin Infect Dis. 2020 Nov 19doi: 10.1093/cid/ciaa1741. PMID: 33215187. Exclusion Code: X4.33215187
150 Huang YW, Yang SF, Yeh YP, Impacts of 12-dose regimen for latent tuberculosis infection: treatment completion rate and cost-effectiveness in Taiwan. Medicine (Baltimore). 2016 Aug;95(34):e4126. doi: 10.1097/md.0000000000004126. PMID: 27559940. Exclusion Code: X6.27559940
151 Huo Z, Yang M, Chen J, Improved early diagnosis of difficult cases of tuberculous pleural effusion by combination of thoracoscopy with immunological tests. Int J Infect Dis. 2019 Apr;81:38–42. doi: 10.1016/j.ijid.2019.01.045. PMID: 30710790. Exclusion Code: X2.30710790
152 Igari H, Akutsu N, Ishikawa S, Positivity rate of interferon-γ release assays for estimating the prevalence of latent tuberculosis infection in renal transplant recipients in Japan. J Infect Chemother. 2019 Jul;25(7):537–42. doi: 10.1016/j.jiac.2019.02.018. PMID: 30905632. Exclusion Code: X2.30905632
153 Igari H, Imasawa T, Noguchi N, Advanced stage of chronic kidney disease is risk of poor treatment outcome for smear-positive pulmonary tuberculosis. J Infect Chemother. 2015 Aug;21(8):559–63. doi: 10.1016/j.jiac.2015.04.008. PMID: 26048063. Exclusion Code: X4.26048063
154 Igari H, Ishikawa S, Nakazawa T, Lymphocyte subset analysis in QuantiFERON-TB Gold Plus and T-Spot.TB for latent tuberculosis infection in rheumatoid arthritis. J Infect Chemother. 2018 Feb;24(2):110–6. doi: 10.1016/j.jiac.2017.09.012. PMID: 29054459. Exclusion Code: X4.29054459
155 Isa SE, Ebonyi AO, Shehu NY, Antituberculosis drugs and hepatotoxicity among hospitalized patients in Jos, Nigeria. Int J Mycobacteriol. 2016 Mar;5(1):21–6. doi: 10.1016/j.ijmyco.2015.10.001. PMID: 26927986. Exclusion Code: X6.26927986
156 Ishikawa S, Igari H, Akutsu N, Comparison of interferon-γ release assays, QuantiFERON TB-GIT and T-Spot.TB, in renal transplantation. J Infect Chemother. 2017 Jul;23(7):468–73. doi: 10.1016/j.jiac.2017.04.002. PMID: 28438462. Exclusion Code: X2.28438462
157 Iwata K, Morishita N, Nishiwaki M, Use of Rifampin Compared with Isoniazid for the Treatment of Latent Tuberculosis Infection in Japan: A Bayesian Inference with Markov Chain Monte Carlo Method. Intern Med. 2020 Nov 1;59(21):2687–91. doi: 10.2169/internalmedicine.3477-19. PMID: 32669488. Exclusion Code: X4.32669488
158 Jablonka A, Dopfer C, Happle C, Tuberculosis specific interferon-gamma production in a current refugee cohort in western Europe. Int J Environ Res Public Health. 2018 Jun 14;15(6)doi: 10.3390/ijerph15061263. PMID: 29904012. Exclusion Code: X2.29904012
159 Jambaldorj E, Han M, Jeong JC, Poor predictability of QuantiFERON-TB assay in recipients and donors for tuberculosis development after kidney transplantation in an intermediate-TB-burden country. BMC Nephrol. 2017 Mar 14;18(1):88. doi: 10.1186/s12882-017-0506-9. PMID: 28292277. Exclusion Code: X2.28292277
160 Jamil SM, Oren E, Garrison GW, Diagnosis of tuberculosis in adults and children. Ann Am Thorac Soc. 2017 Feb;14(2):275–8. doi: 10.1513/AnnalsATS.201608-636CME. PMID: 28146376. Exclusion Code: X1.28146376
161 Janagond AB, Ganesan V, Vijay Kumar GS, Screening of health-care workers for latent tuberculosis infection in a tertiary care hospital. Int J Mycobacteriol. 2017 Jul-Sep;6(3):253–7. doi: 10.4103/ijmy.ijmy_82_17. PMID: 28776523. Exclusion Code: X6.28776523
162 Jeong DH, Kang J, Jung YJ, Comparison of latent tuberculosis infection screening strategies before tumor necrosis factor inhibitor treatment in inflammatory arthritis: IGRA-alone versus combination of TST and IGRA. PLoS One. 2018;13(7):e0198756. doi: 10.1371/journal.pone.0198756. PMID: 29975703. Exclusion Code: X2.29975703
163 Ji GY, Wang Y, Wu SQ, Association between TXNRD1 polymorphisms and antituberculosis drug-induced hepatotoxicity in a prospective study. Genet Mol Res. 2016 Sep 2;15(3)doi: 10.4238/gmr.15038296. PMID: 27706680. Exclusion Code: X3.27706680
164 Ji L, Lou YL, Wu ZX, Usefulness of interferon-γ release assay for the diagnosis of sputum smear-negative pulmonary and extra-pulmonary TB in Zhejiang Province, China. Infect Dis Poverty. 2017 Sep 1;6(1):121. doi: 10.1186/s40249-017-0331-1. PMID: 28859694. Exclusion Code: X3.28859694
165 Jia H, Pan L, Du B, Diagnostic performance of interferon-γ release assay for lymph node tuberculosis. Diagn Microbiol Infect Dis. 2016 May;85(1):56–60. doi: 10.1016/j.diagmicrobio.2016.02.001. PMID: 26971638. Exclusion Code: X2.26971638
166 Jia H, Pan L, Wang G, Assessment of interferon-gamma release assay in patients with non-tuberculous mycobacteria pulmonary disease. Clin Lab. 2019 Oct 1;65(10)doi: 10.7754/Clin.Lab.2019.181247. PMID: 31625364. Exclusion Code: X2.31625364
167 Jindani A, Borgulya G, de Patiño IW, A randomised Phase II trial to evaluate the toxicity of high-dose rifampicin to treat pulmonary tuberculosis. Int J Tuberc Lung Dis. 2016 Jun;20(6):832–8. doi: 10.5588/ijtld.15.0577. PMID: 27155189. Exclusion Code: X2.27155189
168 Jo Y, Shrestha S, Gomes I, Model-based cost-effectiveness of state-level latent tuberculosis interventions in California, Florida, New York and Texas. Clin Infect Dis. 2020 Jun 25doi: 10.1093/cid/ciaa857. PMID: 32584968. Exclusion Code: X6.32584968
169 Jung HJ, Kim YH, Kim YS, Differences in clinical manifestations according to the positivity of interferon-γ assay in patients with intestinal tuberculosis. Gut Liver. 2016 Jul 16;10(4):649–52. doi: 10.5009/gnl15439. PMID: 27282272. Exclusion Code: X2.27282272
170 Jung YJ, Woo HI, Jeon K, The significance of sensitive interferon gamma release assays for diagnosis of latent tuberculosis infection in patients receiving tumor necrosis factor-α antagonist therapy. PLoS One. 2015;10(10):e0141033. doi: 10.1371/journal.pone.0141033. PMID: 26474294. Exclusion Code: X2.26474294
171 Júnior JC L, Ramos RT T, Robazzi T. Treatment of latent tuberculosis in patients with juvenile rheumatic diseases: a systematic review. Rev Bras Reumatol Engl Ed. 2017 May-Jun;57(3):245–53. doi: 10.1016/j.rbre.2017.01.009. PMID: 28535897. Exclusion Code: X2.28535897
172 Kahwati LC, Feltner C, Halpern M, Primary care screening and treatment for latent tuberculosis infection in adults: evidence report and systematic review for the US Preventive Services Task Force. JAMA. 2016 Sep 6;316(9):970–83. doi: 10.1001/jama.2016.10357. PMID: 27599332. Exclusion Code: X6.27599332
173 Kahwati LC, Feltner C, Halpern M, U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Screening for latent tuberculosis infection in adults: an evidence review for the U.S. Preventive Services Task Force. Rockville (MD): Agency for Healthcare Research and Quality (US); 2016. Exclusion Code: X1.
174 Kakaire R, Kiwanuka N, Zalwango S, Excess risk of tuberculous infection among extra-household contacts of tuberculosis cases in an African city. Clin Infect Dis. 2020 Oct 16doi: 10.1093/cid/ciaa1556. PMID: 33064142. Exclusion Code: X2.33064142
175 Kalantri Y, Hemvani N, Chitnis DS. Evaluation of whole blood IFNgamma test using PPD and recombinant antigen challenge for diagnosis of pulmonary and extra-pulmonary tuberculosis. Indian J Exp Biol. 2009 Jun;47(6):463–8. PMID: 19634712. Exclusion Code: X9.19634712
176 Kamiya H, Ikushima S, Kondo K, Diagnostic performance of interferon-gamma release assays in elderly populations in comparison with younger populations. J Infect Chemother. 2013 Apr;19(2):217–22. doi: 10.1007/s10156-012-0480-x. PMID: 23108426. Exclusion Code: X9.23108426
177 Kang W, Wu M, Yang K, Factors associated with negative T-SPOT.TB results among smear-negative tuberculosis patients in China. Sci Rep. 2018 Mar 9;8(1):4236. doi: 10.1038/s41598-018-22495-3. PMID: 29523795. Exclusion Code: X5.29523795
178 Kang YA, Lee HW, Hwang SS, Usefulness of whole-blood interferon-gamma assay and interferon-gamma enzyme-linked immunospot assay in the diagnosis of active pulmonary tuberculosis. Chest. 2007 Sep;132(3):959–65. doi: 10.1378/chest.06-2805. PMID: 17505029. Exclusion Code: X9.17505029
179 Kang YJ, Park H, Park SB, Combined analysis of whole blood interferon gamma release assay and complete blood count analysis for rapid discrimination of active tuberculosis and latent tuberculosis infection. J Clin Tuberc Other Mycobact Dis. 2021 Aug;24:100253. doi: 10.1016/j.jctube.2021.100253. PMID: 34278005. Exclusion Code: X3.34278005
180 Karanja M, Kingwara L, Owiti P, Outcomes of isoniazid preventive therapy among people living with HIV in Kenya: A retrospective study of routine health care data. PLoS One. 2020;15(12):e0234588. doi: 10.1371/journal.pone.0234588. PMID: 33264300. Exclusion Code: X2.33264300
181 Karo B, Kohlenberg A, Hollo V, Isoniazid (INH) mono-resistance and tuberculosis (TB) treatment success: analysis of European surveillance data, 2002 to 2014. Euro Surveill. 2019 Mar;24(12)doi: 10.2807/1560-7917.es.2019.24.12.1800392. PMID: 30914081. Exclusion Code: X2.30914081
182 Katyal M, Leibowitz R, Venters H. IGRA-based screening for latent tuberculosis infection in persons newly incarcerated in New York City jails. J Correct Health Care. 2018 Apr;24(2): 156–70. doi: 10.1177/1078345818763868. PMID: 29633660. Exclusion Code: X4.29633660
183 Khawcharoenporn T, Aksornchindarat W, Yodpinij N, T-SPOT(^®^).TB Test for latent tuberculosis infection diagnosis and treatment guidance in Thai health-care professionals. Indian J Occup Environ Med. 2020 Jan-Apr;24(1):47–9. doi: 10.4103/ijoem.IJOEM_284_19. PMID: 32435118. Exclusion Code: X1.32435118
184 Khawcharoenporn T, Apisarnthanarak A, Sangkitporn S, Tuberculin Skin Test and QuantiFERON(^®^)-TB Gold In-Tube Test for diagnosing latent tuberculosis infection among Thai healthcare workers. Jpn J Infect Dis. 2016 May 20;69(3):224–30. doi: 10.7883/yoken.JJID.2015.181. PMID: 26255736. Exclusion Code: X2.26255736
185 Khumsri J, Hiransuthikul N, Hanvoravongchai P, Effectiveness of tuberculosis screening technology in the initiation of correct diagnosis of pulmonary tuberculosis at a tertiary care hospital in Thailand: comparative analysis of Xpert MTB/RIF versus sputum AFB smear. Asia Pac J Public Health. 2018 Sep;30(6):542–50. doi: 10.1177/1010539518800336. PMID: 30261738. Exclusion Code: X3.30261738
186 Kim HJ, Lee GH, Ryoo S, Role of confirmatory interferon-gamma release assays in school outbreaks of tuberculosis in South Korea. Int J Tuberc Lung Dis. 2015 May;19(5):576–81. doi: 10.5588/ijtld.14.0636. PMID: 25868027. Exclusion Code: X4.25868027
187 Kim SH, Lee SO, Park IA, Isoniazid treatment to prevent TB in kidney and pancreas transplant recipients based on an interferon-γ-releasing assay: an exploratory randomized controlled trial. J Antimicrob Chemother. 2015 May;70(5):1567–72. doi: 10.1093/jac/dku562. PMID: 25608587. Exclusion Code: X2.25608587
188 Kim SH, Oh S, Nham E, Risk Groups of Developing Active Tuberculosis in Liver Transplant Recipients in a Tuberculosis Endemic Area: Risk Stratification by Chest Image and Interferon Gamma Release Assay. Int J Infect Dis. 2021 Oct 28;113:359–66. doi: 10.1016/j.ijid.2021.10.043. PMID: 34718154. Exclusion Code: X2.34718154
189 Kim Y, Kim BK, Choi HJ, Lessons learned from continued TB outbreaks in a high school. PLoS One. 2017;12(11):e0188076. doi: 10.1371/journal.pone.0188076. PMID: 29145443. Exclusion Code: X2.29145443
190 Kim YJ, Kang JY, Kim SI, Predictors for false-negative QuantiFERON-TB Gold assay results in patients with extrapulmonary tuberculosis. BMC Infect Dis. 2018 Sep 10;18(1):457. doi: 10.1186/s12879-018-3344-x. PMID: 30200884. Exclusion Code: X2.30200884
191 Kimuda SG, Andia-Biraro I, Egesa M, Use of QuantiFERON^®^-TB Gold in-tube culture supernatants for measurement of antibody responses. PLoS One. 2017;12(11):e0188396. doi: 10.1371/journal.pone.0188396. PMID: 29161328. Exclusion Code: X4.29161328
192 King TC, Upfal M, Gottlieb A, T-SPOT.TB interferon-γ release assay performance in healthcare worker screening at nineteen U.S. hospitals. Am J Respir Crit Care Med. 2015 Aug 1;192(3):367–73. doi: 10.1164/rccm.201501-0199OC. PMID: 26017193. Exclusion Code: X2.26017193
193 Klautau GB, da Mota NVF, Salles MJC, Interferon-γ release assay as a sensitive diagnostic tool of latent tuberculosis infection in patients with HIV: a cross-sectional study. BMC Infect Dis. 2018 Nov 19;18(1):585. doi: 10.1186/s12879-018-3508-8. PMID: 30453903. Exclusion Code: X2.30453903
194 Knoll BM, Nog R, Wu Y, Three months of weekly rifapentine plus isoniazid for latent tuberculosis treatment in solid organ transplant candidates. Infection. 2017 Jun;45(3):335–9. doi: 10.1007/s15010-017-1004-5. PMID: 28276008. Exclusion Code: X6.28276008
195 Kobashi Y, Mouri K, Yagi S, Usefulness of the QuantiFERON TB-2G test for the differential diagnosis of pulmonary tuberculosis. Intern Med. 2008;47(4):237–43. PMID: 18277023. Exclusion Code: X3.18277023
196 Kobashi Y, Mouri K, Yagi S, Clinical utility of the QuantiFERON TB-2G test for elderly patients with active tuberculosis. Chest. 2008 May;133(5):1196–202. doi: 10.1378/chest.07-1995. PMID: 18263689. Exclusion Code: X3.18263689
197 Kobashi Y, Shimizu H, Ohue Y, False negative results of QuantiFERON TB-2G test in patients with active tuberculosis. Jpn J Infect Dis. 2009 Jul;62(4):300–2. PMID: 19628910. Exclusion Code: X9.19628910
198 Kobashi Y, Sugiu T, Shimizu H, Clinical evaluation of the T-SPOT.TB test for patients with indeterminate results on the QuantiFERON TB-2G test. Intern Med. 2009;48(3):137–42. PMID: 19182423. Exclusion Code: X3.19182423
199 König Walles J, Tesfaye F, Jansson M, Performance of QuantiFERON-TB Gold Plus for detection of latent tuberculosis infection in pregnant women living in a tuberculosis- and HIV-endemic setting. PLoS One. 2018;13(4):e0193589. doi: 10.1371/journal.pone.0193589. PMID: 29617458. Exclusion Code: X2.29617458
200 Kruczak K, Mastalerz L, Sładek K. Interferon-gamma release assays and tuberculin skin testing for diagnosing latent Mycobacterium tuberculosis infection in at-risk groups in Poland. Int J Mycobacteriol. 2016 Mar;5(1):27–33. doi: 10.1016/j.ijmyco.2015.10.004. PMID: 26927987. Exclusion Code: X4.26927987
201 Kruse M, Cruikshank W. End TB strategy: time to move on from the skin test to the interferon-γ release assays. Am J Public Health. 2019 Aug;109(8):1102–4. doi: 10.2105/ajph.2019.305167. PMID: 31268768. Exclusion Code: X6.31268768
202 Kuaban C, Toukam LDI, Sander M. Treatment outcomes and factors associated with unfavourable outcome among previously treated tuberculosis patients with isoniazid resistance in four regions of Cameroon. Pan Afr Med J. 2020;37:45. doi: 10.11604/pamj.2020.37.45.25684. PMID: 33209172. Exclusion Code: X2.33209172
203 La Distia Nora R, Sitompul R, Bakker M, Tuberculosis and other causes of uveitis in Indonesia. Eye (Lond). 2018 Mar;32(3):546–54. doi: 10.1038/eye.2017.231. PMID: 29099497. Exclusion Code: X9.29099497
204 La Manna MP, Orlando V, Li Donni P, Identification of plasma biomarkers for discrimination between tuberculosis infection/disease and pulmonary non tuberculosis disease. PLoS One. 2018;13(3):e0192664. doi: 10.1371/journal.pone.0192664. PMID: 29543810. Exclusion Code: X3.29543810
205 Laurenti P, Raponi M, de Waure C, Performance of interferon-γ release assays in the diagnosis of confirmed active tuberculosis in immunocompetent children: a new systematic review and meta-analysis. BMC Infect Dis. 2016 Mar 18;16:131. doi: 10.1186/s12879-016-1461-y. PMID: 26993789. Exclusion Code: X2.26993789
206 Lee EH, Kim SJ, Ha EJ, Treatment of latent tuberculous infection among health care workers at a tertiary hospital in Korea. Int J Tuberc Lung Dis. 2018 Nov 1;22(11):1336–43. doi: 10.5588/ijtld.18.0280. PMID: 30355414. Exclusion Code: X6.30355414
207 Lee JY, Kim BJ, Kim JM, Usefulness of the IgA and IgG responses to macrophage migration inhibitory factor for the diagnosis of tuberculosis. Diagnostics (Basel). 2020 Nov 23;10(11)doi: 10.3390/diagnostics10110991. PMID: 33238656. Exclusion Code: X5.33238656
208 Lee S, Lee JE, Kang JS, Long-term performance of the IGRA to predict and prevent active tuberculosis development in HIV-infected patients. Int J Tuberc Lung Dis. 2019 Apr 1;23(4):422–7. doi: 10.5588/ijtld.18.0198. PMID: 31064620. Exclusion Code: X2.31064620
209 Lee YJ, Lee J, Kim YY, Performance of whole-blood interferon-gamma release assay in patients admitted to the emergency department with pulmonary infiltrates. BMC Infect Dis. 2011;11:107. doi: 10.1186/1471-2334-11-107. PMID: 21513568. Exclusion Code: X3.21513568
210 Leung CC, Yam WC, Ho PL, T-Spot.TB outperforms tuberculin skin test in predicting development of active tuberculosis among household contacts. Respirology. 2015 Apr;20(3):496–503. doi: 10.1111/resp.12483. PMID: 25689894. Exclusion Code: X2.25689894
211 Li CY, Chen HC, Cheng HY, Role of QuantiFERON-TB-Gold In Tube assay for active and latent tuberculosis infection in investigation of tuberculosis outbreak in a university. J Microbiol Immunol Infect. 2015 Jun;48(3):263–8. doi: 10.1016/j.jmii.2013.08.022. PMID: 24184001. Exclusion Code: X5.24184001
212 Li F, Xu M, Qin C, Recombinant fusion ESAT6-CFP10 immunogen as a skin test reagent for tuberculosis diagnosis: an open-label, randomized, two-centre phase 2a clinical trial. Clin Microbiol Infect. 2016 Oct;22(10):889.e9-.e16. doi: 10.1016/j.cmi.2016.07.015. PMID: 27451942. Exclusion Code: X2.27451942
213 Li H, Yang L, Zheng CY, Use of bronchoalveolar lavage enzyme-linked immunospot for diagnosis of smear-negative pulmonary tuberculosis. Int J Tuberc Lung Dis. 2012 Dec;16(12):1668–73. doi: 10.5588/ijtld.12.0292. PMID: 23131267. Exclusion Code: X9.23131267
214 Li K, Yang C, Jiang Z, Quantitative investigation of factors relevant to the T cell spot test for tuberculosis infection in active tuberculosis. BMC Infect Dis. 2019 Jul 29;19(1):673. doi: 10.1186/s12879-019-4310-y. PMID: 31357953. Exclusion Code: X9.31357953
215 Li Y, Jia W, Lei G, Diagnostic efficiency of Xpert MTB/RIF assay for osteoarticular tuberculosis in patients with inflammatory arthritis in China. PLoS One. 2018;13(6):e0198600. doi: 10.1371/journal.pone.0198600. PMID: 29856840. Exclusion Code: X2.29856840
216 Liang Y, Yang Y, Hou Y, Comparison of three cellular immunoassays to detect tuberculosis infection in 876 healthy recruits. J Interferon Cytokine Res. 2019 Sep;39(9):547–53. doi: 10.1089/jir.2019.0053. PMID: 31107132. Exclusion Code: X2.31107132
217 Lin HS, Cheng CW, Lin MS, The clinical outcomes of oldest old patients with tuberculosis treated by regimens containing rifampicin, isoniazid, and pyrazinamide. Clin Interv Aging. 2016;11:299–306. doi: 10.2147/cia.s95411. PMID: 27042029. Exclusion Code: X2.27042029
218 Lin SY, Chien JY, Chiang HT, Ambulatory independence is associated with higher incidence of latent tuberculosis infection in long-term care facilities in Taiwan. J Microbiol Immunol Infect. 2021 Apr;54(2):319–26. doi: 10.1016/j.jmii.2019.07.008. PMID: 31624017. Exclusion Code: X2.31624017
219 Lin SY, Feng JY, Lee CY, Completion and adverse drag events of latent tuberculosis infection treatment in patients receiving dialysis: predictors and impacts of different regimens in a prospective cohort study. Antimicrob Agents Chemother. 2021 Feb 17;65(3)doi: 10.1128/aac.02184-20. PMID: 33361292. Exclusion Code: X2.33361292
220 Lin WC, Lin HH, Lee SS, Prevalence of latent tuberculosis infection in persons with and without human immunodeficiency virus infection using two interferon-gamma release assays and tuberculin skin test in a low human immunodeficiency virus prevalence, intermediate tuberculosis-burden country. J Microbiol Immunol Infect. 2016 Oct;49(5):729–36. doi: 10.1016/j.jmii.2014.08.010. PMID: 25442858. Exclusion Code: X2.25442858
221 Lines G, Hunter P, Bleything S. Improving treatment completion rates for latent tuberculosis infection: a review of two treatment regimens at a community health center. J Health Care Poor Underserved. 2015 Nov;26(4):1428–39. doi: 10.1353/hpu.2015.0126. PMID: 26548690. Exclusion Code: X6.26548690
222 Liu Q, Gao Y, Ou Q, Differential expression of CD64 in patients with Mycobacterium tuberculosis infection: A potential biomarker for clinical diagnosis and prognosis. J Cell Mol Med. 2020 Dec;24(23):13961–72. doi: 10.1111/jcmm.16004. PMID: 33164320. Exclusion Code: X9.33164320
223 Liu S, Wu M, A E, Factors associated with differential T cell responses to antigens ESAT-6 and CFP-10 in pulmonary tuberculosis patients. Medicine (Baltimore). 2021 Feb 26;100(8):e24615. doi: 10.1097/md.0000000000024615. PMID: 33663071. Exclusion Code: X9.33663071
224 Liu X, Bian S, Cheng X, Utility of T-cell interferon-γ release assays for the diagnosis of female genital tuberculosis in a tertiary referral hospital in Beijing, China. Medicine (Baltimore). 2016 Nov;95(44):e5200. doi: 10.1097/md.0000000000005200. PMID: 27858862. Exclusion Code: X2.27858862
225 Liu Y, Birch S, Newbold KB, Barriers to treatment adherence for individuals with latent tuberculosis infection: A systematic search and narrative synthesis of the literature. Int J Health Plann Manage. 2018 Apr;33(2):e416–e33. doi: 10.1002/hpm.2495. PMID: 29431235. Exclusion Code: X5.29431235
226 Liu Y, Li X, Liu W, IL-6 release of Rv0183 antigen-stimulated whole blood is a potential biomarker for active tuberculosis patients. J Infect. 2018 Apr;76(4):376–82. doi: 10.1016/j.jinf.2017.11.004. PMID: 29174965. Exclusion Code: X3.29174965
227 Lu D, Chen C, Yu S, Diagnosis of tuberculous meningitis using a combination of peripheral blood T-SPOT.TB and cerebrospinal fluid interferon-γ detection methods. Lab Med. 2016 Feb;47(1):6–12. doi: 10.1093/labmed/lmv010. PMID: 26732776. Exclusion Code: X2.26732776
228 Lucet JC, Abiteboul D, Estellat C, Interferon-γ release assay vs. tuberculin skin test for tuberculosis screening in exposed healthcare workers: a longitudinal multicenter comparative study. Infect Control Hosp Epidemiol. 2015 May;36(5):569–74. doi: 10.1017/ice.2015.19. PMID: 25682769. Exclusion Code: X2.25682769
229 Lui G, Lee N, Cheung SW, Interferon gamma release assay for differentiating tuberculosis among pneumonia cases in acute healthcare setting. J Infect. 2011 Jun;62(6):440–7. doi: 10.1016/j.jinf.2011.04.011. PMID: 21575991. Exclusion Code: X3.21575991
230 Lung T, Marks GB, Nhung NV, Household contact investigation for the detection of tuberculosis in Vietnam: economic evaluation of a cluster-randomised trial. Lancet Glob Health. 2019 Mar;7(3):e376–e84. doi: 10.1016/s2214-109x(18)30520-5. PMID: 30784638. Exclusion Code: X6.30784638
231 Luo Y, Tan Y, Yu J, The performance of pleural fluid T-SPOT.TB assay for diagnosing tuberculous pleurisy in China: a two-center prospective cohort study. Front Cell Infect Microbiol. 2019;9:10. doi: 10.3389/fcimb.2019.00010. PMID: 30761274. Exclusion Code: X2.30761274
232 Luo Y, Tang G, Yuan X, Combination of Blood Routine Examination and T-SPOT.TB Assay for Distinguishing Between Active Tuberculosis and Latent Tuberculosis Infection. Front Cell Infect Microbiol. 2021;11:575650. doi: 10.3389/fcimb.2021.575650. PMID: 34277462. Exclusion Code: X4.34277462
233 Luo Y, Xue Y, Cai Y, Lymphocyte Non-Specific Function Detection Facilitating the Stratification of Mycobacterium tuberculosis Infection. Front Immunol. 2021;12:641378. doi: 10.3389/fimmu.2021.641378. PMID: 33953714. Exclusion Code: X2.33953714
234 Luo Y, Xue Y, Tang G, Lymphocyte-Related Immunological Indicators for Stratifying Mycobacterium tuberculosis Infection. Front Immunol. 2021;12:658843. doi: 10.3389/fimmu.2021.658843. PMID: 34276653. Exclusion Code: X3.34276653
235 Ma Y, Li R, Shen J, Clinical effect of T-SPOT.TB test for the diagnosis of tuberculosis. BMC Infect Dis. 2019 Nov 21;19(1):993. doi: 10.1186/s12879-019-4597-8. PMID: 31752713. Exclusion Code: X2.31752713
236 Macaraig MM, Jalees M, Lam C, Improved treatment completion with shorter treatment regimens for latent tuberculous infection. Int J Tuberc Lung Dis. 2018 Nov 1;22(11):1344–9. doi: 10.5588/ijtld.18.0035. PMID: 30355415. Exclusion Code: X6.30355415
237 Makhmudova M, Maxsumova Z, Rajabzoda A, Risk factors for unfavourable treatment outcomes among rifampicin-resistant tuberculosis patients in Tajikistan. Int J Tuberc Lung Dis. 2019 Mar 1;23(3):331–6. doi: 10.5588/ijtld.18.0311. PMID: 30871664. Exclusion Code: X6.30871664
238 Malacarne J, Rios DP, Silva CM, Prevalence and factors associated with latent tuberculosis infection in an indigenous population in the Brazilian Amazon. Rev Soc Bras Med Trop. 2016 Jul-Aug;49(4):456–64. doi: 10.1590/0037-8682-0220-2016. PMID: 27598632. Exclusion Code: X2.27598632
239 Mamishi S, Mahmoudi S, Banar M, Diagnostic accuracy of interferon (IFN)-γ inducible protein 10 (IP-10) as a biomarker for the discrimination of active and latent tuberculosis. Mol Biol Rep. 2019 Dec;46(6):6263–9. doi: 10.1007/s11033-019-05067-0. PMID: 31564016. Exclusion Code: X5.31564016
240 Mamishi S, Marjani M, Pourakbari B, Evaluation of treatment response in active tuberculosis using QuantiFERON-TB Gold Plus. Eur Cytokine Netw. 2020 Dec 1;31(4):129–33. doi: 10.1684/ecn.2020.0457. PMID: 33648920. Exclusion Code: X5.33648920
241 Mamishi S, Pourakbari B, Shams H, Improving T-cell assays for diagnosis of latent TB infection: Confirmation of the potential role of testing Interleukin-2 release in Iranian patients. Allergol Immunopathol (Madr). 2016 Jul-Aug;44(4):314–21. doi: 10.1016/j.aller.2015.09.004. PMID: 26786720. Exclusion Code: X3.26786720
242 Manabe YC, Worodria W, van Leth F, Prevention of early mortality by presumptive tuberculosis therapy study: an open label, randomized controlled trial. Am J Trop Med Hyg. 2016;95(6):1265–71. doi: 10.4269/ajtmh.16-0239. PMID: CN-01286706. Exclusion Code: X2.27928077
243 Mancuso JD, Diffenderfer JM, Ghassemieh BJ, The prevalence of latent tuberculosis infection in the United States. Am J Respir Crit Care Med. 2016 Aug 15;194(4):501–9. doi: 10.1164/rccm.201508-1683OC. PMID: 26866439. Exclusion Code: X5.26866439
244 Mantri AK, Meena P, Puri AS, Comparison of interferon-gamma release assay and tuberculin skin test for the screening of latent tuberculosis in inflammatory bowel disease patients: Indian scenario. Tuberc Res Treat. 2021;2021:6682840. doi: 10.1155/2021/6682840. PMID: 33575041. Exclusion Code: X8.33575041
245 Martínez-Aguilar G, Serrano CJ, Castañeda-Delgado JE, Associated risk factors for latent tuberculosis infection in subjects with diabetes. Arch Med Res. 2015 Apr;46(3):221–7. doi: 10.1016/j.arcmed.2015.03.009. PMID: 25864989. Exclusion Code: X4.25864989
246 Matambo R, Takarinda KC, Thekkur P, Treatment outcomes of multi drug resistant and rifampicin resistant Tuberculosis in Zimbabwe: A cohort analysis of patients initiated on treatment during 2010 to 2015. PLoS One. 2020;15(4):e0230848. doi: 10.1371/journal.pone.0230848. PMID: 32353043. Exclusion Code: X4.32353043
247 Mathema B, Andrews JR, Cohen T, Drivers of tuberculosis transmission. J Infect Dis. 2017 Nov 3;216(suppl_6):S644–s53. doi: 10.1093/infdis/jix354. PMID: 29112745. Exclusion Code: X1.29112745
248 Mayito J, Meya DB, Rhein J, Utility of the monocyte to lymphocyte ratio in diagnosing latent tuberculosis among HIV-infected individuals with a negative tuberculosis symptom screen. PLoS One. 2020;15(11):e0241786. doi: 10.1371/journal.pone.0241786. PMID: 33166312. Exclusion Code: X2.33166312
249 Maze MJ, Paynter J, Chiu W, Therapeutic drug monitoring of isoniazid and rifampicin during anti-tuberculosis treatment in Auckland, New Zealand. Int J Tuberc Lung Dis. 2016 Jul;20(7):955–60. doi: 10.5588/ijtld.15.0792. PMID: 27287650. Exclusion Code: X5.27287650
250 McClintock AH, Eastment M, McKinney CM, Treatment completion for latent tuberculosis infection: a retrospective cohort study comparing 9 months of isoniazid, 4 months of rifampin and 3 months of isoniazid and rifapentine. BMC Infect Dis. 2017 Feb 14;17(1):146. doi: 10.1186/s12879-017-2245-8. PMID: 28196479. Exclusion Code: X6.28196479
251 McGoldrick M. Tuberculosis testing: from routine to risk-based screening for home care and hospice staff. Home Healthc Now. 2017 Feb;35(2):121–2. doi: 10.1097/nhh.0000000000000505. PMID: 28157780. Exclusion Code: X1.28157780
252 Meier T, Enders M. High reproducibility of the interferon-gamma release assay T-SPOT.TB in serial testing. Eur J Clin Microbiol Infect Dis. 2021 Jan;40(1):85–93. doi: 10.1007/s10096-020-03997-3. PMID: 32770282. Exclusion Code: X5.32770282
253 Memish ZA, Mah MW, Mahmood SA, Clinico-diagnostic experience with tuberculous lymphadenitis in Saudi Arabia. Clin Microbiol Infect. 2000 Mar;6(3):137–41. PMID: 11168089. Exclusion Code: X9.11168089
254 Metcalfe JZ, Cattamanchi A, Vittinghoff E, Evaluation of quantitative IFN-gamma response for risk stratification of active tuberculosis suspects. Am J Respir Crit Care Med. 2010 Jan 1;181(1):87–93. doi: 10.1164/rccm.200906-0981OC. PMID: 19797760. Exclusion Code: X3.19797760
255 Millard J, Ugarte-Gil C, Moore DA. Multidrug resistant tuberculosis. BMJ. 2015 Feb 26;350:h882. doi: 10.1136/bmj.h882. PMID: 25721508. Exclusion Code: X1.25721508
256 Mollo B, Jouveshomme S, Philippart F, Biological markers in the diagnosis of tuberculous pleural effusion. Ann Biol Clin (Paris). 2017 Feb 1;75(1):19–27. doi: 10.1684/abc.2016.1201. PMID: 28057604. Exclusion Code: X7.28057604
257 Moon HH, Park SY, Kim JM, Isoniazid prophylaxis for latent tuberculosis infections in liver rransplant recipients in a tuberculosis-endemic area. Ann Transplant. 2017 Jun 5;22:338–45. doi: 10.12659/aot.902989. PMID: 28579606. Exclusion Code: X6.28579606
258 Moon HW, Gaur RL, Tien SS, Evaluation of QuantiFERON-TB Gold-Plus in health care workers in a low-incidence setting. J Clin Microbiol. 2017 Jun;55(6):1650–7. doi: 10.1128/jcm.02498-16. PMID: 28298455. Exclusion Code: X2.28298455
259 Moon HW, Yi A, Yoon S, Serial Assays of QuantiFERON-TB Gold In-Tube and QuantiFERON-TB Gold-Plus in Subjects Exposed to Patients with Active Tuberculosis. Ann Lab Med. 2020 Sep;40(5):428–30. doi: 10.3343/alm.2020.40.5.428. PMID: 32311859. Exclusion Code: X2.32311859
260 Moro RN, Borisov AS, Saukkonen J, Factors associated with noncompletion of latent tuberculosis infection treatment: experience from the PREVENT TB trial in the United States and Canada. Clin Infect Dis. 2016 Jun 1;62(11):1390–400. doi: 10.1093/cid/ciw126. PMID: 26951571. Exclusion Code: X2.26951571
261 Moro RN, Sterling TR, Saukkonen J, Factors associated with non-completion of follow-up: 33-month latent tuberculous infection treatment trial. Int J Tuberc Lung Dis. 2017 Mar 1;21(3):286–96. doi: 10.5588/ijtld.16.0469. PMID: 28087928. Exclusion Code: X5.28087928
262 Mostafavi E, Nasehi M, Hashemi Shahraki A, Comparison of the tuberculin skin test and the QuantiFERON-TB Gold test in detecting latent tuberculosis in health care workers in Iran. Epidemiol Health. 2016;38:e2016032. doi: 10.4178/epih.e2016032. PMID: 27457062. Exclusion Code: X2.27457062
263 Mueller Y, Mpala Q, Kerschberger B, Adherence, tolerability, and outcome after 36 months of isoniazid-preventive therapy in 2 rural clinics of Swaziland: A prospective observational feasibility study. Medicine (Baltimore). 2017 Sep;96(35):e7740. doi: 10.1097/md.0000000000007740. PMID: 28858089. Exclusion Code: X2.28858089
264 Muñoz L, Santin M, Alcaide F, QuantiFERON-TB Gold In-Tube as a confirmatory test for tuberculin skin test in tuberculosis contact tracing: a noninferiority clinical trial. Clin Infect Dis. 2018 Jan 18;66(3):396–403. doi: 10.1093/cid/cix745. PMID: 29020191. Exclusion Code: X4.29020191
265 Napoli C, Ferretti F, Di Ninno F, Screening for tuberculosis in health care workers: experience in an Italian teaching hospital. Biomed Res Int. 2017;2017:7538037. doi: 10.1155/2017/7538037. PMID: 28337457. Exclusion Code: X2.28337457
266 Narasimhan P, MacIntyre CR, Mathai D, High rates of latent TB infection in contacts and the wider community in South India. Trans R Soc Trop Med Hyg. 2017 Feb 1;111(2):55–61. doi: 10.1093/trstmh/trx016. PMID: 28407146. Exclusion Code: X2.28407146
267 Nathavitharana RR. Stamping out tuberculosis: the importance of diagnostic innovation and effective implementation. Ann Am Thorac Soc. 2019 Sep;16(9):1112–3. doi: 10.1513/AnnalsATS.201902-173ED. PMID: 31145637. Exclusion Code: X1.31145637
268 Nemes E, Rozot V, Geldenhuys H, Optimization and interpretation of serial QuantiFERON testing to measure acquisition of mycobacterium tuberculosis Infection. Am J Respir Crit Care Med. 2017 Sep 1;196(5):638–48. doi: 10.1164/rccm.201704-0817OC. PMID: 28737960. Exclusion Code: X3.28737960
269 Nikolayevskyy V, Kontsevaya I, Nikolaevskaya E, Diagnostic performance and impact of routinely implemented Xpert^®^ MTB/RIF assay in a setting of high incidence of drug-resistant TB in Odessa Oblast, Ukraine. Clin Microbiol Infect. 2019 Aug;25(8):1040.e1-.e6. doi: 10.1016/j.cmi.2018.12.013. PMID: 30590114. Exclusion Code: X4.30590114
270 Nishimura T, Ota M, Mori M, The annual risk of tuberculosis infection in newly hired researchers and healthcare workers using interferon-gamma release assay in Japan. J Infect Chemother. 2020 Aug;26(8):818–22. doi: 10.1016/j.jiac.2020.03.020. PMID: 32327332. Exclusion Code: X2.32327332
271 Njie GJ, Morris SB, Woodruff RY, Isoniazid-rifapentine for latent tuberculosis infection: a systematic review and metaanalysis. Am J Prev Med. 2018 Aug;55(2):244–52. doi: 10.1016/j.amepre.2018.04.030. PMID: 29910114. Exclusion Code: X6.29910114
272 Ochoa J, León AL, Ramírez IC, Prevalence of tuberculosis infection in healthcare workers of the public hospital network in Medellín, Colombia: a Bayesian approach. Epidemiol Infect. 2017 Apr;145(6):1095–106. doi: 10.1017/s0950268816003150. PMID: 28065210. Exclusion Code: X2.28065210
273 Ozekinci T, Ozbek E, Celik Y. Comparison of tuberculin skin test and a specific T-cell-based test, T-SPOT.TB, for the diagnosis of latent tuberculosis infection. J Int Med Res. 2007 Sep-Oct;35(5):696–703. PMID: 17944056. Exclusion Code: X9.17944056
274 Palazzo R, Spensieri F, Massari M, Use of whole-blood samples in in-house bulk and single-cell antigen-specific gamma interferon assays for surveillance of Mycobacterium tuberculosis infections. Clin Vaccine Immunol. 2008 Feb;15(2):327–37. doi: 10.1128/cvi.00342-07. PMID: 18032595. Exclusion Code: X9.18032595
275 Parcell BJ, Jarchow-MacDonald AA, Seagar AL, Three year evaluation of Xpert MTB/RIF in a low prevalence tuberculosis setting: A Scottish perspective. J Infect. 2017 May;74(5):466–72. doi: 10.1016/j.jinf.2017.02.005. PMID: 28237624. Exclusion Code: X3.28237624
276 Park JH, Koo B, Kim MJ, Utility of plasma cell-free DNA detection using homobifunctional imidoesters using a microfluidic system for diagnosing active tuberculosis. Infect Dis (Lond). 2021 Aug 18:1–7. doi: 10.1080/23744235.2021.1963839. PMID: 34405761. Exclusion Code: X5.34405761
277 Park SH, Lee SJ, Cho YJ, A prospective cohort study of latent tuberculosis in adult close contacts of active pulmonary tuberculosis patients in Korea. Korean J Intern Med. 2016 May;31(3):517–24. doi: 10.3904/kjim.2015.095. PMID: 27052266. Exclusion Code: X5.27052266
278 Park SJ, Jo KW, Yoo B, Comparison of LTBI treatment regimens for patients receiving anti-tumour necrosis factor therapy. Int J Tuberc Lung Dis. 2015 Mar;19(3):342–8. doi: 10.5588/ijtld.14.0554. PMID: 25686145. Exclusion Code: X2.25686145
279 Pasticci MB, Papalini C, Murgia N, QuantiFERON-TB and tuberculin skin test in patients with active tuberculosis: the experience of a single medium-sized Italian University Hospital. Infez Med. 2021 Jun 1;29(2):229–35. PMID: 34061788. Exclusion Code: X9.34061788
280 Pathanapitoon K, Kunavisarut P, Sirirungsi W, Looking for ocular tuberculosis: prevalence and clinical manifestations of patients with uveitis and positive QuantiFERON(^®^)-TB Gold test. Ocul Immunol Inflamm. 2018;26(6):819–26. doi: 10.1080/09273948.2016.1245760. PMID: 27849401. Exclusion Code: X2.27849401
281 Pattanaik D, Gupta S, Islam S, Conversion of tuberculosis screening tests during biologic therapy among veteran patient population with rheumatic disease. ACR Open Rheumatol. 2019 Nov;1(9):542–5. doi: 10.1002/acr2.11070. PMID: 31777837. Exclusion Code: X2.31777837
282 Pease C, Alvarez G, Mallick R, Cost-effectiveness analysis of 3 months of weekly rifapentine and isoniazid compared to isoniazid monotherapy in a Canadian arctic setting. BMJ Open. 2021 May 13;11(5):e047514. doi: 10.1136/bmjopen-2020-047514. PMID: 33986067. Exclusion Code: X6.33986067
283 Pease C, Amaratunga KR, Alvarez GG. A shorter treatment regimen for latent tuberculosis infection holds promise for at-risk Canadians. Can Commun Dis Rep. 2017 Mar 2;43(3-4):67–71. doi: 10.14745/ccdr.v43i34a02. PMID: 29770067. Exclusion Code: XI.29770067
284 Pease C, Hutton B, Yazdi F, A systematic review of adverse events of rifapentine and isoniazid compared to other treatments for latent tuberculosis infection. Pharmacoepidemiol Drug Saf. 2018 Jun;27(6):557–66. doi: 10.1002/pds.4423. PMID: 29573031. Exclusion Code: X2.29573031
285 Penn-Nicholson A, Nemes E, Hanekom WA, Mycobacterium tuberculosis-specific CD4 T cells are the principal source of IFN-γ in QuantiFERON assays in healthy persons. Tuberculosis (Edinb). 2015 May;95(3):350–1. doi: 10.1016/j.tube.2015.03.002. PMID: 25802032. Exclusion Code: X2.25802032
286 Pérez-Barbosa L, Esquivel-Valerio JA, Arana-Guajardo AC, Increased detection of latent tuberculosis by tuberculin skin test and booster phenomenon in early rheumatoid arthritis patients. Rheumatol Int. 2015 Sep;35(9):1555–9. doi: 10.1007/s00296-015-3246-9. PMID: 25773658. Exclusion Code: X2.25773658
287 Pérez-Recio S, Pallarès N, Grijota-Camino MD, Identification of Recent Tuberculosis Exposure Using QuantiFERON-TB Gold Plus, a Multicenter Study. Microbiol Spectr. 2021 Nov 10;9(3):e0097221. doi: 10.1128/Spectrum.00972-21. PMID: 34756079. Exclusion Code: X2.34756079
288 Peters C, Kozak A, Nienhaus A, Risk of occupational latent tuberculosis infection among health personnel measured by interferon-gamma release assays in low Incidence countries-a systematic review and meta-analysis. Int JEnviron Res Public Health. 2020 Jan 16;17(2)doi: 10.3390/ijerph17020581. PMID: 31963207. Exclusion Code: X6.31963207
289 Petruccioli E, Vanini V, Chiacchio T, Modulation of interferon-gamma response to QuantiFERON-TB-plus detected by enzyme-linked immunosorbent assay in patients with active and latent tuberculosis infection. Int J Mycobacteriol. 2016 Dec;5 Suppl 1:S143–s4. doi: 10.1016/j.ijmyco.2016.09.029. PMID: 28043514. Exclusion Code: X2.28043514
290 Pieterman ED, Liqui Lung FG, Verbon A, A multicentre verification study of the QuantiFERON(^®^)-TB Gold Plus assay. Tuberculosis (Edinb). 2018 Jan;108:136–42. doi: 10.1016/j.tube.2017.11.014. PMID: 29523314. Exclusion Code: X2.29523314
291 Ping PA, Zakaria R, Islam MA, Prevalence and Risk Factors of Latent Tuberculosis Infection (LTBI) in Patients with Type 2 Diabetes Mellitus (T2DM). Int J Environ Res Public Health. 2021 Jan 4;18(1)doi: 10.3390/ijerph18010305. PMID: 33406582. Exclusion Code: X3.33406582
292 Piotrowski WJ, Adam B, Gwadera Ł, QuantiFERON-TB-GOLD In-Tube in patients with sarcoidosis. Adv Respir Med. 2018;86(5):234–9. doi: 10.5603/arm.2018.0037. PMID: 30378651. Exclusion Code: X9.30378651
293 Pourakbari B, Mamishi S, Benvari S, Comparison of the QuantiFERON-TB Gold Plus and QuantiFERON-TB Gold In-Tube interferon-γ release assays: A systematic review and meta-analysis. Adv Med Sci. 2019 Sep;64(2):437–43. doi: 10.1016/j.advms.2019.09.001. PMID: 31586819. Exclusion Code: X6.31586819
294 Pourakbari B, Yousefi K, Mahmoudi S, Evaluation of the QuantiFERON^®^-TB Gold In-Tube assay and tuberculin skin test for the diagnosis of latent tuberculosis infection in an Iranian referral hospital. Infect Disord Drug Targets. 2019;19(2):141–4. doi: 10.2174/1871526518666180228164036. PMID: 29493468. Exclusion Code: X2.29493468
295 Qin L, Zhang L, Zhang Y, Diagnostic value of T-cell interferon-γ release assays on cerebrospinal fluid for tuberculous meningitis. PLoS One. 2015;10(11):e0141814. doi: 10.1371/journal.pone.0141814. PMID: 26545256. Exclusion Code: X2.26545256
296 Rahimi BA, Rahimy N, Ahmadi Q, Treatment outcome of tuberculosis treatment regimens in Kandahar, Afghanistan. Indian J Tuberc. 2020 Jan;67(1):87–93. doi: 10.1016/j.ijtb.2018.10.008. PMID: 32192624. Exclusion Code: X4.32192624
297 Rego K, Pereira K, MacDougall J, Utility of the T-SPOT(^®^).TB tesťs borderline category to increase test resolution for results around the cut-off point. Tuberculosis (Edinb). 2018 Jan;108:178–85. doi: 10.1016/j.tube.2017.12.005. PMID: 29523321. Exclusion Code: X2.29523321
298 Reichler MR, Khan A, Sterling TR, Risk factors for tuberculosis and effect of preventive therapy among close contacts of persons with infectious tuberculosis. Clin Infect Dis. 2020 Apr 10;70(8):1562–72. doi: 10.1093/cid/ciz438. PMID: 31127813. Exclusion Code: X6.31127813
299 Rendini T, Levis W. Quantiferon-Gold tuberculosis test cannot detect latent tuberculosis in patients with leprosy. Clin Infect Dis. 2015 Nov 1;61(9):1439–40. doi: 10.1093/cid/civ588. PMID: 26209684. Exclusion Code: X2.26209684
300 Ruan QL, Huang XT, Yang QL, Efficacy and safety of weekly rifapentine and isoniazid for tuberculosis prevention in Chinese silicosis patients: a randomized controlled trial. Clin Microbiol Infect. 2020 Jun 15doi: 10.1016/j.cmi.2020.06.008. PMID: 32553881. Exclusion Code: X2.32553881
301 Ruhwald M, Aggerbeck H, Gallardo RV, Safety and efficacy of the C-Tb skin test to diagnose Mycobacterium tuberculosis infection, compared with an interferon γ release assay and the tuberculin skin test: a phase 3, double-blind, randomised, controlled trial. Lancet Respir Med. 2017 Apr;5(4):259–68. doi: 10.1016/s2213-2600(16)30436-2. PMID: 28159608. Exclusion Code: X2.28159608
302 Rumende CM, Hadi EJ, Tanjung G, The benefit of interferon-gamma release assay for diagnosis of extrapulmonary tuberculosis. Acta Med Indones. 2018 Apr;50(2):138–43. PMID: 29950533. Exclusion Code: X2.29950533
303 Sakiyama M, Kozaki Y, Komatsu T, Specificity of tuberculin skin test improved by BCG immunization schedule change in Japan. J Infect Chemother. 2021 Sep;27(9):1306–10. doi: 10.1016/j.jiac.2021.04.016. PMID: 33952418. Exclusion Code: X5.33952418
304 Sakr CJ, Musharrafieh UM, Banna HS, Risks and benefits of QuantiFERON(^®^)-TB testing for LTBI screening of health workers. Int J Tuberc Lung Dis. 2021 Jan 1;25(1):72–4. doi: 10.5588/ijtld.20.0334. PMID: 33384050. Exclusion Code: X1.33384050
305 Salindri AD, Auld SC, Schechter MC, Negative tuberculin skin test result predicts all-cause mortality among tuberculosis patients with HIV and diabetes comorbidity. Ann Epidemiol. 2019 May;33:72–8.e4. doi: 10.1016/j.annepidem.2019.02.005. PMID: 30954339. Exclusion Code: X9.30954339
306 Samandari T, Agizew TB, Nyirenda S, Tuberculosis incidence after 36 months' isoniazid prophylaxis in HIV-infected adults in Botswana: a posttrial observational analysis. AIDS (London, England). 2015;29(3):351–9. doi: 10.1097/QAD.0000000000000535. PMID: CN-01070333. Exclusion Code: X2.25686683
307 Sandhu P, Taylor C, Miller RF, Implementation of routine interferon-gamma release assay testing in a South London HIV cohort. Int J STD AIDS. 2020 Mar;31(3):264–7. doi: 10.1177/0956462419893536. PMID: 32036752. Exclusion Code: X2.32036752
308 Sanduzzi A, Marchetiello I, Bocchino M, Tuberculin skin test and/or interferon gamma release assay: is it still time to debate? Infez Med. 2017 Mar 1;25(1):80–1. PMID: 28353462. Exclusion Code: X1.28353462
309 Santos AP, Corrêa RDS, Ribeiro-Alves M, Application of Venn's diagram in the diagnosis of pleural tuberculosis using IFN-γ, IP-10 and adenosine deaminase. PLoS One. 2018;13(8):e0202481. doi: 10.1371/journal.pone.0202481. PMID: 30148839. Exclusion Code: X2.30148839
310 Santos JA, Duarte R, Nunes C. Host factors associated to false negative and indeterminate results in an interferon-γ release assay in patients with active tuberculosis. Pulmonology. 2020 Nov-Dec;26(6):353–62. doi: 10.1016/j.pulmoe.2019.11.001. PMID: 31843341. Exclusion Code: X2.31843341
311 Sato R, Nagai H, Matsui H, Interferon-gamma release assays in patients with Mycobacterium kansasii pulmonary infection: A retrospective survey. J Infect. 2016 Jun;72(6):706–12. doi: 10.1016/j.jinf.2016.03.011. PMID: 27025204. Exclusion Code: X2.27025204
312 Schein YL, Madebo T, Andersen HE, Treatment completion for latent tuberculosis infection in Norway: a prospective cohort study. BMC Infect Dis. 2018 Nov 19;18(1):587. doi: 10.1186/s12879-018-3468-z. PMID: 30453946. Exclusion Code: X9.30453946
313 Schichter-Konfino V, Halasz K, Grushko G, Interferon-gamma-release assay prevents unnecessary tuberculosis therapy. Isr Med Assoc J. 2015 Apr;17(4):223–6. PMID: 26040047. Exclusion Code: X2.26040047
314 Schmidt BM, Engel ME, Abdullahi L, Effectiveness of control measures to prevent occupational tuberculosis infection in health care workers: a systematic review. BMC Public Health. 2018 May 25;18(1):661. doi: 10.1186/s12889-018-5518-2. PMID: 29801449. Exclusion Code: X6.29801449
315 Schmit KM, Lobato MN, Lang SG, High Completion Rate for 12 Weekly Doses of Isoniazid and Rifapentine as Treatment for Latent Mycobacterium tuberculosis Infection in the Federal Bureau of Prisons. J Public Health Manag Pract. 2019 Mar/Apr;25(2):E1–e6. doi: 10.1097/phh.0000000000000822. PMID: 30024493. Exclusion Code: X4.30024493
316 Scordo JM, Aguillón-Durán GP, Ayala D, Interferon gamma release assays for detection of latent Mycobacterium tuberculosis in older Hispanic people. Int J Infect Dis. 2021 Oct;111:85–91. doi: 10.1016/j.ijid.2021.08.014. PMID: 34389503. Exclusion Code: X2.34389503
317 Scriba TJ, Fiore-Gartland A, Penn-Nicholson A, Biomarker-guided tuberculosis preventive therapy (CORTIS): a randomised controlled trial. Lancet Infect Dis. 2021 Mar;21(3):354–65. doi: 10.1016/s1473-3099(20)30914-2. PMID: 33508224. Exclusion Code: X2.33508224
318 Seyhan EC, Gunluoglu G, Gunluoglu MZ, Predictive value of the tuberculin skin test and QuantiFERON-tuberculosis Gold In-Tube test for development of active tuberculosis in hemodialysis patients. Ann Thorac Med. 2016 Apr-Jun;11(2):114–20. doi: 10.4103/1817-1737.180023. PMID: 27168859. Exclusion Code: X2.27168859
319 Shalabi NM, Houssen ME. Discrepancy between the tuberculin skin test and the levels of serum interferon-gamma in the diagnosis of tubercular infection in contacts. Clin Biochem. 2009 Nov;42(16-17):1596–601. doi: 10.1016/j.clinbiochem.2009.08.013. PMID: 19732759. Exclusion Code: X9.19732759
320 Shi X, Zhang L, Zhang Y, Utility of T-cell interferon-γ release assays for etiological diagnosis of classic fever of unknown origin in a high tuberculosis endemic area--a pilot prospective cohort. PLoS One. 2016;11(1):e0146879. doi: 10.1371/journal.pone.0146879. PMID: 26784112. Exclusion Code: X2.26784112
321 Shlomi D, Galor I, More A, Latent tuberculosis infection prevalence in second generation immigrants from high to low TB burden countries. Pulmonology. 2021 Jan 3doi: 10.1016/j.pulmoe.2020.12.001. PMID: 33408042. Exclusion Code: X5.33408042
322 Shrestha R, Gyawali P, Yadav BK, In-vitro assessment of cell-mediated immunity by demonstrating effector-t cells for diagnosis of tuberculosis in Nepalese subjects. Nepal Med Coll J. 2011 Dec;13(4):275–8. PMID: 23016479. Exclusion Code: X9.23016479
323 Silva DR, Sotgiu G, D'Ambrosio L, Diagnostic performances of the Xpert MTB/RIF in Brazil. Respir Med. 2018 Jan;134:12–5. doi: 10.1016/j.rmed.2017.11.012. PMID: 29413498. Exclusion Code: X3.29413498
324 Simkins J, Abbo LM, Camargo JF, Twelve-week rifapentine plus isoniazid versus 9-month isoniazid for the treatment of latent tuberculosis in renal transplant candidates. Transplantation. 2017 Jun;101(6):1468–72. doi: 10.1097/tp.0000000000001329. PMID: 27548035. Exclusion Code: X2.27548035
325 Simkins J, Donato-Santana C, Morris MI, Treatment of latent tuberculosis infection with short-course regimens in potential living kidney donors. Transpl Infect Dis. 2020 Apr;22(2):e13244. doi: 10.1111/tid.13244. PMID: 31923346. Exclusion Code: X6.31923346
326 Simkins J, Morris MI, Abbo LM, Severe hypertension after initiation of rifapentine/isoniazid for latent tuberculosis in renal transplant candidates. Transpl Int. 2017 Jan;30(1):108–9. doi: 10.1111/tri.12881. PMID: 28032405. Exclusion Code: X6.28032405
327 Simmons JD, Van PT, Stein CM, Monocyte metabolic transcriptional programs associate with resistance to tuberculin skin test/interferon-γ release assay conversion. J Clin Invest. 2021 Jul 15;131(14)doi: 10.1172/jci140073. PMID: 34111032. Exclusion Code: X2.34111032
328 Sineke T, Evans D, Schnippel K, The impact of adverse events on health-related quality of life among patients receiving treatment for drug-resistant tuberculosis in Johannesburg, South Africa. Health Qual Life Outcomes. 2019 May 31;17(1):94. doi: 10.1186/s12955-019-1155-4. PMID: 31151398. Exclusion Code: X2.31151398
329 Sloot R, Shanaube K, Claassens M, Interpretation of serial interferon-gamma test results to measure new tuberculosis infection among household contacts in Zambia and South Africa. BMC Infect Dis. 2020 Oct 15;20(1):760. doi: 10.1186/s12879-020-05483-9. PMID: 33059620. Exclusion Code: X2.33059620
330 Smadhi H, Ben Saad S, Daghfous H, Allergy to anti-tuberculosis treatment: Place of reintroduction drug test. Tunis Med. 2019 Mar;97(3):484–90. PMID: 31729724. Exclusion Code: X7.31729724
331 Smit DP, Esterhuizen TM, Meyer D. The role of QuantiFERON(^®^)-TB Gold and tuberculin skin test as diagnostic tests for intraocular tuberculosis in HIV-positive and HIV-negative patients in South Africa. Ocul Immunol Inflamm. 2018;26(6):853–8. doi: 10.1080/09273948.2017.1327078. PMID: 28628340. Exclusion Code: X2.28628340
332 So H, Yuen CS, Yip RM. Comparison of a commercial interferon-gamma release assay and tuberculin skin test for the detection of latent tuberculosis infection in Hong Kong arthritis patients who are candidates for biologic agents. Hong Kong Med J. 2017 Jun;23(3):246–50. doi: 10.12809/hkmj164880. PMID: 28126971. Exclusion Code: X2.28126971
333 Song YJ, Cho SK, Kim H, Risk of Tuberculosis Development in Patients with Rheumatoid Arthritis Receiving Targeted Therapy: a Prospective Single Center Cohort Study. J Korean Med Sci. 2021 Mar 15;36(10):e70. doi: 10.3346/jkms.2021.36.e70. PMID: 33724737. Exclusion Code: X3.33724737
334 Spruijt I, Erkens C, Suurmond J, Implementation of latent tuberculosis infection screening and treatment among newly arriving immigrants in the Netherlands: A mixed methods pilot evaluation. PLoS One. 2019;14(7):e0219252. doi: 10.1371/journal.pone.0219252. PMID: 31260502. Exclusion Code: X5.31260502
335 Stagg HR, Hatherell HA, Lipman MC, Treatment regimens for rifampicin-resistant tuberculosis: highlighting a research gap. Int J Tuberc Lung Dis. 2016 Jul;20(7):866–9. doi: 10.5588/ijtld.16.0034. PMID: 27287636. Exclusion Code: X6.27287636
336 Steffen RE, Pinto M, Kritski A, Cost-effectiveness of newer technologies for the diagnosis of Mycobacterium tuberculosis infection in Brazilian people living with HIV. Sci Rep. 2020 Dec 11;10(1):21823. doi: 10.1038/s41598-020-78737-w. PMID: 33311520. Exclusion Code: X2.33311520
337 Stennis NL, Burzynski JN, Herbert C, Treatment for tuberculosis infection with 3 months of isoniazid and rifapentine in New York City health department clinics. Clin Infect Dis. 2016 Jan 1;62(1):53–9. doi: 10.1093/cid/civ766. PMID: 26338781. Exclusion Code: X4.26338781
338 Stout JE, Wu Y, Ho CS, Evaluating latent tuberculosis infection diagnostics using latent class analysis. Thorax. 2018 Nov;73(11):1062–70. doi: 10.1136/thoraxjnl-2018-211715. PMID: 29982223. Exclusion Code: X2.29982223
339 Suliman S, Geldenhuys H, Johnson JL, Bacillus Calmette-Guérin (BCG) revaccination of adults with latent mycobacterium tuberculosis infection induces long-lived BCG-Reactive NK cell responses. J Immunol. 2016 Aug 15;197(4):1100–10. doi: 10.4049/jimmunol.1501996. PMID: 27412415. Exclusion Code: X5.27412415
340 Suvichapanich S, Fukunaga K, Zahroh H, NAT2 ultra-slow acetylator and risk of anti-tuberculosis drug-induced liver injury: a genotype-based meta-analysis. Pharmacogenet Genomics. 2018 Jul;28(7):167–76. doi: 10.1097/fpc.0000000000000339. PMID: 29781872. Exclusion Code: X5.29781872
341 Szturmowicz M, Broniarek-Samson B, Demkow U. Prevalence and risk factors for latent tuberculosis in polish healthcare workers: the comparison of tuberculin skin test and interferon-gamma release assay (IGRA) performance. J Occup Med Toxicol. 2021 Sep 1;16(1):38. doi: 10.1186/s12995-021-00326-y. PMID: 34470622. Exclusion Code: X2.34470622
342 Tal R, Lawal T, Granger E, Genital tuberculosis screening at an academic fertility center in the United States. Am J Obstet Gynecol. 2020 Nov;223(5):737.e1-.e10. doi: 10.1016/j.ajog.2020.05.045. PMID: 32497612. Exclusion Code: X2.32497612
343 Tamašauskienė L, Hansted E, Vitkauskienė A, Use of interferon-gamma release assay and tuberculin skin test in diagnosing tuberculosis in Lithuanian adults: A comparative analysis. Medicina (Kaunas). 2017;53(3):159–65. doi: 10.1016/j.medici.2017.05.003. PMID: 28712669. Exclusion Code: X7.28712669
344 Tan Y, Tan Y, Li J, Combined IFN-γ and IL-2 release assay for detect active pulmonary tuberculosis: a prospective multicentre diagnostic study in China. J Transl Med. 2021 Jul 3;19(1):289. doi: 10.1186/s12967-021-02970-8. PMID: 34217302. Exclusion Code: X3.34217302
345 Tang J, Huang Y, Cai Z, Mycobacterial heparin-binding hemagglutinin (HBHA)-induced interferon-γ release assay (IGRA) for discrimination of latent and active tuberculosis: A systematic review and meta-analysis. PLoS One. 2021;16(7):e0254571. doi: 10.1371/journal.pone.0254571. PMID: 34270559. Exclusion Code: X3.34270559
346 Tang J, Huang Y, Jiang S, QuantiFERON-TB Gold Plus combined with HBHA-Induced IFN-γ release assay improves the accuracy of identifying tuberculosis disease status. Tuberculosis (Edinb). 2020 Sep;124:101966. doi: 10.1016/j.tube.2020.101966. PMID: 32866942. Exclusion Code: X9.32866942
347 Taxonera C, Ponferrada Á, Bermejo F, Early tuberculin skin test for the diagnosis of latent tuberculosis infection in patients with inflammatory bowel disease. J Crohns Colitis. 2017 Jul 1;11(7):792–800. doi: 10.1093/ecco-jcc/jjx022. PMID: 28333182. Exclusion Code: X2.28333182
348 Telisinghe L, Amofa-Sekyi M, Maluzi K, The sensitivity of the QuantiFERON(^®^)-TB Gold Plus assay in Zambian adults with active tuberculosis. Int J Tuberc Lung Dis. 2017 Jun 1;21(6):690–6. doi: 10.5588/ijtld.16.0764. PMID: 28482964. Exclusion Code: X2.28482964
349 Teranishi S, Kobayashi N, Aoki A, Reproducibility of the T-SPOT.TB test for screening Mycobacterium tuberculosis infection in Japan. J Infect Chemother. 2020 Feb;26(2):194–8. doi: 10.1016/j.jiac.2019.08.006. PMID: 31495568. Exclusion Code: X5.31495568
350 Thanassi W, Noda A, Hernandez B, Negative tuberculin skin test and prediction of reversion of QuantiFERON interferon gamma release assay in US healthcare workers. Infect Control Hosp Epidemiol. 2016 Apr;37(4):478–82. doi: 10.1017/ice.2015.324. PMID: 26818401. Exclusion Code: X2.26818401
351 Theel ES, Hilgart H, Breen-Lyles M, Comparison of the QuantiFERON-TB Gold Plus and QuantiFERON-TB Gold In-Tube interferon gamma release assays in patients at risk for tuberculosis and in health care workers. J Clin Microbiol. 2018 Jul;56(7)doi: 10.1128/jcm.00614-18. PMID: 29743310. Exclusion Code: X4.29743310
352 Toujani S, Cherif J, Mjid M, Evaluation of tuberculin skin test positivity and early tuberculin conversion among medical intern trainees in Tunisia. Tanaffos. 2017;16(2):149–56. PMID: 29308080. Exclusion Code: X2.29308080
353 Tsang DN, Lai CK, Yam WC, Use of interferon gamma release assay to assess latent tuberculosis infection among healthcare workers in Hong Kong. Hong Kong Med J. 2015 Dec;21 Suppl 7:S22–5. PMID: 26908269. Exclusion Code: X2.26908269
354 Tseng SY, Huang YS, Chang TE, Hepatotoxicity, efficacy and completion rate between 3 months of isoniazid plus rifapentine and 9 months of isoniazid in treating latent tuberculosis infection: A systematic review and meta-analysis. J Chin Med Assoc. 2021 Nov 1;84(11):993–1000. doi: 10.1097/jcma.0000000000000605. PMID: 34747900. Exclusion Code: X9.34747900
355 Tsou PH, Huang WC, Huang CC, Quantiferon TB-Gold conversion can predict active tuberculosis development in elderly nursing home residents. Geriatr Gerontol Int. 2015 Oct;15(10):1179–84. doi: 10.1111/ggi.12416. PMID: 25495670. Exclusion Code: X2.25495670
356 Tsuyuzaki M, Igari H, Okada N, Variation in interferon-γ production between QFT-Plus and QFT-GIT assays in TB contact investigation. Respir Investig. 2019 Nov;57(6):561–5. doi: 10.1016/j.resinv.2019.07.002. PMID: 31402331. Exclusion Code: X2.31402331
357 Turnbull L, Bell C, Child F. Tuberculosis (NICE clinical guideline 33). Arch Dis Child Educ Pract Ed. 2017 Jun;102(3):136–42. doi: 10.1136/archdischild-2016-310870. PMID: 27974357. Exclusion Code: X1.27974357
358 Turtle L, Kemp T, Davies GR, In routine UK hospital practice T-SPOT.TB is useful in some patients with a modest pretest probability of active tuberculosis. Eur J Intern Med. 2012 Jun;23(4):363–7. doi: 10.1016/j.ejim.2012.01.002. PMID: 22560387. Exclusion Code: X9.22560387
359 Tweed CD, Crook AM, Amukoye EI, Toxicity associated with tuberculosis chemotherapy in the REMoxTB study. BMC Infect Dis. 2018 Jul 11;18(1):317. doi: 10.1186/s12879-018-3230-6. PMID: 29996783. Exclusion Code: X2.29996783
360 Tweed CD, Crook AM, Dawson R, Toxicity related to standard TB therapy for pulmonary tuberculosis and treatment outcomes in the REMoxTB study according to HIV status. BMC Pulm Med. 2019 Aug 14;19(1):152. doi: 10.1186/s12890-019-0907-6. PMID: 31412895. Exclusion Code: X2.31412895
361 Uden L, Barber E, Ford N, Risk of tuberculosis infection and disease for health care workers: an updated meta-analysis. Open Forum Infect Dis. 2017 Summer;4(3):ofx137. doi: 10.1093/ofid/ofx137. PMID: 28875155. Exclusion Code: X2.28875155
362 Uzorka JW, Bossink AWJ, Franken WPJ, Borderline QuantiFERON results and the distinction between specific responses and test variability. Tuberculosis (Edinb). 2018 Jul;111:102–8. doi: 10.1016/j.tube.2018.06.002. PMID: 30029893. Exclusion Code: X4.30029893
363 Uzorka JW, Duinkerk DL, Kroft LJ M, Trends in diagnostic methods and treatment of latent tuberculosis infection in a tertiary care center from 2000 to 2017. Eur J Clin Microbiol Infect Dis. 2020 Jul;39(7):1329–37. doi: 10.1007/s10096-020-03850-7. PMID: 32076881. Exclusion Code: X2.32076881
364 van Griensven J, Choun K, Chim B, Implementation of isoniazid preventive therapy in an HIV clinic in Cambodia: high rates of discontinuation when combined with antiretroviral therapy. Trop Med Int Health. 2015 Dec;20(12):1823–31. doi: 10.1111/tmi.12609. PMID: 26426387. Exclusion Code: X4.26426387
365 Veening GJ. Long term isoniazid prophylaxis. Controlled trial on INH prophylaxis after recent tuberculin conversion in young adults. Bull Int Union Tuberc. 1968 Dec;41:169–71. PMID: 4885378. Exclusion Code: X3.4885378
366 Velásquez GE, Brooks MB, Coit JM, Efficacy and safety of high-dose rifampin in pulmonary tuberculosis. A randomized controlled trial. Am J Respir Crit Care Med. 2018 Sep 1;198(5):657–66. doi: 10.1164/rccm.201712-2524OC. PMID: 29954183. Exclusion Code: X3.29954183
367 Venkatappa TK, Punnoose R, Katz DJ, Comparing QuantiFERON-TB Gold Plus with other tests to diagnose mycobacterium tuberculosis infection. J Clin Microbiol. 2019 Nov;57(11)doi: 10.1128/jcm.00985-19. PMID: 31462550. Exclusion Code: X2.31462550
368 Verbeeck RK, Singu BS, Kibuule D. Clinical significance of the plasma protein binding of rifampicin in the treatment of tuberculosis patients. Clin Pharmacokinet. 2019 Dec;58(12):1511–5. doi: 10.1007/s40262-019-00800-1. PMID: 31332668. Exclusion Code: X1.31332668
369 Verso MG, Serra N, Ciccarello A, Latent tuberculosis infection among healthcare students and postgraduates in a Mediterranean Italian area: what correlation with work exposure? Int J Environ Res Public Health. 2019 Dec 24;17(1)doi: 10.3390/ijerph17010137. PMID: 31878124. Exclusion Code: X2.31878124
370 Walles J, Tesfaye F, Jansson M, Tuberculosis Infection in Women of Reproductive Age: A Cross-sectional Study at Antenatal Care Clinics in an Ethiopian City. Clin Infect Dis. 2021 Jul 15;73(2):203–10. doi: 10.1093/cid/ciaa561. PMID: 32412638. Exclusion Code: X2.32412638
371 Walsh KF, Vilbrun SC, Souroutzidis A, Improved outcomes with high-dose isoniazid in multidrug-resistant tuberculosis treatment in Haiti. Clin Infect Dis. 2019 Aug 1;69(4):717–9. doi: 10.1093/cid/ciz039. PMID: 30698688. Exclusion Code: X2.30698688
372 Walt MV, Masuku S, Botha S, Retrospective record review of pregnant women treated for rifampicin-resistant tuberculosis in South Africa. PLoS One. 2020;15(9):e0239018. doi: 10.1371/journal.pone.0239018. PMID: 32970722. Exclusion Code: X2.32970722
373 Wang F, Hou HY, Wu SJ, Using the TBAg/PHA ratio in the T-SPOT(^®^).TB assay to distinguish TB disease from LTBI in an endemic area. Int J Tuberc Lung Dis. 2016 Apr;20(4):487–93. doi: 10.5588/ijtld.15.0756. PMID: 26970158. Exclusion Code: X4.26970158
374 Wang F, Yu J, Zhou Y, The use of TB-specific antigen/phytohemagglutinin ratio for diagnosis and treatment monitoring of extrapulmonary tuberculosis. Front Immunol. 2018;9:1047. doi: 10.3389/fimmu.2018.01047. PMID: 29868010. Exclusion Code: X2.29868010
375 Wang L, Yu Y, Chen W, Evaluation of the characteristics of the enzyme-linked immunospot assay for diagnosis of active tuberculosis in China. Clin Vaccine Immunol. 2015 May;22(5):510–5. doi: 10.1128/cvi.00023-15. PMID: 25739918. Exclusion Code: X9.25739918
376 Wang Y, Xiang X, Wu SQ, Association of CYP2B6 gene polymorphisms and anti-tuberculosis drug-induced hepatotoxicity in a Chinese population. Infect Genet Evol. 2017 Jul;51:198–202. doi: 10.1016/j.meegid.2017.04.001. PMID: 28389387. Exclusion Code: X5.28389387
377 Warria K, Nyamthimba P, Chweya A, Tuberculosis disease and infection among household contacts of bacteriologically confirmed and non-confirmed tuberculosis patients. Trop Med Int Health. 2020 Jun;25(6):695–701. doi: 10.1111/tmi.13392. PMID: 32170771. Exclusion Code: X9.32170771
378 Warrington P, Tyrrell G, Choy K, Prevalence of latent tuberculosis infection in Syrian refugees to Canada. Can J Public Health. 2018 Feb;109(1):8–14. doi: 10.17269/s41997-018-0028-7. PMID: 29981073. Exclusion Code: X4.29981073
379 Wawrocki S, Seweryn M, Kielnierowski G, IL-18/IL-37/IP-10 signalling complex as a potential biomarker for discriminating active and latent TB. PLoS One. 2019;14(12):e0225556. doi: 10.1371/journal.pone.0225556. PMID: 31821340. Exclusion Code: X9.31821340
380 Wheeler C, Mohle-Boetani J. Completion rates, adverse effects, and costs of a 3-month and 9-month treatment regimen for latent tuberculosis infection in California inmates, 2011-2014. Public Health Rep. 2019 May/Jun; 134(1_suppl):71s–9s. doi: 10.1177/0033354919826557. PMID: 31059418. Exclusion Code: X6.31059418
381 Wikell A, Jonsson J, Dyrdak R, The Impact of Borderline Quantiferon-TB Gold Plus Results for Latent Tuberculosis Screening under Routine Conditions in a Low-Endemicity Setting. J Clin Microbiol. 2021 Nov 18;59(12):e0137021. doi: 10.1128/jcm.01370-21. PMID: 34550805. Exclusion Code: X2.34550805
382 Wilson FA, Miller TL, Stimpson JP. Mycobacterium tuberculosis infection, immigration status, and diagnostic discordance: a comparison of tuberculin skin test and QuantiFERON-TB Gold In-Tube test among immigrants to the U.S. Public Health Rep. 2016 Mar-Apr;131(2):303–10. doi: 10.1177/003335491613100214. PMID: 26957665. Exclusion Code: X4.26957665
383 Won D, Park JY, Kim HS, Comparative results of QuantiFERON-TB Gold In-Tube and QuantiFERON-TB Gold Plus assays for detection of tuberculosis infection in clinical samples. J Clin Microbiol. 2020 Mar 25;58(4)doi: 10.1128/jcm.01854-19. PMID: 31969422. Exclusion Code: X4.31969422
384 Wondale B, Medihn G, Teklu T, A retrospective study on tuberculosis treatment outcomes at Jinka General Hospital, southern Ethiopia. BMC Res Notes. 2017 Dec 4;10(1):680. doi: 10.1186/s13104-017-3020-z. PMID: 29202880. Exclusion Code: X6.29202880
385 Wu F, Wang L, Guo Q, A homogeneous immunoassay method for detecting interferon-gamma in patients with latent tuberculosis infection. J Microbiol Biotechnol. 2016 Mar;26(3):588–95. doi: 10.4014/jmb.1507.07102. PMID: 26628252. Exclusion Code: X3.26628252
386 Wu J, Bai J, Wang W, ATB discrimination: an in silico tool for identification of active tuberculosis disease based on routine blood test and T-SPOT.TB detection results. J Chem Inf Model. 2019 Nov 25;59(11):4561–8. doi: 10.1021/acs.jcim.9b00678. PMID: 31609612. Exclusion Code: X2.31609612
387 Wu X, Chen P, Wei W, Diagnostic value of the interferon-γ release assay for tuberculosis infection in patients with Behçeťs disease. BMC Infect Dis. 2019 Apr 15;19(1):323. doi: 10.1186/s12879-019-3954-y. PMID: 30987605. Exclusion Code: X2.30987605
388 Wyndham-Thomas C, Dirix V, Schepers K, Contribution of a heparin-binding haemagglutinin interferon-gamma release assay to the detection of Mycobacterium tuberculosis infection in HIV-infected patients: comparison with the tuberculin skin test and the QuantiFERON-TB Gold In-tube. BMC Infect Dis. 2015 Feb 14;15:59. doi: 10.1186/s12879-015-0796-0. PMID: 25886172. Exclusion Code: X2.25886172
389 Xin H, Cao X, Zhang H, Dynamic changes of interferon gamma release assay results with latent tuberculosis infection treatment. Clin Microbiol Infect. 2020doi: 10.1016/j.cmi.2020.02.009. PMID: CN-02102348. Exclusion Code: X3.
390 Xu HY, Li CY, Su SS, Diagnosis of tuberculous pleurisy with combination of adenosine deaminase and interferon-γ immunospot assay in a tuberculosis-endemic population: a prospective cohort study. Medicine (Baltimore). 2017 Nov;96(47):e8412. doi: 10.1097/md.0000000000008412. PMID: 29381918. Exclusion Code: X2.29381918
391 Yamaguchi F, Yoda H, Hiraiwa M, Impact of the interferon-γ release assay and glomerular filtration rate on the estimation of active tuberculosis risk before bronchoscopic examinations: a retrospective pilot study. J Thorac Dis. 2020 Oct;12(10):5842–9. doi: 10.21037/jtd-19-3653. PMID: 33209416. Exclusion Code: X2.33209416
392 Yan L, Kan X, Zhu L, Short-course regimen for subsequent treatment of pulmonary tuberculosis: a prospective, randomized, controlled multicenter clinical trial in China. Clin Ther. 2018 Mar;40(3):440–9. doi: 10.1016/j.clinthera.2018.01.013. PMID: 29519716. Exclusion Code: X2.29519716
393 Yang Q, Ruan Q, Liu X, Preventive tuberculosis treatment effect on QuantiFERON TB-Gold in-tube testing in a high tuberculosis-endemic country: A clinical trial. Int J Infect Dis. 2020 Feb;91:182–7. doi: 10.1016/j.ijid.2019.11.023. PMID: 31770617. Exclusion Code: X2.31770617
394 Yang Q, Xu Q, Chen Q, Discriminating active tuberculosis from latent tuberculosis infection by flow cytometric measurement of CD161-expressing T cells. Sci Rep. 2015 Dec 8;5:17918. doi: 10.1038/srep17918. PMID: 26643453. Exclusion Code: X3.26643453
395 Yang Q, Zhang C, Ruan Q, Higher T-SPOT.TB threshold may aid in diagnosing active tuberculosis?: A real-world clinical practice in a general hospital. Clin Chim Acta. 2020 Oct;509:60–6. doi: 10.1016/j.cca.2020.06.005. PMID: 32505775. Exclusion Code: X6.32505775
396 Yap P, Tan KHX, Lim WY, Prevalence of and risk factors associated with latent tuberculosis in Singapore: A cross-sectional survey. Int J Infect Dis. 2018 Jul;72:55–62. doi: 10.1016/j.ijid.2018.05.004. PMID: 29758278. Exclusion Code: X2.29758278
397 Yoo JW, Jo KW, Park GY, Comparison of latent tuberculosis infection rate between contacts with active tuberculosis and non-contacts. Respir Med. 2016 Feb;111:77–83. doi: 10.1016/j.rmed.2015.12.002. PMID: 26725461. Exclusion Code: X2.26725461
398 Yoon CG, Oh SY, Lee JB, Occupational risk of latent tuberculosis infection in health workers of 14 military hospitals. J Korean Med Sci. 2017 Aug;32(8):1251–7. doi: 10.3346/jkms.2017.32.8.1251. PMID: 28665059. Exclusion Code: X2.28665059
399 Yoshiyama T, Harada N, Higuchi K, Use of the QuantiFERON^®^-TB Gold in Tube test for screening TB contacts and predictive value for active TB. Infect Dis (Lond). 2015 Aug;47(8):542–9. doi: 10.3109/23744235.2015.1026935. PMID: 25901728. Exclusion Code: X2.25901728
400 Yu SN, Jung J, Kim YK, Diagnostic usefulness of IFN-gamma releasing assays compared with conventional tests in patients with disseminated tuberculosis. Medicine (Baltimore). 2015 Jul;94(28):e1094. doi: 10.1097/md.0000000000001094. PMID: 26181542. Exclusion Code: X2.26181542
401 Yu YY, Tsao SM, Yang WT, Association of drag metabolic enzyme genetic polymorphisms and adverse drag reactions in patients receiving rifapentine and isoniazid therapy for latent tuberculosis. Int J Environ Res Public Health. 2019 Dec 27;17(1)doi: 10.3390/ijerph17010210. PMID: 31892222. Exclusion Code: X5.31892222
402 Yuen CM, Majidulla A, Jaswal M, Cost of Delivering 12-Dose Isoniazid and Rifapentine Versus 6 Months of Isoniazid for Tuberculosis Infection in a High-Burden Setting. Clin Infect Dis. 2021 Sep 7;73(5):e1135–e41. doi: 10.1093/cid/ciaa1835. PMID: 33289039. Exclusion Code: X6.33289039
403 Yuen CM, Millones AK, Contreras CC, Tuberculosis household accompaniment to improve the contact management cascade: A prospective cohort study. PLoS One. 2019;14(5):e0217104. doi: 10.1371/journal.pone.0217104. PMID: 31100097. Exclusion Code: X2.31100097
404 Zellweger JP, Sotgiu G, Block M, Risk assessment of tuberculosis in contacts by IFN-γ release assays. A Tuberculosis Network European Trials Group Study. Am J Respir Crit Care Med. 2015 May 15;191(10):1176–84. doi: 10.1164/rccm.201502-02320C. PMID: 25763458. Exclusion Code: X5.25763458
405 Zelner J, Murray M, Becerra M, Protective effects of household-based TB interventions are robust to neighbourhood-level variation in exposure risk in Lima, Peru: a model-based analysis. Int J Epidemiol. 2018 Feb 1;47(1):185–92. doi: 10.1093/ije/dyx171. PMID: 29025111. Exclusion Code: X6.29025111
406 Zenner D, Loutet MG, Harris R, Evaluating 17 years of latent tuberculosis infection screening in north-west England: a retrospective cohort study of reactivation. Eur Respir J. 2017 Jul;50(1)doi: 10.1183/13993003.02505-2016. PMID: 28751410. Exclusion Code: X6.28751410
407 Zhang H, Wang L, Li F, Induration or erythema diameter not less than 5 mm as results of recombinant fusion protein ESAT6-CFP10 skin test for detecting M. tuberculosis infection. BMC Infect Dis. 2020 Sep 18;20(1):685. doi: 10.1186/s12879-020-05413-9. PMID: 32948127. Exclusion Code: X3.32948127
408 Zhang H, Xin H, Wang D, Serial testing of Mycobacterium tuberculosis infection in Chinese village doctors by QuantiFERON-TB Gold Plus, QuantiFERON-TB Gold in-Tube and T-SPOT.TB. J Infect. 2019 Apr;78(4):305–10. doi: 10.1016/j.jinf.2019.01.008. PMID: 30710557. Exclusion Code: X2.30710557
409 Zhang HC, Ruan QL, Wu J, Serial T-SPOT.TB in household contacts of tuberculosis patients: a 6-year observational study in China. Int J Tuberc Lung Dis. 2019 Sep 1;23(9):989–95. doi: 10.5588/ijtld.18.0252. PMID: 31615605. Exclusion Code: X2.31615605
410 Zhang L, Wan S, Ye S, Application of IFN-γ/IL-2 FluoroSpot assay for distinguishing active tuberculosis from non-active tuberculosis: A cohort study. Clin Chim Acta. 2019 Dec;499:64–9. doi: 10.1016/j.cca.2019.08.022. PMID: 31454491. Exclusion Code: X3.31454491
411 Zhang Q, Zhang Q, Sun BQ, GeneXpert MTB/RIF for rapid diagnosis and rifampin resistance detection of endobronchial tuberculosis. Respirology. 2018 Oct;23(10):950–5. doi: 10.1111/resp.13316. PMID: 29691960. Exclusion Code: X3.29691960
412 Zhang R, Tian P, Zhao S, Development and validation of novel diagnostic nomogram for tuberculous pleurisy based on TB-IGRA results. Int J Tuberc Lung Dis. 2020 Nov 1;24(11):1178–85. doi: 10.5588/ijtld.20.0001. PMID: 33172526. Exclusion Code: X3.33172526
413 Zhou G, Luo Q, Luo S, Interferon-γ release assays or tuberculin skin test for detection and management of latent tuberculosis infection: a systematic review and meta-analysis. Lancet Infect Dis. 2020 Dec;20(12):1457–69. doi: 10.1016/s1473-3099(20)30276-0. PMID: 32673595. Exclusion Code: X5.32673595