# Appendix B Additional Methods Information

## Appendix B1 Original Literature Search Strategies

### PubMed 2/24/2021

Screening=844; 844 imported

Interventions=1,462; 1,339 imported

Diagnostic Accuracy of Tests=1,265; 450 imported

Search Number | Query | Filters | Results
1 | “Tuberculosis”[Mesh] OR “Latent Tuberculosis”[Mesh] OR “Mycobacterium tuberculosis”[Mesh] OR “latent tuberculosis”[tiab] OR “latent TB” OR LTBI[tiab] OR Mtb[tiab] | | 219,039
2 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case control”[tw] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR (“Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | | 10,876,893
3 | #1 NOT #2 | | 158,401
4 | Adult[MeSH] OR Adult*[tw] OR “middle age”[tw] OR “middle aged”[tw] | | 8,063,660
5 | #3 AND #4 | | 45,456
6 | “Adolescent”[Mesh] OR adolescen*[tw] OR boys[tw] OR “Child”[Mesh] OR child[tw] OR children*[tw] OR childhood[tw] OR girls[tw] OR pediatric*[tw] OR paediatric*[tw] OR teen[tw] OR teens[tw] OR teenage*[tw] OR youth[tw] OR youths[tw] | | 3,679,569
7 | #3 NOT#6 | | 129,161
8 | #5 OR #7 | | 142,915
9 | #5 OR #7 | English | 73,785
10 | “Systematic Review”[pt] OR (“review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR (“review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “Systematic Reviews as Topic”[Mesh] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “Umbrella Review”[tiab] | | 361,409
11 | #9 AND #10 | | 1,062
12 | “randomized controlled trial”[pt] OR “controlled clinical trial”[pt] OR randomized [tiab] OR placebo[tiab] OR “drug therapy”[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab] | | 4,993,768
13 | #9 AND #12 | | 19,697
14 | “Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Cross-Sectional Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Seroepidemiologic Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “observational study” OR “observational studies” | | 2,697,181
15 | #9 AND #14 | | 12,854
16 | “Interferon-gamma Release Tests”[Mesh] OR “Tuberculin Test”[Mesh] OR IGRA OR Mantoux* OR QFT OR “QFT Gold In Tube” OR “QFT-Gold In Tube” OR “QFT-GIT” OR “QFT-Plus” OR QuantiFERON* OR “tuberculin skin test”[tiab] OR TST[tiab] OR “T-SPOT” OR “T-SPOT.TB” | | 22,327
17 | #16 AND #11 | | 134
18 | #16 AND #13 | | 1,749
19 | #16 AND #15 | | 1,746
20 | #17 OR #18 OR #19 | | 2,968
21 | #20 AND (“2015/01/30”[Date - Publication] : “3000”[Date - Publication]) | | 844
22 | “Isoniazid”[Mesh] OR INH OR isoniazid OR “Rifampin”[Mesh] OR Rifampin OR “rifapentine”[Supplementary Concept] OR rifapentine OR rifampicin | | 50,536
23 | #22 AND #11 | | 173
24 | #22 AND #13 | | 5,047
25 | #22 AND #15 | | 1,851
26 | #23 OR #24 OR #25 | | 5,533
27 | #26 AND (“2015/01/30”[Date - Publication] : “3000”[Date - Publication]) | | 1,462
28 | “Clinical Laboratory Techniques”[MeSH] OR “Comparative Study” [Publication Type] OR “Diagnostic Test Approval”[MeSH] OR “Diagnostic Tests, Routine”[MeSH] OR “False Negative Reactions”[MeSH] OR “False Positive Reactions”[MeSH] OR “Mass Screening”[MeSH] OR “Predictive Value of Tests”[Mesh] OR “Reproducibility of Results”[Mesh] OR “Risk Assessment”[MeSH] OR “ROC Curve”[Mesh] OR “Sensitivity and Specificity”[Mesh] OR accuracy[tw] OR “false negative”[tw] OR “false positive”[tw] OR “likelihood ratio”[tw] OR “predictive value”[tw] OR reproducib*[tw] OR ROC[tw] OR screen*[tiab] OR sensitivity[tw] OR specificity[tw] OR test*[tiab] | | 8,915,578
29 | #9 AND #28 | | 31,163
30 | #29 AND #16 | | 5,831
31 | #30 AND (“2015/01/30”[Date - Publication] : “3000”[Date - Publication]) | | 1,265

### Cochrane Library, 2/24/2021

Screening=108; 93 imported

Interventions=301; 203 imported (300 saved, 1 was from Special Collections tab and not saved)

Diagnostic Accuracy of Tests=118; 20 imported

#1 [mh ”Tuberculosis”] OR [mh ”Latent Tuberculosis”] OR [mh ”Mycobacterium tuberculosis”] OR “latent tuberculosis”:ti,ab OR “latent TB” OR LTBI:ti,ab OR Mtb:ti,ab 2598

#2 address:pt OR “autobiography”:pt OR “bibliography”:pt OR “biography”:pt OR “case control” OR “case report” OR “case reports” OR “case series” OR “comment”:pt OR “comment on” OR congress:pt OR “dictionary”:pt OR “directory”:pt OR “editorial”:pt OR “festschrift”:pt OR “historical article”:pt OR “interview”:pt OR lecture:pt OR “legal case”:pt OR “legislation”:pt OR letter:pt OR “news”:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR ([mh ”Animals”] NOT [mh ”Humans”]) OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae 64489

#3 #1 NOT #2 2440

#4 [mh Adult] OR Adult*:ti,ab,kw OR “middle age”:ti,ab,kw OR “middle aged”:ti,ab,kw 775799

#5 #3 AND #4 1567

#6 [mh adolescent] OR adolescen*:ti,ab,kw OR boys:ti,ab,kw OR [mh child] OR child:ti,ab,kw OR children:ti,ab,kw OR girls:ti,ab,kw OR [mh infant] OR infant*:ti,ab,kw OR pediatric*:ti,ab,kw OR paediatric*:ti,ab,kw OR teen:ti,ab,kw OR teens:ti,ab,kw OR teenage*:ti,ab,kw OR youth:ti,ab,kw OR youths:ti,ab,kw 277813

#7 #3 NOT #6 1601

#8 #5 OR #7 2198

#9 #8 with Cochrane Library publication date from Jan 2015 to Feb 2021 1039

#10 [mh ^”clinical trials as topic”] OR (controlled:ti,ab AND trial:ti,ab) OR “controlled clinical trial”:pt OR [mh ”drug therapy”] OR “randomized controlled trial”:pt OR “randomized controlled trial as topic”:pt OR “single-blind method”:pt OR “double-blind method”:pt OR “random allocation”:pt OR placebo:ti,ab OR randomized:ti,ab OR randomly:ti,ab OR trial:ti 1244856

#11 #9 AND #10 819

#12 [mh ”Cohort Studies”] OR [mh ”Epidemiologic Studies”] OR [mh ” Follow-Up Studies”] OR [mh ”Seroepidemiologic Studies”] OR “Evaluation Studies”:pt OR [mh ”Program Evaluation”] OR “observational study” OR “observational studies” 172800

#13 #9 AND #12 131

#14 [mh ”Interferon-gamma Release Tests”] OR [mh ”Tuberculin Test”] OR IGRA OR Mantoux* OR QFT* OR “QFT Gold In Tube” OR “QFT-Gold In Tube” OR “QFT-GIT” OR “QFT-Plus” OR QuantiFERON OR “QuantiFERON-Plus” OR “QuantiFERON-TB Gold Plus” OR “tuberculin skin test”:ti,ab OR TST:ti,ab OR “T-SPOT” OR “T-SPOT.TB” 1520

#15 #14 AND #11 106

#16 #14 AND #13 18

#17 #15 OR #16 108

#18 [mh ”Isoniazid”] OR INH OR isoniazid OR [mh ”Rifampin”] OR Rifampin OR rifapentine OR rifampicin 3695

#19 #18 AND #11 299

#20 #18 AND #13 43

#21 #19 OR #20 301

#22 [mh ”Clinical Laboratory Techniques”] OR “Comparative Study”:pt OR [mh ” Diagnostic Test Approval”] OR [mh ”Diagnostic Tests, Routine”] OR [mh ”False Negative Reactions”] OR [mh ”False Positive Reactions”] OR [mh ”Mass Screening”] OR [mh ”Predictive Value of Tests”] OR [mh ”Risk Assessment”] OR [mh ”ROC Curve”] OR [mh ”Reproducibility of Results”] OR [mh ”Sensitivity and Specificity”] OR accuracy:ti,ab,kw OR “false negative”:ti,ab,kw OR “false positive”:ti,ab,kw OR “likelihood ratio”:ti,ab,kw OR “predictive value”:ti,ab,kw OR ROC:ti,ab,kw OR reproducib*:ti,ab,kw OR screen*:ti,ab OR sensitivity:ti,ab,kw OR specificity:ti,ab,kw OR test*:ti,ab 585814

#23 #9 AND #22 586

#24 #23 AND #14 118

### Grey Literature

#### ClinicalTrials.gov, 8/4/2020

Screening (38 studies)

Condition box:

(“Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “glucose tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance” OR “glucose intolerance” OR “Prediabetic State” OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus”)

AND

Other terms box:

(“blood glucose” OR OGTT OR “glucose tolerance test” OR “Glycated Hemoglobin A” OR “hemoglobin A1c” OR HbA1c OR “fasting plasma glucose” OR “HbA(1c)” OR HbA1 OR HbA1c OR “HbA 1c” OR “glycosylated hemoglobin” OR “glycated hemoglobin” OR “oral glucose tolerance”) AND (screen* OR screening)

Used child limits Age Group Child (birth-17)

Put together in Expert search:

(“blood glucose” OR OGTT OR “glucose tolerance test” OR “Glycated Hemoglobin A” OR “hemoglobin A1c” OR HbA1c OR “fasting plasma glucose” OR “HbA(1c)” OR HbA1 OR HbA1c OR “HbA 1c” OR “glycosylated hemoglobin” OR “glycated hemoglobin” OR “oral glucose tolerance”) AND (screen* OR screening) AND AREA[ConditionSearch] (“Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “glucose tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “Glucose Intolerance” OR “glucose intolerance” OR “Prediabetic State” OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus”) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] “Child”

38 studies, saved

#### Interventions

Pharmacological Interventions (123 studies):

Condition box:

(“Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “glucose tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “glucose Intolerance” OR “glucose intolerance” OR “Prediabetic State” OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus”)

AND

Intervention/treatment box:

Actos OR Albiglutide OR Amaryl OR Biguanides OR Bydureon OR Byetta OR DiaBeta OR “Dipeptidyl-Peptidase IV Inhibitors” OR “Dipeptidyl peptidase IV inhibitor” OR dulaglutide OR Exenatide OR Fortamet OR Gliclazide OR glimepiride OR Glipizide OR “GLP-1 receptor agonist” OR “GLP-1 receptor agonists” OR “Glucagon-like peptide-1 receptor agonist” OR “Glucagon-like peptide-1 receptor agonists” OR Glucophage OR Glucotrol OR Glumetza OR Glyburide OR “Glynase PresTab” OR Linagliptin OR Liraglutide OR lixisenatide OR Lyxumia OR Meglitinides OR Metformin OR Micronase OR Ozempic OR Pioglitazone OR Prandin OR Repaglinide OR Rosiglitazone OR Saxagliptin OR semaglutide OR Sitagliptin OR “Sulfonylurea Compounds” OR Starlix OR Sulfonylureas OR Tanzeum OR Thiazolidinediones OR Tolazamide OR Tolbutamide OR Trulicity OR TZDs OR Victoza OR vildagliptin

Used Child Limits Age Group Child (Birth–17)

In Expert search:

AREA[ConditionSearch] (“Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “glucose tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “glucose Intolerance” OR “glucose intolerance” OR “Prediabetic State” OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus”) AND AREA[InterventionSearch] (Actos OR Albiglutide OR Amaryl OR Biguanides OR Bydureon OR Byetta OR DiaBeta OR “Dipeptidyl-Peptidase IV Inhibitors” OR “Dipeptidyl peptidase IV inhibitor” OR dulaglutide OR Exenatide OR Fortamet OR Gliclazide OR glimepiride OR Glipizide OR “GLP-1 receptor agonist” OR “GLP-1 receptor agonists” OR “Glucagon-like peptide-1 receptor agonist” OR “Glucagon-like peptide-1 receptor agonists” OR Glucophage OR Glucotrol OR Glumetza OR Glyburide OR “Glynase PresTab” OR Linagliptin OR Liraglutide OR lixisenatide OR Lyxumia OR Meglitinides OR Metformin OR Micronase OR Ozempic OR Pioglitazone OR Prandin OR Repaglinide OR Rosiglitazone OR Saxagliptin OR semaglutide OR Sitagliptin OR “Sulfonylurea Compounds” OR Starlix OR Sulfonylureas OR Tanzeum OR Thiazolidinediones OR Tolazamide OR Tolbutamide OR Trulicity OR TZDs OR Victoza OR vildagliptin) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] “Child”

123 studies saved

Separate Search for Nonpharmacological Interventions (177 studies):

Condition box:

(“Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “glucose tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “glucose Intolerance” OR “glucose intolerance” OR “Prediabetic State” OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus”)

AND

Non-Pharmacological Interventions in Treatment/Interventions box:

(advice OR “Behavior Therapy” OR (behavior* AND therap*) OR (behavior* AND chang*) OR (behavior* AND modification*) OR “Caloric Restriction” OR ((child* AND parent*) and therap*) OR counsel* OR “cognitive behavior” OR “cognitive behavioral” OR “cognitive therap*” OR CBT OR “Diabetes Prevention Program” OR “Diabetes Prevention Programme” OR DPP OR (“Diabetes Prevention” AND (program* OR stud* OR trial*)) OR diet OR dietary OR Exercise OR “family intervention*” OR “family therap*” OR “Feedback, Psychological” OR “group therap*” OR “Health Behavior” OR “health behaviors” OR “health behavioral” OR “health behaviours” OR “health behaviour” OR “Health Education” OR “Health Education as Topic” OR “health education” OR “Health Promotion” OR “health promotion” OR “Life Style” OR lifestyle OR “life style” OR “Lifestyle Intervention” OR “Motivational Interviewing” OR “motivational interviewing” OR “non pharmacologic intervention” OR “nonpharmacologic intervention” OR “parent* intervention*” OR “patient education” OR “physical activity” OR “physically active” OR “psychological feedback” OR “Risk Reduction Behavior” OR “Risk Reduction Behavior” OR “Weight Loss” OR “Weight Reduction Programs”)

Used Child Limits Age Group Chilid (Birth-17)

In Expert Search:

AREA[ConditionSearch] (EXPAND[Concept] “Diabetes Mellitus, Type 2” OR EXPAND[Concept] “Glucose Tolerance” OR EXPAND[Concept] “glucose tolerance” OR EXPAND[Concept] “impaired glucose tolerance” OR IGT OR EXPAND[Concept] “impaired fasting glucose” OR IFG OR EXPAND[Concept] “glucose Intolerance” OR EXPAND[Concept] “glucose intolerance” OR EXPAND[Concept] “Prediabetic State” OR EXPAND[Concept] “prediabetic state” OR prediabet* OR EXPAND[Concept] “pre diabetes” OR EXPAND[Concept] “diabetes mellitus type 2” OR EXPAND[Concept] “type 2 diabetes mellitus”) AND AREA[InterventionSearch] (advice OR “Behavior Therapy” OR (behavior* AND therap*) OR (behavior* AND chang*) OR (behavior* AND modification*) OR “Caloric Restriction” OR ((child* AND parent*) and therap*) OR counsel* OR “cognitive behavior” OR “cognitive behavioral” OR “cognitive therap*” OR CBT OR “Diabetes Prevention Program” OR “Diabetes Prevention Programme” OR DPP OR (“Diabetes Prevention” AND (program* OR stud* OR trial*)) OR diet OR dietary OR Exercise OR “family intervention*” OR “family therap*” OR “Feedback, Psychological” OR “group therap*” OR “Health Behavior” OR “health behaviors” OR “health behavioral” OR “health behaviours” OR “health behaviour” OR “Health Education” OR “Health Education as Topic” OR “health education” OR “Health Promotion” OR “health promotion” OR “Life Style” OR lifestyle OR “life style” OR “Lifestyle Intervention” OR “Motivational Interviewing” OR “motivational interviewing” OR “non pharmacologic intervention” OR “nonpharmacologic intervention” OR “parent* intervention*” OR “patient education” OR “physical activity” OR “physically active” OR “psychological feedback” OR “Risk Reduction Behavior” OR “Risk Reduction Behavior” OR “Weight Loss” OR “Weight Reduction Programs”) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] “Child”

177 studies saved

#### ClinicalTrials.gov Addendum, 8/21/2020

211 studies, 138 imported, and 73 duplicates discarded

Condition box:

(“Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “glucose tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “glucose Intolerance” OR “glucose intolerance” OR “Prediabetic State” OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus” NOT (“type 1 diabetes” OR “diabetes mellitus type 1”))

AND

Intervention/treatment box:

- (“hypoglycemic agent*” OR insulin)
- Used child limits Age Group Child (birth-17)

In Expert search:

AREA[ConditionSearch] (“Diabetes Mellitus, Type 2” OR “Glucose Tolerance” OR “glucose tolerance” OR “impaired glucose tolerance” OR IGT OR “impaired fasting glucose” OR IFG OR “glucose Intolerance” OR “glucose intolerance” OR “Prediabetic State” OR “prediabetic state” OR prediabet* OR “pre diabetes” OR “diabetes mellitus type 2” OR “type 2 diabetes mellitus” NOT (“type 1 diabetes” OR “diabetes mellitus type 1”)) AND AREA[InterventionSearch] (EXPAND[Concept] “hypoglycemic agent*” OR insulin) AND AREA[StdAge] EXPAND[Term] COVER[FullMatch] “Child”

#### Update Searches

PubMed, 12/3/2021

Screening = 178; 178 imported

Interventions = 429; 403 imported

Diagnostic Accuracy of Tests = 279; 111 imported

Search number | Query | Filters | Results
1 | “Tuberculosis”[Mesh] OR “Latent Tuberculosis”[Mesh] OR “Mycobacterium tuberculosis”[Mesh] OR “latent tuberculosis”[tiab] OR “latent TB” OR LTBI[tiab] OR Mtb[tiab] | | 224,533
2 | address[pt] OR “autobiography”[pt] OR “bibliography”[pt] OR “biography”[pt] OR “case control”[tw] OR “case report”[tw] OR “case reports”[tw] OR “case series”[tw] OR “comment”[pt] OR “comment on”[All Fields] OR congress[pt] OR “dictionary”[pt] OR “directory”[pt] OR “editorial”[pt] OR “festschrift”[pt] OR “historical article”[pt] OR “interview”[pt] OR lecture[pt] OR “legal case”[pt] OR “legislation”[pt] OR letter[pt] OR “news”[pt] OR “newspaper article”[pt] OR “patient education handout”[pt] OR “periodical index”[pt] OR ("Animals”[Mesh] NOT “Humans”[Mesh]) OR rats[tw] OR cow[tw] OR cows[tw] OR chicken[tw] OR chickens[tw] OR horse[tw] OR horses[tw] OR mice[tw] OR mouse[tw] OR bovine[tw] OR sheep OR ovine OR murine OR murinae | | 11,221,120
3 | #1 NOT #2 | | 162,172
4 | Adult[MeSH] OR Adult*[tw] OR “middle age”[tw] OR “middle aged”[tw] | | 8,360,564
5 | #3 AND #4 | | 46,628
6 | “Adolescent”[Mesh] OR adolescen*[tw] OR boys[tw] OR “Child”[Mesh] OR child[tw] OR children*[tw] OR childhood[tw] OR girls[tw] OR pediatric*[tw] OR paediatric*[tw] OR teen[tw] OR teens[tw] OR teenage*[tw] OR youth[tw] OR youths[tw] | | 3,809,282
7 | #3 NOT #6 | | 128,908
8 | #5 OR #7 | | 149,538
9 | #5 OR #7 | English | 82,179
10 | “Systematic Review”[pt] OR ("review”[Publication Type] AND “systematic”[tiab]) OR “systematic review”[All Fields] OR ("review literature as topic”[MeSH] AND “systematic”[tiab]) OR “meta-analysis”[Publication Type] OR “meta-analysis as topic”[MeSH Terms] OR “Systematic Reviews as Topic”[Mesh] OR “meta-analysis”[tiab] OR “meta-analyses”[tiab] OR “meta-synthesis”[tiab] OR “meta-syntheses”[tiab] OR “Umbrella Review”[tiab] | | 404,951
11 | #9 AND #10 | | 1,467
12 | “randomized controlled trial”[pt] OR “controlled clinical trial”[pt] OR randomized [tiab] OR placebo[tiab] OR “drug therapy”[sh] OR randomly[tiab] OR trial[tiab] OR groups[tiab] | | 5,265,701
13 | #9 AND #12 | | 22,173
14 | “Cohort Studies”[MeSH] OR “Epidemiologic Studies”[MeSH] OR “Cross-Sectional Studies”[MeSH] OR “Follow-Up Studies”[MeSH] OR “Seroepidemiologic Studies”[MeSH] OR “Evaluation Studies”[Publication Type] OR “observational study” OR “observational studies" | | 2,920,425
15 | #9 AND #14 | | 13,901
16 | “Interferon-gamma Release Tests”[Mesh] OR “Tuberculin Test”[Mesh] OR IGRA OR Mantoux* OR QFT OR “QFT Gold In Tube” OR “QFT-Gold In Tube” OR “QFT-GIT” OR “QFT-Plus” OR QuantiFERON* OR “tuberculin skin test”[tiab] OR TST[tiab] OR “T-SPOT” OR “T-SPOT.TB" | | 23,021
17 | #16 AND #11 | | 168
18 | #16 AND #13 | | 1,747
19 | #16 AND #15 | | 1,729
20 | #17 OR #18 OR #19 | | 2,948
21 | #20 AND ("2020/08/24”[Date - Publication] : “3000”[Date - Publication]) | | 178
22 | “Isoniazid”[Mesh] OR INH OR isoniazid OR “Rifampin”[Mesh] OR Rifampin OR “rifapentine”[Supplementary Concept] OR rifapentine OR rifampicin | | 51,876
23 | #22 AND #11 | | 247
24 | #22 AND #13 | | 5,782
25 | #22 AND #15 | | 2,137
26 | #23 OR #24 OR #25 | | 6,365
27 | #26 AND ("2020/08/24”[Date - Publication] : “3000”[Date - Publication]) | | 429
28 | “Clinical Laboratory Techniques”[MeSH] OR “Comparative Study" [Publication Type] OR “Diagnostic Test Approval”[MeSH] OR “Diagnostic Tests, Routine”[MeSH] OR “False Negative Reactions”[MeSH] OR “False Positive Reactions”[MeSH] OR “Mass Screening”[MeSH] OR “Predictive Value of Tests”[Mesh] OR “Reproducibility of Results”[Mesh] OR “Risk Assessment”[MeSH] OR “ROC Curve”[Mesh] OR “Sensitivity and Specificity”[Mesh] OR accuracy[tw] OR “false negative”[tw] OR “false positive”[tw] OR “likelihood ratio”[tw] OR “predictive value”[tw] OR reproducib*[tw] OR ROC[tw] OR screen*[tiab] OR sensitivity[tw] OR specificity[tw] OR test*[tiab] | | 9,275,529
29 | #9 AND #28 | | 35,964
30 | #29 AND #16 | | 5,606
31 | #30 AND ("2020/08/24”[Date - Publication] : “3000”[Date - Publication]) | | 279

Cochrane Library

12/3/2021

Screening = 21; 17 imported

Interventions = 55; 37 imported

Diagnostic Accuracy of Tests = 22; 2 imported

#1 [mh "Tuberculosis"] OR [mh "Latent Tuberculosis"] OR [mh "Mycobacterium tuberculosis"] OR "latent tuberculosis":ti,ab OR "latent TB" OR LTBI:ti,ab OR Mtb:ti,ab 2779

#2 address:pt OR “autobiography”:pt OR “bibliography”:pt OR “biography”:pt OR “case control” OR "case report" OR “case reports” OR “case series” OR “comment”:pt OR "comment on" OR congress:pt OR “dictionary”:pt OR “directory”:pt OR “editorial”:pt OR “festschrift”:pt OR “historical article”:pt OR “interview”:pt OR lecture:pt OR "legal case":pt OR “legislation”:pt OR letter:pt OR “news”:pt OR “newspaper article”:pt OR “patient education handout”:pt OR “periodical index”:pt OR ([mh "Animals"] NOT [mh "Humans"]) OR rats OR cow OR cows OR chicken OR chickens OR horse OR horses OR mice OR mouse OR bovine OR sheep OR ovine OR murine OR murinae 69319

#3 #1 NOT #2 2607

#4 [mh Adult] OR Adult*:ti,ab,kw OR "middle age":ti,ab,kw OR "middle aged":ti,ab,kw 833674

#5 #3 AND #4 1672

#6 [mh adolescent] OR adolescen*:ti,ab,kw OR boys:ti,ab,kw OR [mh child] OR child:ti,ab,kw OR children:ti,ab,kw OR girls:ti,ab,kw OR [mh infant] OR infant*:ti,ab,kw OR pediatric*:ti,ab,kw OR paediatric*:ti,ab,kw OR teen:ti,ab,kw OR teens:ti,ab,kw OR teenage*:ti,ab,kw OR youth:ti,ab,kw OR youths:ti,ab,kw 293842

#7 #3 NOT #6 1734

#8 #5 OR #7 2351

#9 #8 with Cochrane Library publication date from Aug 2020 to Dec 2021 195

#10 [mh ^"clinical trials as topic"] OR (controlled:ti,ab AND trial:ti,ab) OR "controlled clinical trial":pt OR [mh "drug therapy"] OR "randomized controlled trial":pt OR "randomized controlled trial as topic":pt OR "single-blind method":pt OR "double-blind method":pt OR "random allocation":pt OR placebo:ti,ab OR randomized:ti,ab OR randomly:ti,ab OR trial:ti 1328622

#11 #9 AND #10 161

#12 [mh "Cohort Studies"] OR [mh "Epidemiologic Studies"] OR [mh " Follow-Up Studies"] OR [mh "Seroepidemiologic Studies"] OR "Evaluation Studies":pt OR [mh “Program Evaluation”] OR “observational study” OR “observational studies” 182368

#13 #9 AND #12 16

#14 [mh "Interferon-gamma Release Tests"] OR [mh "Tuberculin Test"] OR IGRA OR Mantoux* OR QFT* OR "QFT Gold In Tube" OR "QFT-Gold In Tube" OR "QFT-GIT" OR "QFT-Plus" OR QuantiFERON OR "QuantiFERON-Plus" OR "QuantiFERON-TB Gold Plus" OR "tuberculin skin test":ti,ab OR TST:ti,ab OR "T-SPOT" OR "T-SPOT.TB" 1657

#15 #14 AND #11 21

#16 #14 AND #13 2

#17 #15 OR #16 21

#18 [mh "Isoniazid"] OR INH OR isoniazid OR [mh "Rifampin"] OR Rifampin OR rifapentine OR rifampicin 3874

#19 #18 AND #11 55

#20 #18 AND #13 5

#21 #19 OR #20 55

#22 [mh "Clinical Laboratory Techniques"] OR "Comparative Study":pt OR [mh " Diagnostic Test Approval"] OR [mh "Diagnostic Tests, Routine"] OR [mh "False Negative Reactions"] OR [mh "False Positive Reactions"] OR [mh "Mass Screening"] OR [mh "Predictive Value of Tests"] OR [mh "Risk Assessment"] OR [mh "ROC Curve"] OR [mh "Reproducibility of Results"] OR [mh "Sensitivity and Specificity"] OR accuracy:ti,ab,kw OR "false negative":ti,ab,kw OR "false positive":ti,ab,kw OR "likelihood ratio":ti,ab,kw OR "predictive value":ti,ab,kw OR ROC:ti,ab,kw OR reproducib*:ti,ab,kw OR screen*:ti,ab OR sensitivity:ti,ab,kw OR specificity:ti,ab,kw OR test*:ti,ab 623231

#23 #9 AND #22 109

#24 #23 AND #14 22

#### Grey Literature Searches

72 total in EndNote

ClinicalTrials.gov, 12/3/2021

Advanced search

[underlined: Condition or disease box:] "Latent Tuberculosis" OR "Mycobacterium tuberculosis" OR "latent TB" OR LTBI OR Mtb

[underlined: Eligibility Criteria, Age Group]: Selected checkboxes: Adult (18–64), Older Adult (65+)

[underlined: Last Update Posted]: From 02/24/2021 to 12/3/2021

65 results

Saved to EndNote using Irma Klering's modified ClinicalTrials.gov "Abs" filter to include more fields

WHO ICTRP, 2/24/2021

Advanced search

Condition box: "latent tuberculosis" OR “latent TB” or LTBI

Date of registration: 02/24/2021 to 12/3/2021

Recruitment status: All

7 results

## Appendix B2 Eligibility Criteria

Criteria | Included | Excluded
Populations | All KQs: A priori specific populations of interest include those defined by age, sex, race/ethnicity, pregnancy, and higher risk for developing TB.^*^ For each KQ, we looked for evidence to inform whether results differ by subgroups.; KQs 1, 4: Asymptomatic adults belonging to populations at increased risk for LTBI.^*^ Studies that combine eligible and ineligible populations were eligible if results were stratified for the eligible portion of the study population or the ineligible portion did not exceed 25% of the study population.; KQ 2: For sensitivity outcome: Patients with bacteriologically confirmed active TB who have not yet received treatment or who had received no more than a few weeks of treatment. For specificity outcome: Healthy persons with no history of TB exposure or risks. Studies that combine children and adults or studies with both HIV-negative and HIV-positive persons (sensitivity outcome only) were eligible if results were stratified for the eligible portion of the study population or the ineligible portion did not exceed 25% of the study population.; KQs 3, 5: Asymptomatic adults with confirmed LTBI (e.g., with a positive TST and without symptoms or chest X-ray findings indicative of active TB disease); otherwise, same criteria as for KQ 1 except that close contacts of active TB patients were eligible if LTBI was confirmed. | KQs 1, 4: Children, symptomatic adults, close contacts of active TB patients, and populations at highest risk for progression from LTBI to active TB disease because of underlying immunosuppression or for whom LTBI screening and treatment would be part of standard disease management (often by specialty care providers). This includes persons with HIV, head and neck cancer, leukemia or lymphoma, silicosis, history of or planned organ transplant, dialysis, planned or active use of TNF-α inhibitors, and planned or active use of chemotherapy.; KQ 2: For sensitivity outcome: Persons with TB infection not confirmed by culture, AFB smear, or molecular tests. For specificity outcome: Persons with known history of TB or TB exposure, persons with HIV, and acutely ill persons.
Intervention and comparator | KQs 1, 4: Screening with TST, IGRA, or both compared with no screening.; KQs 2, 4: TST using Mantoux method with intermediate strength dose of PPD and standard thresholds for positive test (i.e., 5 mm, 10 mm, and 15 mm based on risk factors for the persons being tested). Commercially available, FDA-approved IGRA tests: T- SPOT.TB, QFT-Gold in tube (QFT-GIT 3rd generation), and QFT-Gold Plus (4th generation).; KQs 3, 5: Treatment with CDC-recommended regimen (INH daily for 6 or 9 months, INH twice weekly by directly observed therapy for 6 or 9 months, RIF daily for 4 months, or INH plus RPT weekly for 3 months) compared with placebo, no treatment, delayed treatment, or another eligible treatment. | KQs 1, 4: Studies with no comparator group.; KQs 2, 4: Other tests, such as nucleic acid amplification and two-step TST.; KQs 3, 5: Studies comparing other treatments or combinations (i.e., regimens that are not recommended by the CDC).
Outcomes | KQs 1, 3: Active TB disease, TB transmission, quality of life, and mortality (disease specific and overall).; KQ 2: Sensitivity, specificity, and reliability (i.e., test-retest).; KQ 4: False-positive test results leading to unnecessary testing or treatment, labeling, stigma, anxiety, and cellulitis.; KQ 5: Hepatotoxicity, mortality from hepatotoxicity, nausea, vomiting, peripheral neuropathy, development of drug-resistant TB, and other specific adverse effects of medications. | KQ 2: Concordance rates among tests and other outcomes.
Study designs | KQ 1: RCTs and prospective cohort studies.; KQ 2: RCTs, cohort studies, and cross- sectional studies.; KQ 3: Systematic reviews and meta-analyses (including network meta-analyses)^†^ and RCTs.; KQ 4: Systematic reviews, RCTs, and prospective cohort studies.; KQ 5: Systematic reviews and meta-analyses (including network meta-analyses), RCTs, prospective cohort studies, and case-control studies. | All other study designs not already indicated.
Setting | KQ 1: Study settings considered to be applicable to primary care, including primary care practices, homeless shelters, correctional facilities, college health settings, long-term care facilities, and public health clinics.; KQ 2: Any setting.; KQs 3, 5: Same as KQ 1, except that workplace settings are also eligible.; KQ 4: Studies eligible for KQ 1 or 2. | KQ 1: HIV and subspecialty care settings and workplace settings that screen for LTBI as part of a formal surveillance program for occupational exposure.; KQs 3, 5: Same as KQ 1, except that workplace settings are eligible.
Country | KQs 1, 3, 5: Countries categorized as “High” or “Very High” using the Human Development Index, as defined by the United Nations Development Programme.; KQ 2: For sensitivity outcome: Studies in any country. For specificity outcome: Studies in low-TB-burden countries.; KQ 4: Studies eligible for KQ 1 or 2. | KQs 1, 3, 5: Countries not categorized as “High” or “Very High” on the Human Development Index, as defined by the United Nations Development Programme.; KQ 2: For specificity outcome: Studies in high- TB-burden countries.^‡^
Quality | Studies rated good or fair quality. | Studies rated poor quality.
Language | Full text published in English. | Not English language.

* Adult population subgroups at increased risk for developing active TB include 1) persons who have immigrated from TB- endemic countries; 2) persons who work or reside in facilities or institutions with high-risk individuals, such as homeless shelters, correctional facilities, nursing homes, and residential facilities; and 3) persons with increased risk for progression from LTBI to active TB because of underlying illness or use of medications, injection drug use, or radiographic evidence of prior healed TB.^215^

† We focused on the best evidence to address this KQ on treatment, focusing on the most recent high-quality meta-analysis rather than re-reviewing and synthesizing the primary RCTs that were summarized in the prior review on this topic (e.g., those comparing INH vs. placebo that were published in the 1960s and 1970s).

‡ High-TB-burden countries include the following: Angola, Bangladesh, Brazil, Cambodia, Central African Republic, China, Congo, the Democratic Republic of the Congo, Democratic People’s Republic of Korea, Ethiopia, India, Indonesia, Kenya, Lesotho, Liberia, Mozambique, Myanmar, Namibia, Nigeria, Pakistan, Papua New Guinea, Peru, the Philippines, the Russian Federation, Somalia, South Africa, Thailand, the United Republic of Tanzania, Vietnam, and Zimbabwe. This list is not exhaustive but represents the countries with the highest absolute burden (high rates and high population).^4^

Abbreviations: AFB=acid fast bacilli; CDC=Centers for Disease Control and Prevention; FDA=Food and Drug Administration; HIV=human immunodeficiency virus; IGRA=interferon-gamma release assay; INH=isoniazid; KQ=key question; LTBI=latent tuberculosis infection; PPD=purified protein derivative; QFT=QuantiFERON; QFT-GIT=QuantiFERON-TB Gold-In-Tube® test (3rd-generation test); RCT=randomized, controlled trial; RIF=rifampin; RPT=rifapentine; TB=tuberculosis; TNF-α=tumor necrosis factor-α; T-SPOT.TB=commercial IGRA assay; TST=tuberculin skin test; vs.=versus.

## Appendix B3 U.S. Preventive Services Task Force Quality Rating Criteria

### Randomized, Controlled Trials and Cohort Studies

Criteria:

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements that are equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

Definition of Ratings Based on Above Criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies will be graded “fair” if any or all of the following problems occur without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.

Poor: Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Source: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015^47^

### Diagnostic Accuracy Studies

Criteria:

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of Ratings Based on Above Criteria:

Good: Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (greater than 100) of broad-spectrum patients with and without disease.

Fair: Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.

Poor: Has a fatal flaw, such as uses inappropriate reference standard; improperly administers screening test; biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients.

Source: U.S. Preventive Services Task Force. U.S. Preventive Services Task Force, Procedure Manual, Appendix VI. Rockville, MD: U.S. Preventive Services Task Force; 2015^47^