# Appendix A Background Information and Contextual Questions

## Contextual Questions (CQs)

### CQ 1 What risk assessment tools are available for use in primary care to identify adults to screen for LTBI? How do the tools incorporate race and ethnicity?

From the prior review, both the Task Force (TF) and the Evidence-based Practice Center (EPC) identified the need for tools to determine efficient ways of identifying candidates for LTBI screening and treatment. In current clinical practice, these tools are generally in the form of a checklist to help clinicians identify patients who should have further consideration for LTBI screening. The CDC recommends LTBI screening for persons at higher risk for being infected with TB bacteria, as well as those who are at higher risk of developing TB disease once infected with Mycobacterium tuberculosis.

The CDC provides an example risk assessment tool from the California Department of Public Health (CDPH).^35^ The tool recommends screening for persons with any of the following three risk factors: temporary or permanent residence of 1 month or greater in a country with a high TB rate, current or planned immunosuppression, and close contact during lifetime with someone who had TB disease. Many State departments of public health have adopted the CDPH risk assessment tool^201^ or reference the CDC guidance, for example, Michigan,^202^ Washington,^203^ Ohio,^204^ Nevada,^205^ and Pennsylvania.^206^ The Wisconsin Department of Health Services has a similar risk assessment and symptom evaluation tool, and some health departments have adopted this tool.^207,^ ^208^ Other State public health departments have developed their own risk assessment tools, such as the Tennessee Department of Health and the Virginia Department of Health.^209^,^210^,^211^ For example, the Virginia tool includes the risk factor categories that are in the CDPH tool as well as the following: birth, travel, or residence in a country with an elevated TB rate for at least 3 months and medical conditions increasing risk for progression to TB disease, including radiographic evidence of prior healed TB, low body weight (10% below ideal), silicosis, diabetes mellitus, chronic renal failure or on hemodialysis, gastrectomy, jejunoileal bypass, solid organ transplant, and head and neck cancer.^212^

The rationale for the risk factors included in the tools is largely based on LTBI disease prevalence data in various populations. For example, 71 percent of all cases of active TB in the United States in 2019 occurred among persons born outside the US.^6,^ ^213^ The top five countries contributing to these cases were Mexico, the Philippines, India, Vietnam, and China.^6,^ ^213^ Other populations are highlighted because of conditions that confer relative or actual immunosuppression. Appendix A Table 2 summarizes data on LTBI prevalence in populations that are most often considered for LTBI screening. The data for the prevalence estimates in the table sometimes come from small cohorts.

We identified one prospective, cross-sectional study with 455 participants that evaluated a questionnaire to predict positive IGRA results in asymptomatic persons.^214^ Participants ages 15 years or older from the United Arab Emirates were enrolled between August 2016 and May 2017 from hospital outpatient clinics for medical problems other than infection or TB assessment. Of those enrolled, 240 (53%) had an IGRA test performed. All enrollees completed a risk assessment questionnaire, which consisted of five questions assessing potential high-risk exposures (e.g., travel to high-TB-burden area, contact with persons with or suspected to have TB). In a multivariate logistic regression analysis, none of the risk assessment questions was associated with positive IGRA results.

None of the tools or studies we identified explicitly incorporated race or ethnicity.

Appendix A Table 1 Screening Recommendations of Other Groups

Organization, Year | Screening Recommendation | Treatment Recommendation
ATS/IDSA/CDC, 2017^37^ | A clinical practice guideline from the ATS, IDSA, and CDC recommends screening for LTBI to identify persons who may benefit from treatment before progression to active TB infection. | Not applicable
NTCA/CDC, 2019 or 2020 | A committee convened by the NTCA and CDC recommended continuation of preplacement baseline LTBI testing using either IGRA or TST and symptom evaluation for all healthcare personnel with no prior documented history of LTBI or TB disease.^198^ | A committee convened by the NTCA and CDC recommends short-course (3- to 4-month) rifamycin-based treatment regimens, which are preferred over longer-course (6- to 9- month) isoniazid monotherapy for treatment of LTBI.^40^
WHO, 2018^45^ | The WHO recommends systematic testing and treatment for:; - All persons living with HIV,; - Patients initiating anti-TNF treatment; - Patients receiving dialysis; - Patients preparing for an organ or hematological transplant; - Patients with silicosis; - Persons residing in correctional facilities in countries with high TB incidence; - Healthcare workers in countries with high TB incidence; - Immigrants in countries with high TB incidence; - Asymptomatic individuals of all ages in countries with a low TB incidence who are household contacts of persons with active TB.; The WHO recommends either a tuberculin skin test (TST) or interferon-gamma release assay (IGRA) to test for LTBI. | The WHO recommends the following: isoniazid monotherapy for 6 months is recommended for treatment of LTBI in both adults and children in countries with high and low TB incidence, rifampicin plus isoniazid daily for 3 months should be offered as an alternative to 6 months of isoniazid monotherapy as preventive treatment for children and adolescents age <15 years in countries with a high TB incidence, and a combination of rifapentine and isoniazid weekly for 3 months may be offered as an alternative to 6 months of isoniazid monotherapy as preventive treatment for both adults and children in countries with a high TB incidence.
NICE, 2019^199^ | NICE recommends TST testing in adults and children ages 2 to 65 who are close contacts of a person with pulmonary or laryngeal TB. Children younger than 2 years and adults who are immunocompromised should be assessed for risk before being tested. Persons from underserved groups, including persons experiencing homelessness, persons who misuse substances, persons residing in correctional facilities, and vulnerable migrants, who are younger than 65 years should be offered IGRA testing. | NICE recommends 3 months of isoniazid (with pyridoxine) and rifampicin to persons younger than 35 years if hepatotoxicity is a concern after an assessment of both liver function (including transaminase levels) and risk factors and 6 months of isoniazid (with pyridoxine) if interactions with rifamycins are a concern, for example, in persons with HIV or who have had a transplant.
AAP/ACOG^196^ | Current joint guidelines from the AAP and ACOG recommend screening for latent TB in early pregnancy for women at high risk for TB, including recent TB exposure, HIV infection, risk factors increasing risk of progression to active disease (such as diabetes, lupus, cancer, alcoholism, and drug addiction), use of immune-suppressing drugs such as TNF-alpha inhibitors or chronic steroids, renal failure on dialysis, homelessness, living or working in long-term care facilities such as nursing homes and prisons, being medically underserved, and being born in a country with high prevalence of TB.
CTS/CLA/PHAC^200^ | The 7th Edition of the Canadian Tuberculosis Standards by the CTS, CLA, and PHAC recommends consideration of screening for the following groups:; - Foreign-born persons; - Persons with non-HIV immune suppression and other medical or behavioral risk factors for TB; - Long-term visitors to countries with higher TB incidence; - TB contacts; - Persons with HIV infection; - Canadian-born Aboriginal Peoples; - Children; - Employees and users of healthcare and correctional facilities | The 7th Edition of the Canadian Tuberculosis Standards by the CTS, CLA, and PHAC recommends self-administered isoniazid (INH) taken daily for 9 months (9INH) for the treatment of LTBI. Acceptable alternatives include daily self-administered INH for 6 months (6INH), and daily self-administered INH and rifampin (RIF) for 3 to 4 months.

Abbreviations: AAP=American Academy of Pediatrics; ACOG=American College of Obstetrics and Gynecology; ATS=American Thoracic Society; CDC=Centers for Disease Control and Prevention; CLA=Canadian Lung Association; CTS=Canadian Thoracic Society; HIV=human immunodeficiency virus; IDSA=Infectious Disease Society of America; IGRA=interferon-gamma release assays; INH=isoniazid; LTBI=latent tuberculosis infection; NICE=National Institute for Health and Care Excellence; NTCA=National Tuberculosis Controllers Association; PHAC=Public Health Agency of Canada; RIF=rifampin; RPT=rifapentine; TB=tuberculosis; TST=tuberculin skin tests; WHO=World Health Organization.

Appendix A Table 2 Prevalence of Latent Tuberculosis Infection by High-Risk Category From Studies Published in English, French, or Spanish, 2009 Through 2014^*^

High-Risk Description | Prevalence Based on TST ≥5 mm, Median % (Range) | Prevalence Based on T-SPOT.TB, Median % (Range) | Prevalence Based on QFT-GIT, Median % (Range) | Incidence of Active TB Median Rate per 1,000 (Range) | Total Population Contributing to Effect Estimates (Number of Studies)
Persons residing in correctional facilities | 45.5 (23.1–87.6) | NR | NR | 2.6 (0.03–9.8) | 5801 (2)^†^; 331,773 (3)^ǂ^
Persons who lived in high-TB-burden countries | 39.7 (17.8–55.4) | 17.0 (9.0–24.9) | 30.2 (9.8–53.8) | 3.6 (1.3–41.2) | 29,434 (2)^§^; 1,479,542,654 (1)^‖^
Persons who use illicit drugs | 85.0 (0.3–86.7) | 45.8 (34.1–57.5) | 63.0 (1.4–66.4) | 6.0^¶^ | 872 (1)^#^
Persons experiencing homelessness | 45.6 (20.5–79.8) | NR | 53.8 (18.6–75.9) | 2.2 (0.1–4.3) | 32,108 (1)^**^; 338,568 (1)^††^

* Adapted from Getahun et al. (2015).^9^ Data are from studies conducted in countries with a TB incidence of <1 per 1,000 population. We omitted estimates for populations that are not within the scope of this report (e.g., close contacts of active TB patients; populations at highest risk for progression from LTBI to active TB disease because of underlying immunosuppression or for whom LTBI screening and treatment would be part of standard disease management, including persons living with HIV, head and neck cancer, leukemia or lymphoma, silicosis, history of or planned organ transplant, dialysis, planned or active use of TNF-α inhibitors, and planned or active use of chemotherapy).

† All persons residing in correctional facilities were systematically screened for TB.

ǂ Based on reported annual or year-end census multiplied by number of years studied. Unclear if total incarcerations is equal to unique number of persons residing in correctional facilities.

§ All newly immigrated persons were systematically screened for TB.

¶ Single study.

‖ Cases identified by national TB registry. Denominator based on number of newly arrived immigrants over 7-year period.

# Mixed population of HIV-positive and -negative persons.

** Systematically screened all residents of local homeless shelters (n=32,108).

†† Identified cases from TB registry. Denominator based on estimated homelessness in 1998 multiplied by 12-year study period. Unclear if denominator represents unique homeless persons over this time period.

Abbreviations: HIV=human immunodeficiency virus; LTBI=latent tuberculosis infection; NR=not reported; QFT-GIT=QuantiFERON-TB® Gold In-Tube (3rd-generation test); TB=tuberculosis; TNF=tumor necrosis factor; T-SPOT.TB=commercial IGRA assay; TST=tuberculin skin test.