# References

1 American Cancer Society. Melanoma Skin Cancer. Atlanta, GA: American Cancer Society [2020 October 16]. https://www.cancer.org/cancer/melanoma-skin-cancer.html.
2 Apalla Z, Lallas A, Sotiriou E, Epidemiological trends in skin cancer. Dermatology practical & conceptual. 2017;7(2):1–6. PMID: 28515985.28515985
3 Chang AE, Karnell LH, Menck HR. The National Cancer Data Base report on cutaneous and noncutaneous melanoma: a summary of 84,836 cases from the past decade. The American College of Surgeons Commission on Cancer and the American Cancer Society. Cancer. 1998;83(8):1664–78. PMID: 9781962.9781962
4 Duffy K, Grossman D. The dysplastic nevus: from historical perspective to management in the modern era: part I. Historical, histologic, and clinical aspects. J Am Acad Dermatol. 2012;67(1):1 e-16; quiz 7–8. PMID: 22703915.22703915
5 Gershenwald JE, Scolyer RA, Hess KR, Melanoma staging: Evidence-based changes in the American Joint Committee on Cancer eighth edition cancer staging manual. CA: a cancer journal for clinicians. 2017;67(6):472–92. PMID: 29028110.29028110
6 American Society of Clinical Oncology (ASCO) Society of Clinical Oncology (ASCO). Skin Cancer (Non-Melanoma): Introduction. Cancer.Net]. https://www.cancer.net/cancer-types/skin-cancer-non-melanoma/introduction.
7 Rogers HW, Weinstock MA, Feldman SR, Incidence Estimate of Nonmelanoma Skin Cancer (Keratinocyte Carcinomas) in the U.S. Population, 2012. JAMA Dermatol. 2015;151(10):1081–6. PMID: 25928283.25928283
8 Harris RB, Griffith K, Moon TE. Trends in the Incidence of Nonmelanoma Skin Cancers in Southeastern Arizona, 1985–1996. J Am Acad Dermatol. 2001;45(4):528–36. PMID: 11568742.11568742
9 Eisemann N, Waldmann A, Geller AC, Non-Melanoma Skin Cancer Incidence and Impact of Skin Cancer Screening on Incidence. The Journal of investigative dermatology. 2014;134(1):43–50. PMID: 23877569.23877569
10 Xiang F, Lucas R, Hales S, Incidence of nonmelanoma skin cancer in relation to ambient UV radiation in white populations, 1978–2012: empirical relationships. JAMA Dermatol. 2014;150(10):1063–71. PMID: 25103031.25103031
11 Weinstock MA, Bogaars HA, Ashley M, Nonmelanoma skin cancer mortality. A population-based study. Archives of dermatology. 1991;127(8):1194–7. PMID: 1863078.1863078
12 Karia PS, Han J, Schmults CD. Cutaneous squamous cell carcinoma: estimated incidence of disease, nodal metastasis, and deaths from disease in the United States, 2012. J Am Acad Dermatol. 2013;68(6):957–66. PMID: 23375456.23375456
13 American Cancer Society. Key Statistics for Melanoma Skin Cancer. American Cancer Society 2020/10/23]. https://www.cancer.org/cancer/melanoma-skin-cancer/about/keystatistics.html.
14 SEER. Cancer Stat Facts: Melanoma of the Skin. Seer.cancer.gov [2022 August 24]. https://seer.cancer.gov/statfacts/html/melan.html.
15 Livingstone E, Windemuth-Kieselbach C, Eigentler TK, A first prospective population-based analysis investigating the actual practice of melanoma diagnosis, treatment and follow-up. European journal of cancer (Oxford, England: 1990). 2011;47(13):1977–89. PMID: 21612915.21612915
16 Welch HG, Woloshin S, Schwartz LM. Skin Biopsy Rates and Incidence of Melanoma: Population Based Ecological Study. BMJ (Clinical research ed). 2005;331(7515):481. PMID: 16081427.16081427
17 American Cancer Society. Cancer Facts & Figures 2020. Atlanta:: American Cancer Society 2020/10/20]. https://www.cancer.org/content/dam/cancer-org/research/cancer-facts-and-statistics/annual-cancer-facts-and-figures/2020/cancer-facts-and-figures-2020.pdf.
18 U.S. Cancer Statistics Working Group. U.S. Cancer Statistics Data Visualizations Tool, based on 2019 submission data (1999–2017). U.S. Department of Health and Human Services, Centers for Disease Control and Prevention and National Cancer Institute [2020 November]. www.cdc.gov/cancer/dataviz.
19 Kurtansky NR, Dusza SW, Halpern AC, An Epidemiologic Analysis of Melanoma Overdiagnosis in the United States, 1975–2017. The Journal of investigative dermatology. 2021. PMID: 34902365.34902365
20 SEER. Melanoma of the Skin: Recent Trends in U.S. Age-Adjusted Mortality Rates, 2000–2018. 2020/10/20]. https://seer.cancer.gov/explorer/application.html?site=53&data_type=2&graph_type=2&compareBy=age_range&chk_age_range_1=1&chk_age_range_9=9&chk_age_range_141=141&chk_age_range_157=157&sex=1&race=1&advopt_precision=1&advopt_display=2#fnote_methodology
21 SEER. Melanoma of the Skin: U.S. 5-Year Age-Adjusted Mortality Rates, 2015–2019. CDC [2022 Aug 24]. https://seer.cancer.gov/explorer/application.html?site=53&data_type=2&graph_type=10&compareBy=race&chk_race_5=5&chk_race_4=4&chk_race_3=3&chk_race_6=6&chk_race_8=8&chk_race_2=2&series=9&sex=1&age_range=1&advopt_precision=1&advopt_show_ci=on&advopt_display=2#fnote_source.
22 SEER*Explorer. Melanoma of the Skin: Stage Distribution of SEER Incidence Cases, 2010–2019, by Race/Ethnicity, Both Sexes, All Ages. Surveillance, Epidemiology, and End Results Program, National Cancer Institute [2022 August 24]. https://seer.cancer.gov/explorer/application.html?site=53&data_type=1&graph_type=4&compareBy=race&chk_race_4=4&chk_race_3=3&chk_race_2=2&sex=1&age_range=1&advopt_precision=1&advopt_display=2.
23 SEER*Explorer. Melanoma of the Skin: SEER 5-Year Relative Survival Rates, 2012–2018 by Race/Ethnicity and Stage at Diagnosis, Both Sexes, All Ages. Surveillance, Epidemiology, and End Results Program, National Cancer Institute [2022 Aug 24]. https://seer.cancer.gov/explorer/application.html?site=53&data_type=4&graph_type=5&compareBy=race&chk_race_4=4&chk_race_3=3&chk_race_2=2&series=stage&chk_stage_104=104&chk_stage_105=105&chk_stage_106=106&sex=1&age_range=1&advopt_precision=1&advopt_show_ci=on&advopt_display=2.
24 Higgins S, Nazemi A, Feinstein S, Clinical Presentations of Melanoma in African Americans, Hispanics, and Asians. Dermatol Surg. 2019;45(6):791–801. PMID: 30614836.30614836
25 Alexandrescu DT, Maslin B, Kauffman CL, Malignant melanoma in pigmented skin: does the current interventional model fit a different clinical, histologic, and molecular entity? Dermatol Surg. 2013;39(9):1291–303. PMID: 23795952.23795952
26 Cortez JL, Vasquez J, Wei ML. The Impact of Demographics, Socioeconomics, and Healthcare Access on Melanoma Outcomes. Journal of the American Academy of Dermatology. 2020.
27 Joseph MG, Zulueta WP, Kennedy PJ. Squamous Cell Carcinoma of the Skin of the Trunk and Limbs: The Incidence of Metastases and their Outcome. The Australian and New Zealand journal of surgery. 1992;62(9):697–701. PMID: 1520151.1520151
28 Brantsch KD, Meisner C, Schönfisch B, Analysis of Risk Factors Determining Prognosis of Cutaneous Squamous-Cell Carcinoma: A Prospective Study. The Lancet Oncology. 2008;9(8):713–20. PMID: 18617440.18617440
29 Brougham ND, Dennett ER, Cameron R, The Incidence of Metastasis from Cutaneous Squamous Cell Carcinoma and the Impact of its Risk Factors. Journal of surgical oncology. 2012;106(7):811–5. PMID: 22592943.22592943
30 Gloster HM Jr, Neal K. Skin Cancer in Skin of Color. J Am Acad Dermatol. 2006;55(5):741–60; quiz 61–4. PMID: 17052479.17052479
31 American Cancer Society. Skin Cancer: Basal and Squamus Cell. Atlanta, GA: American Cancer Society [2020 October 16]. https://www.cancer.org/cancer/basal-and-squamous-cell-skin-cancer.html.
32 Lattanzi M, Lee Y, Simpson D, Primary Melanoma Histologic Subtype: Impact on Survival and Response to Therapy. Journal of the National Cancer Institute. 2019;111(2):180–8. PMID: 29912415.29912415
33 Shaikh WR, Xiong M, Weinstock MA. The contribution of nodular subtype to melanoma mortality in the United States, 1978 to 2007. Archives of dermatology. 2012;148(1):30–6. PMID: 21931016.21931016
34 Swetter SM, Boldrick JC, Jung SY, Increasing incidence of lentigo maligna melanoma subtypes: northern California and national trends 1990–2000. The Journal of investigative dermatology. 2005;125(4):685–91. PMID: 16185266.16185266
35 Tannous ZS, Lerner LH, Duncan LM, Progression to Invasive Melanoma from Malignant Melanoma In Situ, Lentigo Maligna Type. Human pathology. 2000;31(6):705–8. PMID: 10872664.10872664
36 Clark WH Jr., Elder DE, Van Horn M. The Biologic Forms of Malignant Melanoma. Human pathology. 1986;17(5):443–50. PMID: 3699806.3699806
37 Huang K, Fan J, Misra S. Acral Lentiginous Melanoma: Incidence and Survival in the United States, 2006–2015, an Analysis of SEER Registry. Journal of Surgical Research. 2020;251:329–39.32208196
38 Wang Y, Zhao Y, Ma S. Racial differences in six major subtypes of melanoma: Descriptive epidemiology. BMC Cancer. 2016;16(1).
39 Balch CM, Soong SJ, Gershenwald JE, Prognostic Factors Analysis of 17,600 Melanoma Patients: Validation of the American Joint Committee on Cancer Melanoma Staging System. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. 2001;19(16):3622–34. PMID: 11504744.11504744
40 Clark WH Jr., Elder DE, Guerry Dt, Model Predicting Survival in Stage I Melanoma Based on Tumor Progression. J Natl Cancer Inst. 1989;81(24):1893–904. PMID: 2593166.2593166
41 Rigel DS, Carucci JA. Malignant Melanoma: Prevention, Early Detection, and Treatment in The 21st Century. CA: a cancer journal for clinicians. 2000;50(4):215–36; quiz 37–40. PMID: 10986965.10986965
42 Wernli KJ, Henrikson NB, Morrison CC, Screening for Skin Cancer in Adults: Updated Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2016;316(4):436–47. PMID: 27458949.27458949
43 Zell JA, Cinar P, Mobasher M, Survival for patients with invasive cutaneous melanoma among ethnic groups: the effects of socioeconomic status and treatment. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. 2008;26(1):66–75. PMID: 18165642.18165642
44 Armstrong BK, English DR. Epidemiologic studies. In: Balch CM, Houghton AN, Milton GW, Sober AJ, Soong S-J, editors. Cutaneous melanoma. 2 ed. Philadelphia: JB Lippincott; 1992. p. 12–26.
45 Cancer IAfRo. IARC Monographs on the Evaluation of Carcinogenic Risks to Humans: Solar and Ultraviolet Radiation. Lyon, France 1992.
46 International Agency for Research on Cancer. Agents classified by the IARC Monographs, Volumes 1–114. IARC Monographs on the Identification of Carcinogenic Hazards to Humans 2020/10/22]. https://monographs.iarc.fr/agents-classified-by-the-iarc/.
47 Gandini S, Sera F, Cattaruzza MS, Meta-Analysis of Risk Factors for Cutaneous Melanoma: II. Sun Exposure. European journal of cancer (Oxford, England: 1990). 2005;41(1):45–60. PMID: 15617990.15617990
48 Henrikson NB, Morrison CC, Blasi PR, Behavioral Counseling for Skin Cancer Prevention: Evidence Report and Systematic Review for the US Preventive Services Task Force. JAMA. 2018;319(11):1143–57. PMID: 29558557.29558557
49 Wehner MR, Shive ML, Chren MM, Indoor Tanning and Non-Melanoma Skin Cancer: Systematic Review and Meta-Analysis. BMJ (Clinical research ed). 2012;345:e5909. PMID: 23033409.23033409
50 Colantonio S, Bracken MB, Beecker J. The Association of Indoor Tanning and Melanoma in Adults: Systematic Review and Meta-Analysis. J Am Acad Dermatol. 2014;70(5):847–57.e1–18. PMID: 24629998.24629998
51 International Agency for Research on Cancer Working Group on artificial ultraviolet (UV) light and skin cancer. The Association of Use of Sunbeds with Cutaneous Malignant Melanoma and other Skin Cancers: A Systematic Review. International journal of cancer. 2007;120(5):1116–22. PMID: 1713133517131335.
52 SEER*Explorer. Recent Trends in SEER Age-Adjusted Incidence Rates, 2000–2018. 12/01/2021]. https://seer.cancer.gov/explorer/application.html?site=53&data_type=1&graph_type=2&compareBy=age_range&chk_age_range_1=1&chk_age_range_9=9&chk_age_range_141=141&chk_age_range_157=157&rate_type=2&sex=2&race=1&stage=101&advopt_precision=1&advopt_show_ci=on&advopt_display=2.
53 Melanoma Strikes Men Harder. American Academy of Dermatology Association 12/09/2021]. https://www.aad.org/public/diseases/skin-cancer/types/common/melanoma/men-50.
54 Fitzpatrick TB. The validity and practicality of sun-reactive skin types I through VI. Archives of dermatology. 1988;124(6):869–71. PMID: 3377516.3377516
55 Gandini S, Sera F, Cattaruzza MS, Meta-Analysis of Risk Factors for Cutaneous Melanoma: I. Common and Atypical Naevi. European journal of cancer (Oxford, England: 1990). 2005;41(1):28–44. PMID: 15617989.15617989
56 Veierød MB, Couto E, Lund E, Host Characteristics, Sun Exposure, Indoor Tanning and Risk of Squamous Cell Carcinoma of the Skin. International journal of cancer. 2014;135(2):413–22. PMID: 24408678.24408678
57 Khalesi M, Whiteman DC, Tran B, A Meta-Analysis of Pigmentary Characteristics, Sun Sensitivity, Freckling and Melanocytic Nevi And Risk of Basal Cell Carcinoma of the Skin. Cancer epidemiology. 2013;37(5):534–43. PMID: 23849507.23849507
58 Gandini S, Sera F, Cattaruzza MS, Meta-Analysis of Risk Factors for Cutaneous Melanoma: III. Family History, Actinic Damage and Phenotypic Factors. European journal of cancer (Oxford, England: 1990). 2005;41(14):2040–59. PMID: 16125929.16125929
59 Lopes F, Sleiman MG, Sebastian K, UV Exposure and the Risk of Cutaneous Melanoma in Skin of Color: A Systematic Review. JAMA Dermatol. 2021;157(2):213–9. PMID: 33325988.33325988
60 Cho E, Rosner BA, Colditz GA. Risk Factors for Melanoma by Body Site. Cancer epidemiology, biomarkers & prevention: a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. 2005;14(5):1241–4. PMID: 15894679.15894679
61 Tucker MA, Halpern A, Holly EA, Clinically Recognized Dysplastic Nevi. A Central Risk Factor for Cutaneous Melanoma. JAMA. 1997;277(18):1439–44. PMID: 9145715.9145715
62 Veierød MB, Weiderpass E, Thörn M, A Prospective Study of Pigmentation, Sun Exposure, and Risk of Cutaneous Malignant Melanoma in Women. J Natl Cancer Inst. 2003;95(20):1530–8. PMID: 14559875.14559875
63 Marghoob AA, Slade J, Salopek TG, Basal Cell and Squamous Cell Carcinomas are Important Risk Factors for Cutaneous Malignant Melanoma. Screening Implications. Cancer. 1995;75(2 Suppl):707–14. PMID: 7804999.7804999
64 Pomerantz H, Huang D, Weinstock MA. Risk of Subsequent Melanoma After Melanoma In Situ and Invasive Melanoma: A Population-Based Study from 1973 to 2011. J Am Acad Dermatol. 2015;72(5):794–800. PMID: 25769192.25769192
65 Spanogle JP, Clarke CA, Aroner S, Risk of Second Primary Malignancies Following Cutaneous Melanoma Diagnosis: A Population-Based Study. J Am Acad Dermatol. 2010;62(5):757–67. PMID: 20223559.20223559
66 Olsen CM, Carroll HJ, Whiteman DC. Familial Melanoma: A Meta-Analysis and Estimates of Attributable Fraction. Cancer epidemiology, biomarkers & prevention: a publication of the American Association for Cancer Research, cosponsored by the American Society of Preventive Oncology. 2010;19(1):65–73. PMID: 20056624.20056624
67 Rivers JK. Melanoma. Lancet (London, England). 1996;347(9004):803–6. PMID: 8622339.8622339
68 Landi MT, Bishop DT, MacGregor S, Genome-wide association meta-analyses combining multiple risk phenotypes provide insights into the genetic architecture of cutaneous melanoma susceptibility. Nat Genet. 2020;52(5):494–504. PMID: 32341527.32341527
69 Law MH, Aoude LG, Duffy DL, Multiplex melanoma families are enriched for polygenic risk. Hum Mol Genet. 2020;29(17):2976–85. PMID: 32716505.32716505
70 Wei EX, Li X, Nan H. Having a first-degree relative with melanoma increases lifetime risk of melanoma, squamous cell carcinoma, and basal cell carcinoma. J Am Acad Dermatol. 2019;81(2):489–99. PMID: 31230976.31230976
71 Haugh AM, Njauw CN, Bubley JA, Genotypic and Phenotypic Features of BAP1 Cancer Syndrome: A Report of 8 New Families and Review of Cases in the Literature. JAMA Dermatol. 2017;153(10):999–1006. PMID: 28793149.28793149
72 Choquet H, Ashrafzadeh S, Kim Y, Genetic and environmental factors underlying keratinocyte carcinoma risk. JCI Insight. 2020;5(10). PMID: 32434987.32434987
73 Lambert WC, Kuo HR, Lambert MW. Xeroderma Pigmentosum. Dermatologic clinics. 1995;13(1):169–209. PMID: 7712643.7712643
74 Abbasi NR, Shaw HM, Rigel DS, Early Diagnosis of Cutaneous Melanoma: Revisiting the ABCD criteria. Jama. 2004;292(22):2771–6. PMID: 15585738.15585738
75 Grob JJ, Bonerandi JJ. The 'Ugly Duckling' Sign: Identification of the Common Characteristics of Nevi in an Individual as a Basis for Melanoma Screening. Archives of dermatology. 1998;134(1):103–4. PMID: 9449921.9449921
76 Jones OT, Jurascheck LC, van Melle MA, Dermoscopy for melanoma detection and triage in primary care: a systematic review. BMJ open. 2019;9(8):e027529. PMID: 31434767.31434767
77 Westerhoff K, McCarthy WH, Menzies SW. Increase in the sensitivity for melanoma diagnosis by primary care physicians using skin surface microscopy. Br J Dermatol. 2000;143(5):1016–20. PMID: 11069512.11069512
78 Menzies SW, Emery J, Staples M, Impact of dermoscopy and short-term sequential digital dermoscopy imaging for the management of pigmented lesions in primary care: a sequential intervention trial. Br J Dermatol. 2009;161(6):1270–7. PMID: 19747359.19747359
79 Swetter SM, Tsao H, Bichakjian CK, Guidelines of care for the management of primary cutaneous melanoma. J Am Acad Dermatol. 2019;80(1):208–50. PMID: 30392755.30392755
80 Thomas V, Aasi S, Wilson L, Cancer of the Skin. In: DeVita VT, Lawrence TS, Rosenberg SA, DePinho RA, RA W, editors. DeVita, Hellman and Rosenberg's Cancer: Principles and Practice of Oncology. 8th ed. Philadelphia: Wolters Kluwer Health/Lippincott Williams & Wilkins; 2008. p. 1863–87.
81 Wang H, Xu Y, Shi J, Photodynamic therapy in the treatment of basal cell carcinoma: a systematic review and meta-analysis. Photodermatol Photoimmunol Photomed. 2015;31(1):44–53. PMID: 25377432.25377432
82 Zou Y, Zhao Y, Yu J, Photodynamic therapy versus surgical excision to basal cell carcinoma: meta-analysis. J Cosmet Dermatol. 2016;15(4):374–82. PMID: 27363535.27363535
83 Slingluff CL Jr, Flaherty KT, Rosenberg SA, Melanoma Section 2 Cutaneous Melanoma. In: deVita VT, Lawrence TS, Rosenberg SA, dePinho RA, Weinberg RA, editors. DeVita, Hellman, and Rosenberg's Cancer: Priniciples and Practice of Oncology. 8th ed. Philadelphia: Wolters, Kluwer Health/Lippencourt Williams & Wilkins; 2008. p. 1897–951.
84 Franklin C, Livingstone E, Roesch A, Immunotherapy in melanoma: Recent advances and future directions. Eur J Surg Oncol. 2017;43(3):604–11. PMID: 27769635.27769635
85 Vesely MD, Chen L. Normalization Cancer Immunotherapy for Melanoma. The Journal of investigative dermatology. 2020;140(6):1134–42. PMID: 32092349.32092349
86 Curti BD, Faries MB. Recent Advances in the Treatment of Melanoma. New England Journal of Medicine. 2021;384(23):2229–40.34107182
87 National cancer Institute. Drugs Approved for Melanoma. National Cancer Institute 11/22/2021]. https://www.cancer.gov/about-cancer/treatment/drugs/melanoma.
88 Schwartz JL, Wang TS, Hamilton TA, Thin primary cutaneous melanomas: associated detection patterns, lesion characteristics, and patient characteristics. Cancer. 2002;95(7):1562–8. PMID: 12237926.12237926
89 Epstein DS, Lange JR, Gruber SB, Is physician detection associated with thinner melanomas? JAMA. 1999;281(7):640–3. PMID: 10029126.10029126
90 Oliveria SA, Heneghan MK, Cushman LF, Skin Cancer Screening by Dermatologists, Family Practitioners, and Internists: Barriers and Facilitating Factors. Archives of dermatology. 2011;147(1):39–44. PMID: 21242390.21242390
91 Shellenberger RA, Tawagi K, Kakaraparthi S, Are Primary Care Residents Trained to Perform Skin Cancer Examinations? J Gen Intern Med. 2018;33(11):1839–41. PMID: 30022412.30022412
92 Kirsner RS, Muhkerjee S, Federman DG. Skin Cancer Screening in Primary Care: Prevalence And Barriers. J Am Acad Dermatol. 1999;41(4):564–6. PMID: 10495376.10495376
93 Goulart JM, Quigley EA, Dusza S, Skin cancer education for primary care physicians: a systematic review of published evaluated interventions. J Gen Intern Med. 2011;26(9):1027–35. PMID: 21472502.21472502
94 Swetter SM, Chang J, Shaub AR, Primary Care-Based Skin Cancer Screening in a Veterans Affairs Health Care System. JAMA Dermatol. 2017;153(8):797–801. PMID: 28593242.28593242
95 Keesara S, Jonas A, Schulman K. Covid-19 and Health Care's Digital Revolution. The New England journal of medicine. 2020;382(23):e82. PMID: 32240581.32240581
96 Totten AM, Hansen RN, Wagner J, Telehealth for Acute and Chronic Care Consultations. Rockville (MD) 2019.
97 Finnane A, Dallest K, Janda M, Teledermatology for the Diagnosis and Management of Skin Cancer: A Systematic Review. JAMA Dermatol. 2017;153(3):319–27. PMID: 27926766.27926766
98 Totten AM, Womack DM, Eden KB, Telehealth: Mapping the Evidence for Patient Outcomes From Systematic Reviews. Rockville (MD) 2016.
99 Bibbins-Domingo K, Grossman DC, Curry SJ, Screening for Skin Cancer: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;316(4):429–35. PMID: 27458948.27458948
100 American Cancer Society. Can Melanoma Skin Cancer Be Found Early?: American Cancer Society 2020/10/23]. https://www.cancer.org/cancer/melanoma-skin-cancer/detection-diagnosis-staging/detection.html#references.
101 American Cancer Society. Guidelines for the Early Detection of Cancer. American Cancer Society 2020/10/20]. https://www.cancer.org/healthy/find-cancer-early/cancer-screening-guidelines/american-cancer-society-guidelines-for-the-early-detection-of-cancer.html.
102 American Academy of Dermatology. Skin Cancer: Incidence Rates. American Academy of Dermatology Association 2020/10/20]. https://www.aad.org/media/stats-skin-cancer.
103 American Academy of Dermatology. Public Health Programs: Free Cancer Screenings. American Academy of Dermatology Association 2020/10/20]. https://www.aad.org/public/public-health/skin-cancer-screenings.
104 Breitbart EW, Waldmann A, Nolte S, Systematic skin cancer screening in Northern Germany. J Am Acad Dermatol. 2012;66(2):201–11. PMID: 22074699.22074699
105 Grossman DC, Curry SJ, Owens DK, Behavioral Counseling to Prevent Skin Cancer: US Preventive Services Task Force Recommendation Statement. Jama. 2018;319(11):1134–42. PMID: 29558558.29558558
106 Wernli KJ, Henrikson NB, Morrison CC, Screening for Skin Cancer in Adults: An Updated Systematic Evidence Review for the U.S. Preventive Services Task Force. Rockville (MD) 2016.
107 Svedman FC, Pillas D, Taylor A, Stage-specific survival and recurrence in patients with cutaneous malignant melanoma in Europe – A systematic review of the literature. Clin Epidemiol. 2016;8:109–22.27307765
108 Miller R, Walker S, Shui I, Epidemiology and survival outcomes in stages II and III cutaneous melanoma: A systematic review. Melanoma manag. 2020;7(1):39–51.
109 Shellenberger RA, Fayyaz F, Sako Z, Impact of Biopsy Technique on Clinically Important Outcomes for Cutaneous Melanoma: A Systematic Review and Meta-analysis. Mayo Clinic Proceedings: Innovations, Quality and Outcomes. 2020;4(4):373–83.
110 McFarland SL, Schram SE. Physician skin examinations for melanoma screening. Cutis. 2015;96(3):175–82. PMID: 26562268.26562268
111 Moody JA, Ali RF, Carbone AC, Complications of sentinel lymph node biopsy for melanoma - A systematic review of the literature. European Journal of Surgical Oncology. 2017;43(2):270–7. PMID: 27423448.27423448
112 Kyrgidis A, Tzellos T, Mocellin S, Sentinel lymph node biopsy followed by lymph node dissection for localised primary cutaneous melanoma. Cochrane Database of Systematic Reviews. 2015(5):CD010307. PMID: 25978975.25978975
113 Dinnes J, Deeks JJ, Grainge MJ, Visual inspection for diagnosing cutaneous melanoma in adults. Cochrane Database of Systematic Reviews. 2018;12:CD013194. PMID: 30521684.30521684
114 Madeja J, Kelsberg G, Safranek S. Does screening by primary care providers effectively detect melanoma and other skin cancers? J. 2020;69(2):E10–E2. PMID: 32182298.32182298
115 Wang S, Ezaldein HH, Delost GR, Safety and Efficacy of Mohs Micrographic Surgery in Children and Adolescents: A Systematic Review. Dermatologic Surgery. 2020;46(7):880–4. PMID: 31834072.31834072
116 United Nations Human Development Program. Human Development Index (HDI). [2020 October 23]. http://hdr.undp.org/en/content/human-development-index-hdi.
117 Wells G, Shea B, O'Connell D, The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. [2021 July 12]. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
118 Berkman ND, Lohr KN, Ansari M, Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. Rockville (MD) 2008.
119 Atkins D, Eccles M, Flottorp S, Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589.15615589
120 Boniol M, Autier P, Gandini S. Melanoma mortality following skin cancer screening in Germany. BMJ open. 2015;5(9):e008158. PMID: 26373399.26373399
121 Datzmann T, Schoffer O, Meier F, Are patients benefiting from participation in the German skin cancer screening programme? A large cohort study based on administrative data. Br J Dermatol. 2022;186(1):69–77. PMID: 34289097.34289097
122 Eisemann N, Waldmann A, Holleczek B, Observed and Expected Mortality in the German Skin Cancer Screening Pilot Project Screen. J Med Screen. 2018;25(3):166–8.29169295
123 Geller AC, Greinert R, Sinclair C, A nationwide population-based skin cancer screening in Germany: proceedings of the first meeting of the International Task Force on Skin Cancer Screening and Prevention (September 24 and 25, 2009). Cancer epidemiology. 2010;34(3):355–8. PMID: 20381443.20381443
124 Kaiser M, Schiller J, Schreckenberger C. The effectiveness of a population-based skin cancer screening program: evidence from Germany. Eur J Health Econ. 2018;19(3):355–67. PMID: 28353004.28353004
125 Katalinic A, Eisemann N, Waldmann A. Skin Cancer Screening in Germany. Documenting Melanoma Incidence and Mortality From 2008 to 2013. Deutsches Arzteblatt international. 2015;112(38):629–34. PMID: 26429634.26429634
126 Katalinic A, Waldmann A, Weinstock MA, Does skin cancer screening save lives?: an observational study comparing trends in melanoma mortality in regions with and without screening. Cancer. 2012;118(21):5395–402. PMID: 22517033.22517033
127 Kornek T, Schafer I, Reusch M, Routine skin cancer screening in Germany: four years of experience from the dermatologists' perspective. Dermatology. 2012;225(4):289–93. PMID: 23295723.23295723
128 Stang A, Jöckel KH. Does Skin Cancer Screening Save Lives? A Detailed Analysis of Mortality Time Trends in Schleswig-Holstein and Germany. Cancer. 2016;122(3):432–7. PMID: 26480048.26480048
129 Aitken JF, Elwood M, Baade PD, Clinical whole-body skin examination reduces the incidence of thick melanomas. International journal of cancer. 2010;126(2):450–8. PMID: 19609948.19609948
130 Cristofolini M, Boi S, Cattoni D, A 10-Year Follow-Up Study of Subjects Recruited in a Health Campaign for the Early Diagnosis of Cutaneous Melanoma: Suggestions for the Screening Timetable. Dermatology. 2015;231(4):345–52. PMID: 26278413.26278413
131 Ferris LK, Saul MI, Lin Y, A Large Skin Cancer Screening Quality Initiative: Description and First-Year Outcomes. JAMA Oncology. 2017;3(8):1112–5. PMID: 28241191.28241191
132 Hoorens I, Vossaert K, Pil L, Total-body examination vs lesion-directed skin cancer screening. JAMA Dermatol. 2016;152(1):27–34.26466155
133 Krensel M, Andrees V, Mohr N, Costs of routine skin cancer screening in Germany - a claims data analysis. Clin Exp Dermatol. 2020;30:30. PMID: 33378094.33378094
134 Matsumoto M, Wack S, Weinstock MA, Five-Year Outcomes of a Melanoma Screening Initiative in a Large Health Care System. JAMA Dermatol. 2022. PMID: 35385051.35385051
135 Trautmann F, Meier F, Seidler A, Effects of the German skin cancer screening programme on melanoma incidence and indicators of disease severity. British Journal of Dermatology. 2016;175(5):912–9. PMID: 27203791.27203791
136 Gambichler T, Senger E, Rapp S, Deep shave excision of macular melanocytic nevi with the razor blade biopsy technique. Dermatol Surg. 2000;26(7):662–6. PMID: 10886275.10886275
137 Matthews NH, Risica PM, Ferris LK, Psychosocial impact of skin biopsies in the setting of melanoma screening: a cross-sectional survey. British Journal of Dermatology. 2019;180(3):664–5. PMID: 30183068.30183068
138 Risica PM, Matthews NH, Dionne L, Psychosocial consequences of skin cancer screening. Preventive Medicine Reports. 2018;10:310–6. PMID: 29868385.29868385
139 Dawes SM, Tsai S, Gittleman H, Racial disparities in melanoma survival. Journal of the American Academy of Dermatology. 2016;75(5):983–91. PMID: 27476974.27476974
140 Enninga EAL, Moser JC, Weaver AL, Survival of cutaneous melanoma based on sex, age, and stage in the United States, 1992–2011. Cancer Medicine. 2017;6(10):2203–12. PMID: 28879661.28879661
141 Farrow NE, Turner MC, Salama AKS, Overall Survival Improved for Contemporary Patients with Melanoma: A 2004–2015 National Cancer Database Analysis. Oncolog. 2020;8(2):261–75. PMID: 32700043.32700043
142 Khosrotehrani K, Dasgupta P, Byrom L, Melanoma survival is superior in females across all tumour stages but is influenced by age. Arch Dermatol Res. 2015;307(8):731–40. PMID: 26103951.26103951
143 Mahendraraj K, Sidhu K, Lau CS, Malignant Melanoma in African-Americans: A Population-Based Clinical Outcomes Study Involving 1106 African-American Patients from the Surveillance, Epidemiology, and End Result (SEER) Database (1988–2011). Medicine. 2017;96(15):e6258. PMID: 28403068.28403068
144 Qian Y, Johannet P, Sawyers A, The ongoing racial disparities in melanoma: An analysis of the Surveillance, Epidemiology, and End Results database (1975–2016). J Am Acad Dermatol. 2021;84(6):1585–93. PMID: 32861710.32861710
145 Robsahm TE, Helsing P, Nilssen Y, High mortality due to cutaneous melanoma in Norway: a study of prognostic factors in a nationwide cancer registry. Clin Epidemiol. 2018;10:537–48. PMID: 29780262.29780262
146 Ward-Peterson M, Acuna JM, Alkhalifah MK, Association Between Race/Ethnicity and Survival of Melanoma Patients in the United States Over 3 Decades: A Secondary Analysis of SEER Data. Medicine (Baltimore). 2016;95(17):e3315. PMID: 27124020.27124020
147 Zheng G, Chattopadhyay S, Sundquist K, Association between tumor characteristics and second primary cancers with cutaneous melanoma survival: A nationwide cohort study. Pigment Cell & Melanoma Research. 2020;33(4):625–32. PMID: 32012479.32012479
148 Anastasiadou Z, Schafer I, Siebert J, Participation and health care provision of statutory skin cancer screening in Germany - a secondary data analysis. Journal of the European Academy of Dermatology & Venereology,. 2016;30(3):424–7. PMID: 26856813.26856813
149 Hemminki K, Sundquist K, Sundquist J, Familial Risks and Proportions Describing Population Landscape of Familial Cancer. Cancers (Basel). 2021;13(17). PMID: 34503195.35008178
150 Anders MP, Fengler S, Volkmer B, Nationwide skin cancer screening in Germany: Evaluation of the training program. Int J Dermatol. 2017;56(10):1046–51. PMID: 28832980.28832980
151 Tikkanen R, Osborn R, Mossialos E, International Health Care System Profiles: Germany. The Commonwealth Fund [2022 April 6]. https://www.commonwealthfund.org/international-health-policy-center/countries/germany.
152 Cole P, Morrison AS. Basic issues in population screening for cancer. J Natl Cancer Inst. 1980;64(5):1263–72. PMID: 6767876.6767876
153 Dufault B, Klar N. The quality of modern cross-sectional ecologic studies: a bibliometric review. Am J Epidemiol. 2011;174(10):1101–7. PMID: 21940800.21940800
154 Tu JV, Ko DT. Ecological studies and cardiovascular outcomes research. Circulation. 2008;118(24):2588–93. PMID: 19064693.19064693
155 Morgenstern H. Ecologic studies in epidemiology: concepts, principles, and methods. Annual review of public health. 1995;16:61–81. PMID: 7639884.7639884
156 Stang A, Jockel KH, Heidinger O. Skin cancer rates in North Rhine-Westphalia, Germany before and after the introduction of the nationwide skin cancer screening program (2000–2015). Eur J Epidemiol. 2018;33(3):303–12. PMID: 29294207.29294207
157 Eisemann N, Jansen L, Castro FA, Survival with nonmelanoma skin cancer in Germany. British Journal of Dermatology. 2016;174(4):778–85. PMID: 26676514.26676514
158 Kosary CL, Altekruse SF, Ruhl J, Clinical and prognostic factors for melanoma of the skin using SEER registries: collaborative stage data collection system, version 1 and version 2. Cancer. 2014;120 Suppl 23:3807–14. PMID: 25412392.25412392
159 Gimotty PA, Shore R, Lozon NL, Miscoding of Melanoma Thickness in SEER: Research and Clinical Implications. The Journal of investigative dermatology. 2016;136(11):2168–72. PMID: 27354265.27354265
160 Johansson M, Brodersen J, Gøtzsche PC, Screening for reducing morbidity and mortality in malignant melanoma. The Cochrane database of systematic reviews. 2019;6(6):Cd012352. PMID: 31157404.31157404
161 Balch CM, Gershenwald JE, Soong SJ, Final version of 2009 AJCC melanoma staging and classification. Journal of clinical oncology: official journal of the American Society of Clinical Oncology. 2009;27(36):6199–206. PMID: 19917835.19917835
162 Schmitd LB, Beesley LJ, Russo N, Redefining Perineural Invasion: Integration of Biology With Clinical Outcome. Neoplasia. 2018;20(7):657–67. PMID: 29800815.29800815
163 Vaidya TS, Mori S, Dusza SW, Appearance-related psychosocial distress following facial skin cancer surgery using the FACE-Q Skin Cancer. Archives of Dermatological Research. 2019;311(9):691–6. PMID: 31338583.31338583
164 García-Montero P, de Gálvez-Aranda MV, Blázquez-Sánchez N, Factors related to the evolution of quality of life in patients with cervicofacial non-melanoma skin cancer. Support Care Cancer. 2021;29(9):5187–95. PMID: 33629186.33629186
165 Arts LPJ, Waalboer-Spuij R, de Roos KP, Health-Related Quality of Life, Satisfaction with Care, and Cosmetic Results in Relation to Treatment among Patients with Keratinocyte Cancer in the Head and Neck Area: Results from the PROFILES Registry. Dermatology. 2020;236(2):133–42. PMID: 31434078.31434078
166 Fontanillas P, Alipanahi B, Furlotte NA, Disease risk scores for skin cancers. Nat Commun. 2021;12(1):160. PMID: 33420020.33420020
167 Khera AV, Chaffin M, Aragam KG, Genome-wide polygenic scores for common diseases identify individuals with risk equivalent to monogenic mutations. Nat Genet. 2018;50(9):1219–24. PMID: 30104762.30104762
168 Chatterjee N, Shi J, García-Closas M. Developing and evaluating polygenic risk prediction models for stratified disease prevention. Nature reviews Genetics. 2016;17(7):392–406. PMID: 27140283.27140283
169 Kaiser I, Pfahlberg AB, Uter W, Risk Prediction Models for Melanoma: A Systematic Review on the Heterogeneity in Model Development and Validation. Int J Environ Res Public Health. 2020;17(21). PMID: 33126677.33126677
170 Vuong K, McGeechan K, Armstrong BK, Risk prediction models for incident primary cutaneous melanoma: a systematic review. JAMA Dermatol. 2014;150(4):434–44. PMID: 24522401.24522401
171 Walter FM, Morris HC, Humphrys E, Effect of adding a diagnostic aid to best practice to manage suspicious pigmented lesions in primary care: randomised controlled trial. BMJ (Clinical research ed) [serial on the Internet]. 2012; 345: Available from: http://europepmc.org/abstract/MED/22763392 https://www.ncbi.nlm.nih.gov/pmc/articles/pmid/22763392/?tool=EBI 10.1136/bmj.e4110 https://europepmc.org/articles/PMC3389518.
172 Harkemanne E, Baeck M, Tromme I. Training general practitioners in melanoma diagnosis: a scoping review of the literature. BMJ open. 2021;11(3):e043926. PMID: 33757946.33757946
173 Dinnes J, Deeks JJ, Chuchu N, Dermoscopy, with and without visual inspection, for diagnosing melanoma in adults. Cochrane Database of Systematic Reviews. 2018;12:CD011902. PMID: 30521682.30521682
174 Grimaldi L, Silvestri A, Brandi C, Digital epiluminescence dermoscopy for pigmented cutaneous lesions, primary care physicians, and telediagnosis: a useful tool? J Plast Reconstr Aesthet Surg. 2009;62(8):1054–8. PMID: 18547883.18547883
175 Dinnes J, Deeks JJ, Saleh D, Reflectance confocal microscopy for diagnosing cutaneous melanoma in adults. Cochrane Database of Systematic Reviews. 2018;12:CD013190. PMID: 30521681.30521681
176 Chuchu N, Dinnes J, Takwoingi Y, Teledermatology for diagnosing skin cancer in adults. Cochrane Database of Systematic Reviews. 2018;12:CD013193. PMID: 30521686.30521686
177 Chuchu N, Takwoingi Y, Dinnes J, Smartphone applications for triaging adults with skin lesions that are suspicious for melanoma. Cochrane Database of Systematic Reviews. 2018;12:CD013192. PMID: 30521685.30521685
178 Davies L, Petitti DB, Martin L, Defining, Estimating, and Communicating Overdiagnosis in Cancer Screening. Annals of internal medicine. 2018;169(1):36–43. PMID: 29946705.29946705
179 Etzioni R, Gulati R, Mallinger L, Influence of study features and methods on overdiagnosis estimates in breast and prostate cancer screening. Annals of internal medicine. 2013;158(11):831–8. PMID: 23732716.23732716
180 Swerlick RA, Chen S. The melanoma epidemic. Is increased surveillance the solution or the problem? Archives of dermatology. 1996;132(8):881–4. PMID: 8712837.8712837
181 Linos E, Swetter SM, Cockburn MG, Increasing Burden of Melanoma in the United States. The Journal of investigative dermatology. 2009;129(7):1666–74. PMID: 19131946.19131946
182 Welch HG, Black WC. Overdiagnosis in Cancer. J Natl Cancer Inst. 2010;102(9):605–13. PMID: 20413742.20413742
183 Welch HG, Mazer BL, Adamson AS. The Rapid Rise in Cutaneous Melanoma Diagnoses. The New England journal of medicine. 2021;384(1):72–9. PMID: 33406334.33406334
184 Muzumdar S, Lin G, Kerr P, Evidence concerning the accusation that melanoma is overdiagnosed. J Am Acad Dermatol. 2021;85(4):841–6. PMID: 34116095.34116095
185 Nelson KC, Swetter SM, Saboda K, Evaluation of the Number-Needed-to-Biopsy Metric for the Diagnosis of Cutaneous Melanoma: A Systematic Review and Meta-analysis. JAMA Dermatology. 2019;10:10. PMID: 31290958.31290958
186 Petty AJ, Ackerson B, Garza R, Meta-analysis of number needed to treat for diagnosis of melanoma by clinical setting. J Am Acad Dermatol. 2020;82(5):1158–65. PMID: 31931085.31931085
187 Glasziou PP, Jones MA, Pathirana T, Estimating the magnitude of cancer overdiagnosis in Australia. Med J Aust. 2020;212(4):163–8. PMID: 31858624.31858624
188 Weinstock MA, Ferris LK, Saul MI, Downstream consequences of melanoma screening in a community practice setting: First results. Cancer. 2016;122(20):3152–6. PMID: 27391802.27391802
189 Alam M, Ibrahim O, Nodzenski M, Adverse events associated with mohs micrographic surgery: multicenter prospective cohort study of 20,821 cases at 23 centers. JAMA Dermatol. 2013;149(12):1378–85. PMID: 24080866.24080866
190 Liu X, Sprengers M, Nelemans PJ, Risk Factors for Surgical Site Infections in Dermatological Surgery. Acta Derm Venereol. 2018;98(2):246–50. PMID: 29136259.29136259
191 Pascual J, Belinchon I, Ramos J. Cutaneous surgery complications in individuals aged 80 and older versus younger than 80 after excision of nonmelanoma skin cancer. Journal of the american geriatrics society [serial on the Internet]. 2015; 63(1): Available from: https://www.cochranelibrary.com/central/doi/10.1002/central/CN-01066755/full.
192 Amici JM, Rogues AM, Lasheras A, A prospective study of the incidence of complications associated with dermatological surgery. Br J Dermatol. 2005;153(5):967–71. PMID: 16225607.16225607
193 Cortinas Saenz M, Saenz Guirado S, Gamez Moreno J, Analysis of results, quality indicators, and postsurgical complications in an outpatient dermatological surgery program. Actas Dermosifiliogr. 2012;103(1):36–43. PMID: 22444505.22444505
194 Vaidya TS, Nehal KS, Rossi AM, Patient-reported adverse effects after facial skin cancer surgery: Long-term data to inform counseling and expectations. Journal of the American Academy of Dermatology. 2019;81(6):1423–5. PMID: 31150707.31150707
195 Newlands C, Currie R, Memon A, Non-melanoma skin cancer: United Kingdom National Multidisciplinary Guidelines. J Laryngol Otol. 2016;130(S2):S125–S32. PMID: 27841126.27841126
196 Love WE, Bernhard JD, Bordeaux JS. Topical imiquimod or fluorouracil therapy for basal and squamous cell carcinoma: a systematic review. Archives of dermatology. 2009;145(12):1431–8. PMID: 20026854.20026854
197 AHFS Patient Medication Information. Fluorouracil Topical. Bethesda, MD: American Society of Health-System Pharmacists, Inc [2022 April 25]. https://medlineplus.gov/druginfo/meds/a605010.html.
198 AHFS Patient Medication Information. Imiquimod Topical. Bethesda, MD: American Society of Health-System Pharmacists, Inc. [2022 April 25]. https://medlineplus.gov/druginfo/meds/a698010.html.
199 Ozog DM, Rkein AM, Fabi SG, Photodynamic Therapy: A Clinical Consensus Guide. Dermatol Surg. 2016;42(7):804–27. PMID: 27336945.27336945
200 American Cancer Society. Radiation Therapy for Melanoma Skin Cancer. American Cancer Society 11/22/2021]. https://www.cancer.org/cancer/melanoma-skin-cancer/treating/radiation-therapy.html#written_by.
201 American Cancer Society. Chemotherapy for Melanoma Skin Cancer. American Cancer Society 11/09/2021]. https://www.cancer.org/cancer/melanoma-skin-cancer/treating/chemotherapy.html.
202 American Cancer Society. Treating Melanoma Skin Cancer. American Cancer Society 10/29/2021]. https://www.cancer.org/cancer/melanoma-skin-cancer/treating.html.
203 Onitilo AA, Wittig JA. Principles of Immunotherapy in Melanoma. The Surgical clinics of North America. 2020;100(1):161–73. PMID: 31753110.31753110
204 Carlos G, Anforth R, Clements A, Cutaneous toxic effects of BRAF inhibitors alone and in combination with MEK inhibitors formetastatic melanoma. JAMA Dermatology. 2015;151(10):1103–9.26200476
205 Abdel-Wahab N, Shah M, Suarez-Almazor ME. Adverse Events Associated with Immune Checkpoint Blockade in Patients with Cancer: A Systematic Review of Case Reports. PLoS One. 2016;11(7):e0160221. PMID: 27472273.27472273
206 SEER*Explorer. Recent Trends in SEER Incidence(2000–2018) and U.S. Mortality(2000–2019). National Cancer Institute 12/03/2021]. https://seer.cancer.gov/explorer/application.html?site=53&data_type=9&graph_type=2&compareBy=rate_type&chk_rate_type_1=1&chk_rate_type_2=2&chk_rate_type_3=3&sex=1&race=1&age_range=1&hdn_stage=101&advopt_precision=1&advopt_show_ci=on&advopt_display=2.
207 SEER. Musculoskeletal System - Summary Staging Guide 2000. 12/01/2021]. https://seer.cancer.gov/tools/ssm/ssm2000/musculoskel.pdf.
208 Dickson PV, Gershenwald JE. Staging and prognosis of cutaneous melanoma. Surg Oncol Clin N Am. 2011;20(1):1–17. PMID: 21111956.21111956
209 Bruckmann NH, Bennedsen SN, Duijf PHG, A functional genetic screen identifies the Mediator complex as essential for SSX2-induced senescence. Cell Death Dis. 2019;10(11):841. PMID: 31695025.31695025
210 Lenzi R, Marchetti M, Muscatello L. Incidental nodal metastasis of differentiated thyroid carcinoma in neck dissection specimens from head and neck cancer patients. J Laryngol Otol. 2017;131(4):368–71. PMID: 28244844.28244844