# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Brandy Peaker, M.D., M.P.H., at the Agency for Healthcare Research and Quality; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Lisa H. Williams, M.D., for content expertise and review of the draft report; Adewole Adamson, M.D., M.P.P., Kiarash Khosrotehrani, M.D., and Martin Weinstock, M.D., Ph.D., who provided expert review of the draft report; the Centers for Disease Control and Prevention for providing federal partner review of our draft report; and Jill Pope, B.A., and Cristian Campillay Madrid, B.A., at the Kaiser Permanente Center for Health Research and Kaiser Permanente Washington Health Research Institute for technical and editorial assistance.