# Chapter 4 Discussion

## Summary of Evidence

We conducted this systematic review to support the USPSTF in updating their 2016 recommendation on skin cancer screening. This review assessed the effectiveness and harms of routine screening with clinician visual skin examination and the associations between screening and stage or thickness at detection and between stage at skin cancer detection and melanoma and all-cause mortality. Since the previous review,^106^ we have included 17 new studies. Among them are two new studies reporting on the national skin cancer screening program in Germany (KQ1);^124^ five new studies comparing stage or lesion thickness at detection between routine skin examination compared to usual care (KQ2);^129,^ ^131–133,^ ^135^ nine new studies assessing the association between stage at skin cancer detection and mortality (KQ4);^139–143,^ ^145–147^ and one new study providing data on the potential psychosocial harms of screening (KQ3).^138^ Overall, our findings align with the results of the 2016 systematic review. A summary of the evidence for each key question is shown in Table 24 and summarized below.

Table 24 Summary of Evidence Table

Key Question | Studies (K); Observations (N); Study Design | Summary of Findings | Consistency and Precision | Overall Strength of Evidence | Body of Evidence Limitations | Applicability
KQ1. What is the effectiveness of routine skin cancer screening with visual skin examination by clinicians in reducing skin cancer morbidity and mortality or all-cause mortality?; KQ1a. Does the effectiveness of screening vary by subgroups? | K=3 (1 good-quality, 2 fair-quality); N: NR in one study; 1,791,615 in the other two studies; Melanoma: K=3 (1 good-quality, 2 fair-quality), n=NR in one study; 1,791,615 in the other two studies; KC: No studies; Nonrandomized study (ecologic) | Melanoma mortality: Based on nonrandomized and ecologic evidence, limited to no mortality benefit to population-based skin cancer screening programs at 4- to 10-year followup compared to no screening; All-cause mortality: No studies; KC: No studies | Melanoma mortality: Consistent, imprecise; KC: NA | Melanoma: Low for limited to no mortality benefit; KC: Insufficient | Ecologic design limits individual level analyses; Little information about clinical, socioeconomic, or behavioral risk factors in included populations; Potential lead time and healthy screenee bias; Use of population statistics for outcome assessment; Trial evidence with mortality outcomes unlikely | European population with universal health insurance and subsidized clinician skin examination. No US data.
KQ2. Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care?; KQ2a. Do rates of earlier skin cancer detection vary by subgroups? | Melanoma: K=6 (1 good-quality, 5 fair-quality), n=2,947,595; KC: K=4 (all fair-quality), n=2,332,128; Skin cancer precursor lesions: K=2 (both fair-quality), n=309,661; Nonrandomized studies | Melanoma: Routine clinician skin examination is not associated with earlier stage at detection of invasive melanoma compared to usual care (2 studies); Inconsistent evidence on whether clinician skin examination is associated with increased detection of in situ melanoma compared to usual care (2 studies); Inconsistent evidence on whether clinician skin examination is associated with increased detection of melanoma at either <1 mm or <2 mm thickness compared to usual care (3 studies); KC: Routine clinician skin examination is not associated with either increased detection or stage at detection of KC (4 studies); Skin cancer precursor lesions: Routine clinician skin examination is not associated with increased detection of skin cancer precursor lesions (actinic keratosis or dysplastic nevi) compared to usual care (2 studies) | Reasonably consistent, imprecise | Melanoma: Moderate for no association between screening and stage at invasive melanoma detection; Low for inconsistent evidence for association between screening and thinner lesions at detection or detection of in situ melanoma; KC: Low for no association between routine clinician skin examination and either KC detection or stage at KC detection; Skin cancer precursor lesions: Low for no association between routine clinician skin examination and precursor lesion detection | Lack of information on clinical, biological, or socioeconomic risk factors in included populations; Heterogeneous comparison groups and screening interventions; Potential for selection bias in screening program participation (both patients and clinicians); Limited data on specific population groups | Five of 6 included conducted outside of the US; The single US study was applicable to US primary care insured populations receiving care in large academic medical centers; Populations predominantly White race or European ancestry
KQ3. What are the harms of skin cancer screening and diagnostic followup?; KQ3a. Do the harms of screening vary by subgroups? | Cosmetic harms K=1 (fair-quality) n=45; Psychological harms K=1 (fair-quality) n=187; KQ3a: No studies included; Nonrandomized studies | Cosmetic harms: 27 patients rated 7% (4 out of 56) of shave biopsy sites having poor cosmetic outcomes at 6-month followup; Psychological harms: US-based study of adults who underwent skin cancer screening by trained primary care providers, participants at 5- and 8-month followup assessment scored within the normal range on measures of anxiety and depression; and reported none to minimal psychological harms of screening | Reasonably consistent, imprecise | Insufficient for minimal persistent harms of screening | Small body of evidence for screened populations; Heterogeneous outcomes | People receiving routine screening in US and Germany
KQ4. What is the association between detection of precancerous lesions or earlier stage skin cancer and morbidity and mortality due to skin cancer or all-cause mortality?; KQ4a. Does this association vary by subgroups? | Melanoma: K=9 (3 good-quality, 6 fair-quality), n=1,326,051^*^; KC: No included studies; Nonrandomized studies | Melanoma mortality: Progression of melanoma stage at detection was strongly, positively associated with increasing risk of melanoma mortality; Compared to in situ melanoma at detection, adjHRs for melanoma mortality were 5.8 (95% CI, 5.3 to 6.3) for localized, 31.5 (95% CI, 28.9 to 34.2) for regional, and 169.6 (95% CI, 154.2 to 186.6) for distant stage in one US study (n=185,219); Melanoma mortality risk is higher among Black, API, AIAN, and Hispanic adults with melanoma AJCC stage I and SEER localized stages compared to White adults at the same stages.; All-cause mortality: Progression of melanoma stage, for both SEER summary stage and AJCC stages, at detection was positively associated with increasing risk of all-cause mortality | Melanoma mortality, all-cause mortality: Reasonably consistent, reasonably precise; KC: NA | Melanoma: High for association between stage at detection and melanoma and all-cause mortality; KC: NA | Generally well-conducted nonrandomized studies of large cancer registry data; Heterogeneous risk measures and choice of referent groups; Primary quality concerns are incompleteness and potential inaccuracy of retrospectively collected data | Populations of the US, Australia, Sweden, and Norway with melanoma diagnosis

* N refers to sum of each individual study population and does not account for overlapping populations (from SEER data, for example).

Abbreviations: AANAPI=Asian American/Native American/Pacific Islander; API=Asian or Pacific Islander; AIAN=American Indian or Alaska Native; Adj=Adjusted; AJCC=American Joint Committee on Cancer; CI=Confidence interval; HR=Hazard ratio; KC=Keratinocyte carcinoma; KQ=Key Question; NR=Not reported; RR=Relative risk; SEER=Surveillance, Epidemiology, and End Results Program; US=United States.

### Melanoma

#### Direct Evidence of Benefits of Clinician Visual Skin Examination

All direct evidence on screening effectiveness comes from nonrandomized analyses of population-based skin cancer screening programs in Germany.^120,^ ^121,^ ^124,^ ^125^ Since the previous review, longer followup data for mortality has been published for the SCREEN skin cancer screening program—a regional pilot screening program included in the previous review—adding non-overlapping national skin cancer mortality data following the introduction of a national skin cancer screening program and one analysis of melanoma mortality using German health insurance claims data.

Population-level mortality statistics alone suggest no melanoma mortality benefit associated with routine skin cancer screening in German regions offering routine screening compared to regions without routine screening programs. Individual-level data available in one included study suggests a potential mortality benefit associated with skin cancer screening in the German program that was attenuated on multivariable analyses and sensitivity analyses to assess lead time bias.^121^ However, despite a well-conducted study, several limitations remain in this observational analysis, including potential healthy screenee bias, lead time bias, and inability to assess overdiagnosis. Limited data on melanoma mortality rates in specific population groups were available. There was some evidence of reduced mortality in screened persons over age 65, in particular, for males. However, these results should be considered hypothesis-generating, given the limitations of the included study designs.

Our findings about the lack of available evidence are consistent with a 2019 Cochrane Collaboration systematic review,^160^ which included only randomized trials of screening in people without suspected melanoma. Primary outcomes were total mortality, melanoma overdiagnosis, quality of life, and psychosocial consequences. The review reported on two trials of skin cancer screening. One trial’s main outcome was increasing skin self-examination, and the other was a pilot study that never led to a randomized trial. Neither study reported on any of the review’s primary outcomes; nor did they report melanoma mortality or other outcomes of interest for our review. Neither study was included in our review.

Our conclusions are limited substantially by the lack of randomized studies and by the limitations of ecologic study designs, including the inability to conduct individual level analyses of screening benefit, such as screening program participation and impacts in specific population groups. Applicability to U.S. settings is difficult to assess, particularly with respect to specific population groups (e.g., race or ethnicity) and health system differences. Thus, we find an overall low strength of evidence for no to limited melanoma mortality benefit.

#### Indirect Evidence on the Potential Benefits of Skin Cancer Screening

Given the lack of direct evidence on the benefits of skin cancer screening, the USPSTF is interested in evidence along the indirect pathway through which skin cancer screening could result in improved mortality and morbidity. This indirect evidence includes two questions: whether visual skin examination by a clinician is associated with thinner lesions or earlier stage at detection compared to usual care, and whether early stage at detection is associated with lower melanoma and all-cause mortality.

##### Association Between Clinician Skin Exam and Lesion Thickness or Stage at Diagnosis

Based on three studies reporting detection of in situ melanoma or stage at invasive melanoma detection and three studies reporting thickness at melanoma detection in screened populations, the body of evidence is inconsistent.

Based on two analyses of German screening program data, there is no evidence of an indirect screening benefit through earlier stage at invasive melanoma detection. The body of evidence is less consistent with respect to in situ melanoma and thickness at melanoma detection. In a study of routine clinician skin examination conducted as part of a U.S.-based clinical decision support initiative, the proportion of in situ melanomas (versus invasive melanoma of any stage) was higher in the group receiving skin examination (48.3% of total melanomas detected in situ in screened group vs. 34.6% in unscreened group, adjHR 2.6 [95% CI, 2.1 to 3.1]; p<0.001).^134^ However, an analysis of German National Screening Program data found similar rates of in situ melanoma detection in both screened and unscreened groups.^133^

Findings also were inconsistent for the association between skin exam and melanoma thickness. Across three studies reporting melanoma detection of lesions <2 mm (AJCC Stage IB–IIA) or <1 mm thickness (AJCC Stage IA and IB), no clear association or estimation of magnitude of effect was apparent. While one Australian study suggested a pattern of thinner melanoma lesions associated with skin examination and, conversely, thicker lesions associated with lack of skin exam; this was not supported in the other two studies, which both found inconsistent evidence between heterogenous thickness categories. Together the three studies do not provide consistent evidence about which thickness categories (e.g., the thinnest lesions) might be associated with a screening benefit.

Several limitations of these studies should be noted. Stage and thickness categories were heterogeneous, limiting pooled analyses and direct comparisons across studies. In addition to small numbers of melanoma cases in several studies, delivery of skin examination varied widely, including community-based skin examination events, a national population screening program, a physician-focused initiative with no patient involvement, and a case control study measuring patient self-report of skin examination. Community-based and physician-focused events, in particular, likely include a mix of lesion-directed (i.e., patient-detected) and asymptomatic population-based screening, which could dilute any association between true population screening and stage or thickness at detection. Further, skin examination in these studies was conducted by a mix of dermatologists and primary care clinicians; as discussed below (see Test Performance Considerations and Potential for Overdiagnosis and Overtreatment) accuracy of clinician visual skin examination appears similar between primary care or specialist clinicians, but the total number needed to biopsy to diagnose one melanoma may be higher compared to dermatologists.

Taken together, the body of evidence on invasive melanoma stage at detection, in situ melanoma at detection, and melanoma thickness at detection offers inconsistent indirect evidence at best of a benefit of visual skin examination through earlier stage at detection or detection of thinner lesions. Given their inconsistency, these findings should not be interpreted as evidence of no benefit, and also should be interpreted in light of the potential for overdiagnosis in skin cancer, particularly for detection of in situ melanoma and melanoma <1 mm in thickness. The overall strength of evidence is low for inconsistent evidence about visual skin examination and detection of thinner melanoma or in situ melanoma at detection.

##### Association Between Stage at Diagnosis and Melanoma or All-Cause Mortality

Our review found across nine nonrandomized studies that there is a strong, consistent positive association between advancing stage at melanoma detection and increasing melanoma mortality and all-cause mortality risk. Specific relative risk estimates varied with the choice of referent group (in situ melanoma versus localized stage at detection), risk measure, adjustment variables, and staging system used (AJCC or SEER summary stage), but the positive relationship was the same across studies. These findings should be viewed as confirmatory of the substantial body of literature establishing stage at melanoma diagnosis—which for early stage primarily refers to lesion thickness—as a primary prognostic indicator of melanoma survival. The AJCC melanoma staging system is updated based on survival analyses of a large (>46,000) international cohort of persons with melanoma,^5,^ ^161^ and reflects clinically relevant categories of lesion thickness, nodal involvement, and metastasis based on their prognostic relationship to melanoma survival considering current treatment options.^5^ Our review adds measures of mortality, rather than relative survival, and limited information on specific population groups. One large U.S.-based study^144^ ^162^ found that melanoma mortality risk was lower for White persons with localized melanoma than for Black, Hispanic, API, and AIAN persons with the same stage. Overall, this body of evidence has a high strength of evidence and underscores the widely accepted and well-studied notion that early detection and treatment of melanoma is associated with improved mortality outcomes.

### Keratinocyte Cancers

No direct evidence was available in the included studies about the benefits of skin cancer screening for keratinocyte cancers of the skin. Four included studies suggest that routine clinician skin examination was not associated with either increased detection or stage at detection of keratinocyte skin cancer (overall strength of evidence is low). No evidence was available in the included studies about the association between stage at KC detection and skin cancer or all-cause mortality.

### Harms of Skin Cancer Screening

Direct evidence on harms of skin cancer screening continues to be sparse. Hypothesized harms from screening include cosmetic harms (e.g., scarring) from diagnostic workup, psychosocial harms (e.g., worry) from the screening process, and overdiagnosis and overtreatment. Based on included evidence from two small studies,^136,^ ^138^ one examining cosmetic harms and the other psychosocial harms from screening, there is little to no evidence of persistent harms associated with screening. These findings are consistent with studies conducted in unscreened populations suggesting minimal persistent patient-reported harms from skin cancer surgery at up to 6 months after surgery.^163–165^ Overall, given the small number of studies focused on screened populations, the included body of evidence is insufficient to fully assess psychosocial or cosmetic harms of skin cancer screening.

Our review found no studies directly examining overdiagnosis or overtreatment harms from skin cancer screening, although this remains a potential harm of skin cancer screening (see Potential for Overdiagnosis and Overtreatment).

## Contextual Considerations

### Risk Assessment Tools in Primary Care

Given the clear link between early detection of melanoma and mortality, identification of individuals at risk of skin cancer could benefit clinical practice through the development of validated risk assessment tools. Multiple risk assessment tools have been developed, typically using established risk factors for melanoma (e.g., fair skin, increased number of nevi, family history of melanoma, polygenic risk). Polygenic risk scores for skin cancer risk prediction may show promise, but these are early in development, and none have been externally validated.^166–168^

A 2020 systematic review aimed to evaluate published risk assessment models for melanoma and concluded that there is a lack of consensus across models, most of which have not been externally validated. There was substantial heterogeneity in risk factor selection, methods, and validation,^169^ prohibiting direct comparisons between models. Only six of 40 included studies validated their findings using external datasets. One study validated their findings using multiple external datasets (Western Australian Melanoma Study, Leeds Melanoma Case-Control Study, the Epigene-QSkin Study, and the Swedish Women’s Lifestyle and Health Cohort Study),^170^ while the other five used a single external data set for validation. This demonstrates a need for more validation studies of existing models, focusing on external validation using multiple data sources, before these models are ready for clinical use.

### Test Performance Considerations

In most cancer screening, a device or test (e.g., mammography) is used to visualize cancers that might not be detected otherwise, and a patient receives diagnostic workup and followup care subsequent to the screening visit. Assessment of test performance is typically limited to the qualities of the device or test. However, clinician visual skin examination uses clinical judgment and is not the only way to visualize concerning lesions, as people can self-examine their own skin. Treatment can often be completed with lesion removal at the time of detection, conflating assessment of the screening and diagnostic workup processes. Thus, traditional measures of test performance (e.g., sensitivity, specificity, false positives) may be less interpretable for skin cancer than with other cancer screening tests. But as an ideal screening test, visual skin examination would accurately identify and triage all malignant lesions and minimize unnecessary biopsy of false positives. Influencing factors might include training or subspecialty of the screening clinician; the use of assistive tools during visual examination (e.g., dermoscopy or confocal microscopy); asynchronous vs. in-person clinician review of lesions; and use of artificial intelligence apps.

#### Primary Care vs. Subspecialist Setting/Screening

Few studies have examined the test accuracy of a visual screening inspection in primary care, and even fewer have examined the accuracy of initial skin examination in persons without self-identified lesions. These studies are often limited by their small size, uncertain or high risk of bias, and low applicability to a general screening population. A 2018 review^113^ conducted by the Cochrane Skin Cancer Diagnostic Test Accuracy Group examined the diagnostic accuracy of visual skin examination for diagnosing cutaneous melanoma. Setting (primary, secondary, specialist) was not associated with statistically significant differences in the accuracy of visual skin inspection and across 39 datasets and various types of skin examinations (i.e., first examination; diagnosis of a previously identified suspicious lesion). Similarly, the relative diagnostic odds ratio of secondary care or a specialist clinic compared to primary care was 1.51 (95% CI, 0.32 to 7.09). The use of a named diagnostic algorithm (e.g., ABCDE) compared with no reported algorithm did not improve accuracy (relative diagnostic odds ratio 1.03 [95% CI, 0.25 to 4.34]).

The 2018 review^113^ identified no studies of true population-based screening with visual exam but did include three studies prospectively recruiting primary care patients seeking review of suspicious lesions (lesion-directed screening). These studies were conducted outside the United States in Italy, England, and Australia. Only one^171^ of the three studies reported patient characteristics; patients were primarily men (64%), White (94%), and aged 45 years or younger (55%). Among these primary care patients with suspicious lesions, there were a total of 1339 lesions and 55 melanomas. Individual study estimates for sensitivity to detect melanoma varied widely (ranging from 0.34 to 1.0). Pooled sensitivity to detect melanoma was high, though this estimate was imprecise (sensitivity 0.924, 95% CI, 0.262 to 0.998). Pooled specificity was 0.797 (95% CI, 0.737 to 0.847), suggesting a potential opportunity for training to improve diagnostic abilities. With these pooled estimates, if a clinician saw 1000 suspicious lesions where 90 were melanoma, 83 would correctly be identified as melanoma (Figure 9). But 185 lesions would incorrectly screen positive and be unnecessarily subject to biopsy.

Figure 9 Pictogram Depicting the Test Performance of Visual Inspection for Hypothetical 1,000 Lesions^113^

Pictogram depicting hypothetical: The pooled sensitivity to detect melanoma was 0.924 (95% CI, 0.262 to 0.998) and specificity was 0.797 (95% CI, 0.737 to 0.847). While the pooled sensitivity for visual inspection is quite high, with only three studies, the estimate was imprecise and individual estimates varied widely (ranging from 0.34 to 1.0). The ideal screening test would maximize sensitivity, identifying all patients with cancer, but also minimize the false positives who would be subject to unnecessary workup. With these pooled estimates, if a physician saw 1,000 suspicious lesions where 90 were melanoma, 83 would correctly be identified as melanoma (Figure). But 185 lesions would incorrectly screen positive and be unnecessarily subject to further workup (i.e., biopsy).

This figure is a pictogram depicting the test performance of visual inspection for diagnosing melanoma in a hypothetical review of 1000 suspicious lesions. The data for this pictogram are from a 2018 Cochrane review by Dinnes et al. that included 3 studies. The pooled sensitivity to detect melanoma was 0.924 (95% CI, 0.262 to 0.998) and specificity was 0.797 (95% CI, 0.737 to 0.847). With these pooled estimates, if a physician saw 1000 suspicious lesions where 90 were melanoma, 83 would correctly be identified as melanoma. However, 185 lesions would incorrectly screen positive and be unnecessarily subject to further work up (i.e. biopsy).

Clinician visual skin examination by either primary care or specialist clinicians can detect and diagnose most melanomas; additional training in melanoma diagnosis may further enhance these skills. A 2021 review of 31 training programs for primary care physicians found that training can improve melanoma diagnosis (e.g., improved confidence, decrease in dermatologist referral for ultimately benign lesions, and improved benign/malignant ratio of referred lesions) although trainees may require refresher or booster training material for a sustained effect.^172^

#### Use of Magnifying Tools During Visual Skin Examination

Magnifying tools, such as dermoscopy or confocal microscopy, might also help improve accuracy further. A related systematic review^173^ found that two of three studies conducted among primary care patients with suspicious lesions also compared visual inspection alone to visual inspection plus dermoscopy. In both studies, visual inspection plus dermoscopy improved the test accuracy to detect melanoma. In one study,^78^ both sensitivity (0.53 vs 0.38) and specificity (0.89 vs 0.85) improved, but the confidence intervals overlapped. In the second study,^174^ sensitivity was the same for both screening approaches (1.0), but specificity was higher when a dermoscope was added (0.90 vs 0.73).

Reflectance confocal microscopy alone or in addition to dermoscopy to detect melanoma and atypical intraepidermal melanocytic variants may further enhance accuracy, but is typically limited to specialty settings.^175^

#### In-Person Screening vs. Asynchronous or Virtual Visual Skin Examination

In-person visual skin examination appears more accurate than asynchronous lesion review. The Cochrane systematic review also examined how in-person visual examination compared to asynchronous clinician review of images. Across 39 datasets, in-person visual examinations (28 datasets) to detect melanomas had much higher accuracy compared to only asynchronous clinician review of clinical images (11 datasets) (relative diagnostic odds ratio 8.54; 95% CI, 2.89 to 25.3).^113^

#### Additional Test Performance Considerations

Teledermatology includes dermatologist examination of digital images asynchronously or via live video consultation and appears to have high sensitivity with mixed specificity. A systematic review^176^ completed by the Cochrane Skin Cancer Diagnostic Test Accuracy Group identified 22 teledermatology test accuracy studies; 16 of these examined test accuracy and six studies examined the referral accuracy. Four studies reported a pooled sensitivity of 0.949 (95% CI, 0.901 to 0.974) and pooled specificity of 0.843 (95% CI, 0.485 to 0.968).

Another related systematic review^177^ examined the accuracy of five different smartphone applications to detect melanoma or atypical intraepidermal melanocytic variants, which could help improve access to dermatology review of patient-identified suspicious lesions. Two studies were identified; one examined the accuracy of an application where a dermatologist assessed the images and three artificial intelligence-based applications and the other study examined one artificial intelligence-based application. Together these studies examined 332 lesions and 86 melanomas. Accuracy of the four AI-based applications varied widely: sensitivity ranged from 0.07 (95% CI, 0.02 to 0.16) to 0.98 (95% CI, 0.90 to 1.00) and specificity from 0.30 (95% CI, 0.22 to 0.40) to 0.94 (95% CI, 0.87 to 0.97). The accuracy of the application storing images to be reviewed by a dermatologist reported a sensitivity of 0.73 (95% CI, 0.52 to 0.88) and a specificity of 0.83 (95% CI, 0.75 to 0.89).

### Potential for Overdiagnosis and Overtreatment

Overdiagnosis generally refers to the detection of a condition that would not have caused illness in the absence of detection. Overdiagnosis in cancer screening is defined as the detection of a (histologically confirmed) cancer through screening that would not otherwise have been diagnosed in a person's lifetime had screening not been done. Overtreatment is a potential consequence of overdiagnosis, and is defined as treatment provided after identification of incidental findings of uncertain significance, overdetection of precancerous lesions, or overdiagnosis or misdiagnosis of cancer and that may not benefit the patient.^178^

Direct measurement of overdiagnosis is not possible but may be explored indirectly using long term trial data or population data. Unexplained increasing excess incidence of skin cancer can indicate the presence of overdiagnosis, though the excess-incidence approach can result in overestimates of overdiagnosis.^178,^ ^179^ Concern about melanoma overdiagnosis was first raised in the 1990s, following observations^16,^ ^180–182^ of a trend that continues divergence between increasing melanoma incidence and a relatively flat melanoma mortality rate. Based on SEER data, in the United States, the annual incidence of melanoma increased from 7.9 to 25.3 per 100,000 individuals between 1975 and 2018, while mortality remained stable (death rates per 100,000 were 2.07 in 1975 and 2.01 in 2018) (Figure 1). Melanomas diagnosed at early stages (in situ and lesions less than <1 mm thickness^183^) are the main contributors to the increased incidence.^19^

Potential explanations of increasing incidence of melanoma include an aging population; increased UV exposure via increased sun exposure and tanning bed behavior; changes in histopathologic criteria that result in higher sensitivity; better reporting of melanoma; and increased diagnostic scrutiny.^183,^ ^184^ Increased diagnostic scrutiny could indicate overdiagnosis, especially in the absence of improved health outcomes, as is demonstrated in the case of melanoma.

Neither the 2016 USPSTF skin cancer screening evidence review,^106^ nor a 2019 review of the effects of skin cancer screening commissioned by the Cochrane collaboration, found trial data on overdiagnosis^160^ associated with patient-, caregiver-, or provider-directed screening. The included studies in our review reveal little new information about potential overdiagnosis, limited to estimates of increased incidence from population data without accompanying evidence of a mortality benefit. After the introduction of the German program in 2008, skin cancer incidence rose sharply for both melanoma and KC (Figures 3, 4, and 10; Appendix E Table 1).^135^ As measured by skin cancer-related hospital discharges as a proxy for incidence, a similar increase did not appear in surrounding European countries during the same period.^124^ This suggests that skin cancer screening could potentially result in overdiagnosis of skin cancer without evidence of improved mortality, but no direct evidence was available.

Figure 10 Melanoma Incidence and Mortality, Overall Population, Schleswig-Holstein vs. Germany, 1998-2013^124^

* Period of active screening

This figure shows trends in melanoma incidence and mortality in the SCREEN pilot project region (Schleswig-Holstein) and Germany as a whole from 1998 to 2013. These data, which also are reported in Table 6 (mortality) and Appendix E Table 1 (incidence), show that melanoma incidence rose sharply for both Schleswig-Holstein and Germany as a whole after the introduction of the German national screening program in 2008. Meanwhile, melanoma mortality remained more stable in both Schleswig-Holstein and Germany as a whole from 1998 to 2013.

Overtreatment of skin cancer could be estimated by measures of unnecessary excisions or lesion removal. One of these measures is the number needed to biopsy (NNB), if a skin lesion is inappropriately classified as malignant and sent to biopsy. This misclassification can be related to clinician training or inappropriate clinical guidelines. For skin cancer, however, interpretation of these measures is complicated since lesion removal, followed by biopsy, can serve as the complete treatment. In a systematic review of 46 studies of 455,496 biopsied tumors and 29,257 biopsied melanomas, the weighted mean number needed to biopsy (NNB) for a diagnosis of cutaneous melanoma was 14.8 (ranging from 2.2–30.5) for any health care providers, 14.6 for Australian primary care practitioners, 13.2 for U.S.-based dermatologists and advanced practice professionals, and 7.5 for dermatologists in all studies (confidence intervals not reported).^185^ In another meta-analysis of 36 observational studies and 398,549 biopsies, the NNB was estimated to be 9.71 (95% CI, 7.72 to 12.29, I^2^=99.7%) across all specialties. The NNB was estimated to be 22.62 (95% CI, 12.95 to 40.10; k=6, I^2^= 99.8%) for primary care practitioners, to be 9.60 (95% CI, 6.97 to 13.41; k=14, I^2^=98.0%) for dermatologists, and to be 5.85 (95% CI, 4.24 to 8.27; k=12, I^2^=97.6%) for dermatologists with a subspecialty in pigmented lesions.^186^ However, the authors acknowledged that specialists may have a lower NNB than primary care providers because specialists see a higher proportion of high-risk patients.^186^

One observational study (not included in our review) used Australian national data to examine excess lifetime risk of melanoma in 2012 compared to 1982 to estimate melanoma overdiagnosis.^187^ The excess incidence approach in this study assumed the same diagnostic intensity in 1982 and 2012. For women, this study found that the absolute lifetime risk of melanoma diagnoses, including in situ, increased by 5.1 percent, and the risk for invasive melanoma increased by 0.7 percent from 1982 to 2012. Among women, the estimated overdiagnosis of melanoma detected at any stage, including in situ, was 53.7 percent (95% CI, 51.3% to 56.1%) with 10,492 cancer diagnoses and 5,634 (95% CI, 5,386 to 5,882) overdiagnosed melanomas in 2012. Overdiagnosis of invasive melanoma was estimated to be 15.2 percent (95% CI, 11.4% to 19.0%) with 5,088 diagnoses and 744 (95% CI, 580 to 968) cases of overdiagnosed melanoma.

Another observational study assessed dermatology visits and skin surgeries among patients of PCPs who did and did not undergo training in diagnosing skin cancer as part of the U.S.-based physician-focused decision support intervention included for KQ2 and KQ3. In the group with the highest percentage of trained providers, there was a 79% increase in melanoma diagnoses (95% confidence interval, 15% to 138%) and no substantial increase in skin surgeries or dermatology visits in any group at 6.5 months follow up.^188^

### Serious Harms of Skin Cancer Treatment

Mohs micrographic surgery is a planned procedure for treatment of skin cancer, particularly KC. It occurs separately from screening and is generally associated with a low risk of serious adverse events. A multicenter prospective cohort study of 23 medical centers found that out of 20,821 Mohs procedures, 179 adverse events were reported, for an adverse event rate of less than 1 percent (0.72%).^189^ Serious harms that have been reported due to Mohs procedures and wide local excision include infection, functional loss, and superficial skin necrosis.^189,^ ^190^ Serious harms from other surgical treatments such as excision, and electrodesiccation and curettage are rare, but include scarring or disfigurement, nerve damage, persistent pain or sensitivity at the surgical site, and infection.^191–194^

Topical treatments, such as 5-flurouracil and imiquimod creams, are commonly used to treat superficial KC or actinic keratosis when surgical excision is not optimal or desired by the patient.^79,^ ^195^ Serious harms from these treatments include severe stomach pain, vomiting, and blistering of the treated skin, as well as burning, crusting, erythema, permanent hypopigmentation, erosion, rash, and pain at the treatment site.^196–198^ These effects have been reported to peak at approximately 6 weeks of treatment but can persist up to 2 years.^196^ Additionally, flu-like symptoms such as nausea, fever, fatigue, and muscle weakness have been associated with both treatments. Photodynamic therapy (i.e., a combined use of a drug [photosensitizing agent] along with the light) is mainly used to treat superficial KC. Serious side effects from this therapy are extremely rare.^199^

Serious harms from radiation therapy and chemotherapy have been well documented, and include hair loss, permanent pigment changes, dermal fibrosis, peripheral neuropathy, and memory loss.^79,^ ^85,^ ^200–203^ These conditions typically resolve once treatment is completed; however, some patients may continue to experience lasting effects.

Serious side effects of immunotherapies have been reported in approximately 10 to 55 percent of patients.^84,^ ^203^ For immune checkpoint inhibitors these include dermatitis, colitis, pruritus, vitiligo, skin eruptions, extreme fatigue, the aggravation of existing autoimmune conditions, and in rare instances, death.^79,^ ^84,^ ^85,^ ^203^ Reported side effects from BRAF/MAPK inhibitors include severe ultraviolet A-induced photosensitivity, painful palmoplantar keratosis, hair loss, thickening of the skin of the palms/feet, the development of cutaneous SCC, and dermatitis.^79,^ ^204^ More than 90 percent of those on BRAF monotherapies experience adverse events and approximately 40 percent of those on checkpoint inhibitors will experience autoimmune skin conditions.^79^ Approximately 25 percent of patients experience persistent symptoms.^204,^ ^205^ Reported adverse events associated with treatment with TVEC include nausea, fatigue, flu-like illness, and cellulitis.^84^ Immunotherapy treatment, used in combination or alongside more traditional therapies, continues to be the focus of active research.

## Ongoing Trials

According to ClinicalTrials.gov, as of April 2022, six trials relevant to skin cancer screening in adults are ongoing. However, none of these trials evaluate the benefits and harms of population-based skin cancer screening (Appendix F).

## Limitations of Approach

This review focuses on the benefits and harms of routine clinician visual skin examination in adolescents and adults without self-identified skin lesions of concern. Preventive counseling to encourage sun protection behaviors and patient or partner skin self-examination are not included here and are addressed in another USPSTF recommendation statement.^99^ Similarly, clinician review of patient-identified concerning skin lesions (frequently called “screening” in the literature) was out of scope. To provide the best available evidence on skin cancer screening effectiveness, we included ecologic study designs, which have inherent limitations that would likely not be included in the presence of more robust study designs. Further, we excluded screening programs that did not primarily include clinician skin examination, limiting our ability to comment on technology-based forms of skin examination.

Our review is limited to harms explicitly related to screening, biopsy, or excision in screened populations, and may have missed relevant data in other populations (e.g., persons seeking diagnostic workup of suspicious lesions). This may have narrowly limited the assessment of cosmetic harms of shave biopsy/diagnostic workup. Further, we limited our review to studies of persistent harms beyond 30 days, which precludes our ability to comment on patient-reported harms before, during, and immediately after screening.

We limited our assessment of the association between stage at detection and health outcomes to mortality outcomes, excluding relative survival outcomes (e.g., 5-year survival). This focused our review on the health outcomes important to the USPSTF, but in so doing we may have missed relevant information, particularly on survival outcomes in specific population groups.

Test performance considerations and potential overdiagnosis related to skin cancer screening are considered contextually in this review, not through systematically reviewed key questions.

## Limitations of the Literature

The lack of direct individual-level or trial data on the effectiveness of skin cancer screening is a primary limitation of the literature. Since no national organizations recommend routine skin cancer screening by clinicians, and since large trials of skin cancer screening may not be feasible and none are underway, the included evidence from Germany currently represents the best evidence available. Little data on specific population groups was available and may represent a missed opportunity to provide evidence about risk-based skin cancer screening approaches. There was very limited information about the effectiveness and harms of screening for keratinocyte cancers. This is not surprising, since keratinocyte cancers are not reportable diseases to cancer registries.

Included studies of the association of stage at detection and skin cancer mortality tended to use summary stage categories rather than the AJCC staging system, limiting assessment of substages, particularly lesion thickness, in early-stage melanoma. Included studies of the association between clinician skin exam and earlier detection of skin cancers described heterogeneous settings, skin examination procedures, and comparison groups.

## Future Research Needs

The highest quality evidence for direct effectiveness of skin cancer screening would come from randomized controlled trials. However, these trials may not be feasible. The body of evidence from non-randomized studies would be strengthened by data on benefits and harms of risk-based screening in specific population subgroups based on known risk factors such as age, sex, skin type, UV exposure, or groups stratified using validated risk assessment tools; data on screening benefits and harms for specific melanoma subtypes; and by individual-level analyses of mortality outcomes in persons with screen-detected melanoma compared to those with melanoma detected through usual care or lesion-directed examination. Evidence on potential overdiagnosis and subsequent overtreatment of early-stage skin cancer would also be beneficial.

## Conclusion

A substantial observational evidence base suggests a clear association between earlier stage at skin cancer detection and decreased mortality risk. However, nonrandomized studies suggest no melanoma mortality benefit associated with skin cancer screening in adolescents or adults in regions with implemented routine screening compared to regions without routine screening, and limited evidence for potential benefit from one nonrandomized study. Nonrandomized evidence suggests no association between routine clinician skin examination and earlier stage at melanoma detection; evidence is inconsistent on whether clinician skin examination is associated with thinner melanoma lesions at detection. There is little direct evidence on harms of screening, however; other than overdiagnosis and overtreatment, there are few hypothesized persistent serious harms.