# Chapter 3 Results

## Literature Search

We reviewed 20,320 abstracts and assessed 522 full-text articles for inclusion (Appendix A Figure 1). For KQ1, we included three studies (10 articles);^104,^ ^120–128^ for KQ2, we included six studies (7 articles);^129–135^ KQ3 was comprised of two studies (3 articles);^136–138^ and KQ4 included nine studies (9 articles).^139–147^

Seventeen studies were newly identified in this update.^121,^ ^124,^ ^130,^ ^132–135,^ ^138–147^

A list of included studies and a list of excluded studies with reasons for exclusion are available in Appendix C and Appendix D, respectively. We determined all included studies were of fair or good quality (Appendix A Table 2).

## KQ1. What Is the Effectiveness of Routine Skin Cancer Screening With Visual Skin Examination by Clinicians in Reducing Skin Cancer Morbidity and Mortality or All-Cause Mortality? Does the Effectiveness of Screening Vary by Subgroups (e.g., Age, Sex, Skin Type, Race/Ethnicity, Socioeconomic Status, or UV Exposure)?

### Summary of Results

Based on ecologic data and non-randomized study data from three evaluations of two related screening programs in Germany, the included evidence (both screening programs rated fair quality) does not suggest a melanoma mortality benefit at the population level over 4 to 10 years’ followup after screening (n=NR in one study; 1,791,615 in the other two). At ten-year followup of the Skin Cancer Research to Provide Evidence for Effectiveness of Screening in Northern Germany (SCREEN) pilot, melanoma mortality in the SCREEN region compared to the rest of Germany does not support an ongoing mortality benefit to routine skin cancer screening.^125^ Similarly, at 5-year followup of the German National Screening Program, no mortality benefit was observed based on national population statistics. Rather, increases in mortality, not decreases, were observed for multiple European countries, including Germany.^124^

One non-randomized study (n=1,431,327) of melanoma mortality in individuals with documented skin cancer screening provided through German statutory health insurance found an absolute decrease in mortality suggesting a screening benefit at four-year followup, but this difference was attenuated on multivariate analysis and adjustment for lead time bias.^121^ No included studies reported all-cause mortality, SCC mortality, BCC mortality, or skin cancer morbidity.

Three included publications from the two German screening programs reported age- and sex-specific melanoma mortality. Similar to the results reported in the main study populations, across these analyses, there was no evidence of a melanoma mortality benefit to screening at the population level.

### Detailed Results

#### Overview of Included Studies

Publications using data from two population-based screening programs in Germany met inclusion criteria (Tables 3 and 4). The first fair-quality study, also included in the previous review, was the SCREEN skin cancer screening pilot, which was conducted in the Schleswig-Holstein state in northern Germany from 2003–2004 (n=360,288 screened). Ten-year followup data on melanoma mortality from this program is included in this report.^125^ The second screening program is the German national skin cancer screening program, implemented in 2008, which includes skin cancer screening covered through statutory health insurance following the promising 5-year mortality data observed in the SCREEN program.^126^ One evaluation used a nonrandomized design (n=1,431,327) to examine administrative data from a German health insurance company with documented skin cancer screening as provided through the German skin cancer screening program.^121^ Another evaluation (2 publications) reporting melanoma mortality rates in Germany and surrounding countries during the first 5 years of the screening program, which included approximately 3 million screened individuals, also met inclusion criteria. ^120,^ ^124^ All but one included publication used ecologic analyses to examine melanoma mortality rates in screened geographic areas compared to areas without population screening programs.

Table 3. Study Characteristics of Included Studies (KQs 1–3)

Key Question | Author, Year Study or Program Name Quality | Country | N | Study Design | Intended screening population | Length of Followup
KQ1: What is the effectiveness of routine skin cancer screening with visual skin examination by clinicians in reducing skin cancer morbidity and mortality or all-cause mortality? | Datzmann, 2022^121^; German national skin cancer screening program; Good | Germany | 1,431,327 | Nonrandomized study | Adults age 35 and older who were enrolled in AOK PLUS (a statutory health insurer in Saxony, Germany) between 2010 and 2016 | 4 years
KQ1: What is the effectiveness of routine skin cancer screening with visual skin examination by clinicians in reducing skin cancer morbidity and mortality or all-cause mortality? | Kaiser, 2018^124^; Boniol, 2015^120^; German national skin cancer screening program; Fair | Germany | NR | Nonrandomized study (Ecologic) | Enrollees in German statutory health insurance (90% of German population) Age 35 years and over | Kaiser 2000–2013; Boniol 1980–2012
KQ1: What is the effectiveness of routine skin cancer screening with visual skin examination by clinicians in reducing skin cancer morbidity and mortality or all-cause mortality? | Katalinic, 2015^104,^ ^122,^ ^125,^ ^126,^ ^128^; Skin Cancer Research to Provide Evidence for Effectiveness of Screening in Northern Germany (SCREEN); Fair | Germany | 360,288 screened | Nonrandomized study (Ecologic) | Resident of Schleswig-Holstein region; age 20 or older; insured with German statutory health insurance | Katalinic 2012^126^: 1998–2009; Katalinic 2015^125^: 1998–2013; Eisemann 2018^122^: 2003–2008
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care (e.g., lesion-directed skin examination)? | Krensel, 2020^133^; German National Screening Program; Fair | Germany | Total study population=NR; Total skin cancer cases included for KQ2 analysis=12,082 | Nonrandomized study | All enrollees in Barmer (a provider of national statutory health insurance) who were age 35 years and older with an incident diagnosis of cutaneous melanoma, nonmelanoma skin cancer, and preliminary stages of skin cancer. | 2013–2016 Eligible participants had to have continuous enrollment from 8 quarters before (preobservation period) until 4 quarters after (followup period) incident diagnosis.
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care (e.g., lesion-directed skin examination)? | Matsumoto, 2022^131,^ ^134^; INFORMED (INternet curriculum FOR Melanoma Early Detection); Good | US | Total study population=595,799; Total skin cancer cases included for KQ2 analysis=994 | Nonrandomized study | Patients age 35 and older who saw a UPMC-employed primary care physician for an office visit from 2014 to 2018. Patients were considered “screened” if they had a documented full body skin examination by a PCP or skin cancer screening visit with a clinician during the study period. | Median 3 years
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care (e.g., lesion-directed skin examination)? | Hoorens, 2016^132^; Fair | Belgium | Total study population=1,982; Total skin cancer cases included for KQ2 analysis=47 | Nonrandomized study | Residents of two communities (Wichelen and Nevele) in East Flanders, Belgium, age 18 and older | NR (appears to be immediately after screening, 2014)
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care (e.g., lesion-directed skin examination)? | Trautmann, 2016^135^; German National Screening Program; Fair | Germany (Saxony) | Total study population=2,022,467; Total skin cancer cases included for KQ2 analyses=34,295 | Nonrandomized study | All persons insured by AOK PLUS (a provider of national statutory health insurance) with incident melanoma or nonmelanoma skin cancer | NR (used administrative healthcare data from 2005–2012)
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care (e.g., lesion-directed skin examination)? | Cristofolini, 2015^130^; Fair | Italy | Total study population=307,679; Total skin cancer cases included for KQ2 analyses=1,390^*^ | Nonrandomized study | All residents of Trento province (comparison group) as well as all residents who participated in free whole-body skin examination of pigmented lesions offered by Trento branch of the Italian League Against Cancer (screening group) | Median 10 years
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care (e.g., lesion-directed skin examination)? | Aitken, 2010^129^; Fair | Australia | Total study population=7,586; Total skin cancer cases included for KQ2 analyses=3,762 | Nonrandomized study | Queensland residents age 20–75 diagnosed with histologically confirmed first primary invasive cutaneous melanoma between January 1, 2000, and December 31, 2003 | 3 years
KQ3: What are the harms of skin cancer screening and diagnostic followup? | Risica, 2018^137,^ ^138^; Fair | US | 187 | Nonrandomized study | UPMC patients that completed a mailed survey who were ≥35 years of age and were indicated in the EMR of having a visit where a skin cancer screen was done in two selected PCP practices | 8 months
KQ3: What are the harms of skin cancer screening and diagnostic followup? | Gambichler, 2000^136^; Fair | Germany | 45 | Nonrandomized study | Patient undergoing routine skin cancer screening in the outpatient setting with macular melanocytic nevi of less than 15 mm | 6 months

* Number of keratinocyte cancers not reported for comparison group of Trento population.

Abbreviations: KQ=Key question; mm=millimeter; NR=Not reported; PCP=Primary care provider; UPMC=University of Pittsburgh Medical Center; EMR=electronic medical record; US=United States.

Table 4. Intervention Characteristics, Included Studies (KQs 1–3)

Key Question | Author, Year Study Name Quality | Country | Providers Conducting Screening | Screening Intervention Description | Comparison Group Description | Frequency of Screening | Followup Protocol of Identified Lesions
KQ1: What is the effectiveness of routine skin cancer screening with visual skin examination by clinicians in reducing skin cancer morbidity and mortality or all-cause mortality? | Datzmann, 2022^121^; German national skin cancer screening program; Good | Germany | Primary care physician or dermatologist | Whole body skin examination included examination of the entire body surface and all visible mucous membranes (oral, genital, and anal).^149^ Adults age ≥35 years enrolled in German statutory health insurance are eligible for asymptomatic screening. Program began 2008. | Enrollees with first-onset melanoma diagnosed 2013–2016 who did not participate in the screening program | Once every 2 years | Primary care–identified lesions referred to dermatology; Dermatologist-identified lesions followed up by identifying dermatologist^149^
KQ1: What is the effectiveness of routine skin cancer screening with visual skin examination by clinicians in reducing skin cancer morbidity and mortality or all-cause mortality? | Kaiser, 2018^124^; Boniol, 2015^120^; German national skin cancer screening program; Fair | Germany | Primary care physician or dermatologist | Whole body skin examination included examination of the entire body surface and all visible mucous membranes (oral, genital, and anal).^149^ Screening was free of charge to screenees as part of German statutory health insurance. Program began 2008.; Enrollees encouraged to have suspicious lesions checked as early as possible. | No comparison group established by screening program. Ecologic comparisons:; Other European countries (22 countries)^*^,^124^; Surrounding countries (8 countries)^†^,^120^ | Once every 2 years | Primary care– identified lesions referred to dermatology; Dermatologist-identified lesions followed up by identifying dermatologist^149^
KQ1: What is the effectiveness of routine skin cancer screening with visual skin examination by clinicians in reducing skin cancer morbidity and mortality or all-cause mortality? | Katalinic, 2015^104,^ ^122,^ ^125,^ ^126^; Skin Cancer Research to Provide Evidence for Effectiveness of Screening in Northern Germany (SCREEN); Fair | Germany | Dermatologists and non-dermatologists | Pilot study in a single state (Schleswig-Holstein) 2003–2004. Components:; 1) training nondermatologists and dermatologists in skin cancer screening; 2) media campaign to encourage skin cancer screening in adults age 20 years and older; 3) full body skin examination | Germany (including SH region),^104,^ ^122,^ ^125,^ ^126^ Germany (excluding intervention region),^122^ Saarland region, Germany,^126^ Four adjoining regions to intervention region^‡^,^126^ | Single screening | Referred to dermatologist
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care? | Krensel, 2020^133^; German National Screening Program; Fair | Germany | NR | Routine skin cancer screening per German national screening program guidance within any quarter of the year in which the excision took place^*^ | No documentation of routine skin cancer screening within any quarter of year in which excision took place | NR | Biopsy or excision to verify diagnoses
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care? | Matsumoto, 2022^131,^ ^134^; INFORMED (INternet curriculum FOR Melanoma Early Detection); Good | US | Primary care physician | Electronic health record was modified to include full-body skin examination as a preventive service recommendation for patients age 35 years and older; program promoted by health system leadership to primary care physicians; physician training via validated web-based skin cancer identification training tool Years: 2014–2018 | Did not receive screening during study period (2014–2018) | NR | Biopsy or referral to dermatologist for further evaluation through routine standard- of-care practice
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care? | Hoorens, 2016^132^; Fair | Belgium | Dermatologist | Total body screening residents received personal invite to 5-day TBE event held in 2014.; Lesion-directed screening residents received personal invite to 4-day event offering review of suspicious lesions.; For both groups, screening was performed by trained physicians using both naked-eye inspection and dermoscopy.; For lesion-directed screening group, a total body examination was offered to all participants at the end of the lesion screening. | Lesion-directed screening using visual inspection and dermoscopy followed by optional total body examination | Single screening | In the case of a suspicious lesion, a second opinion was obtained. Suspicious lesions were photographed, and the patient received a referral letter for their PCP or dermatologist
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care? | Trautmann, 2016^135^; German National Screening Program; Fair | Germany (Saxony) | PCP and dermatologists | Evidence in administrative data of routine skin cancer screening per German national screening program guidance^‖^ | Comparison group consisted of persons without documentation of skin cancer screening | NR | NR
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care? | Cristofolini, 2015^130^; Fair | Italy | Dermatologist | Public awareness campaign offering education about skin cancer and free whole-body skin examinations. Whole-body skin examinations involved the following: patients undressed and had all skin examined by the same trained dermatologist, with a dermatoscopic check of lesions. Patients with suspect lesions were sent to surgery for excision and histological examination. Dates of screening Jan 2001–December 2004, program sponsored by nonprofit cancer prevention advocacy group. | General population of Trento, Italy | NR | Sent to surgery for excision and histological examination
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care? | Aitken, 2010^129^; Fair | Australia | Physician (not further specified) | Clinical skin examination was determined retrospectively by asking: ‘‘During the last 3 years before [you first believed something was wrong (cases)/reference date (controls)], had a doctor deliberately checked all or nearly all of your whole body for early signs of skin cancer?’’ For cases, this clinical skin examination did not include the initial examination by a doctor as part of the diagnostic process, unless this was a whole-body clinical skin examination of an asymptomatic patient (i.e., a skin screening examination) | Control group also asked about receipt of clinical skin examination in 3 years prior to reference date | NR | NA
KQ3: What are the harms of skin cancer screening and diagnostic followup? | Risica, 2018^137,^ ^138^; Fair | US | Primary care physician | Full-body visual skin examination by a UPMC PCP.; UPMC melanoma screening program background: UPMC PCPs were invited to take part of the Internal Curriculum for Melanoma Early Detection (INFORMED) online training program to improve early detection of melanoma and keratinocyte carcinomas. INFORMED is a validated web-based training for detection of skin cancers, particularly melanoma. "Thoroughly screened" patients are those who self-reported being screened and being completely undressed (“with or without undergarments") and had at least 2 of 3 body parts (back, abdomen, calves) examined. | “Not thoroughly screened” patients were those who did not indicate having whole body screened for skin cancer, did not disrobe, or have 2 of 3 body parts examined | Single screening | Some patients reported undergoing skin biopsies following screening
KQ3: What are the harms of skin cancer screening and diagnostic followup? | Gambichler, 2000^136^; Fair | Germany | NR | Routine skin cancer screening in the outpatient setting | NR | NR | NR

* Austria, Belgium, Bulgaria, Switzerland, Czech Republic, Denmark, Spain, Finland, France, Croatia, Hungary, Ireland, Italy, Netherlands, Norway, Poland, Portugal, Romania, Sweden, Slovenia, and Slovakia.

† Czech Republic, Poland, Denmark, Austria, Belgium, France, The Netherlands, and Switzerland.

‡ Denmark; German federal states of Mecklenburg-Vorpommern, Hamburg, and Lower Saxony.

‖ AOK PLUS covers 51% of inhabitants in the German state of Saxony.

Abbreviations: EHR=Electronic health record; KQ=Key question; NR=Not reported; PCP=Primary care physician; UPMC=University of Pittsburgh Medical Center; US=United States.

Subgroup data (KQ1a) on melanoma mortality by age and sex is provided for both Germany and for the SCREEN program. One study analyzed the annual percent change (APC) in melanoma mortality by sex and age in Germany compared to eight other European countries in order to estimate the impact of the German skin cancer screening program on melanoma mortality by age and sex subgroups.^120^

#### Summary of Included Screening Programs

##### SCREEN (Germany) (2003–2004)^104,^ ^122,^ ^125,^ ^126,^ ^128^

The SCREEN study was conducted to determine the feasibility of a population-based skin cancer screening program in the German primary care health system^104^ (Table 4). In 2001, pilot intervention activities occurred on a small scale with 200 physicians and 6,000 screened patients in the Schleswig-Holstein state of northern Germany. Between 2003 and 2004, following the pilot, the SCREEN project implemented population-based skin cancer screening in Schleswig-Holstein. All residents aged 20 years or more and insured with national statutory health insurance were eligible to participate. The screening program included three main components:

1. [underlined: Provider education and training]. In 2003, nondermatologists (general practitioners in primary care, obstetricians and gynecologists, and urologists; n=1,673) and dermatologists (n=116) participated in an 8-hour training course focused on detecting skin cancer. Content included training in the epidemiology and etiology of skin cancer, training and practice in standardized whole body visual examination, strategies for actively recruiting patients for screening, and program documentation and referral procedures.^104^ Training participation rates were 64 percent for nondermatology providers and 98 percent for dermatologists in the region.
2. [underlined: Public outreach]. An outreach campaign encouraged residents of Schleswig-Holstein aged 20 years and older to seek skin cancer screening by a nondermatology physician through the program. Communication channels included health insurers, physicians, and print, digital, and telephone mass media campaigns.
3. [underlined: Clinician skin exam]. Screening exams were conducted from July 2003 to June 2004 via whole-body visual skin exam conducted by a nondermatology provider, although dermatologists also participated in the program and conducted initial screenings. Suspicious lesions were either referred to dermatology or handled by the screening dermatologist. Physicians were reimbursed about $20 USD per screening exam. All tentative clinical diagnoses were followed by biopsy and histopathologic evaluation. Approximately three quarters (77.4%) of screening exams were conducted by nondermatology providers, and 22.6 percent were conducted by dermatologists. Among the 73,710 individuals referred to dermatology after screening by nondermatology providers, 36.8 percent were lost to followup and did not see a dermatology provider for a second clinical exam.^104^ All confirmed skin cancers were reported to the state tumor registry.

##### German National Screening Program (2008–2013)^120,^ ^124,^ ^135,^ ^148,^ ^149^

Following the completion of the SCREEN study,^126^ Germany implemented a nationwide routine skin cancer screening covered by statutory health insurance (Table 4). The implementation was not designed as a research study and did not include a comparison group; though a 5-year evaluation was required.^149^ Screening included a total skin exam by either a participating primary care clinician or a participating dermatologist. Participating providers completed a standardized 8-hour training program similar to that used in the SCREEN study. Topics included benefits and risks of early screening; etiology of skin cancer and risk factors; training in implementing the screening program; patient communication; and discussion of case examples.^123,^ ^150^ Screening included a visual examination of all visible skin and mucous membranes (oral, vaginal, anal) and was offered free of charge to all enrollees aged 35 years or older. Screening physicians were reimbursed for screenings.^149^ During 2008–2009, screenings were conducted approximately equally by general practitioners or dermatologists.^148^

In Germany, health insurance is mandatory, and the administration of health insurance is implemented by non-governmental insurance companies.^151^ Documentation of clinician skin cancer screening, a reimbursable service for clinicians, is noted in individual health records through billing codes.

#### Population Summary

##### SCREEN Program

Of a total population of 2.8 million in the Schleswig-Holstein region, 1.9 million individuals aged 20 years and older comprised the eligible screening population (Table 5). During the project period, 360,288 people received clinician visual skin exams, representing 19.1 percent of the eligible population in the region. Screening participation rates varied by age, with 20 to 22 percent of adults aged 35 to 69 years participating in screening compared with 14.9 percent of adults over age 70 years.

Table 5 Population Characteristics, Included Studies (KQs 1–4)

Key Question | Author, Year Study Name Quality | Country | N | Population Description | Mean Age, yrs | Female, % | Race/ Ethnicity, % | Hx of Previous SC Screening, n (%) | Family History of Skin Cancer, n (%) Previous Skin Cancer, n (%) | Other Risk Factors
KQ1: What is the effectiveness of routine skin cancer screening with visual skin examination by clinicians in reducing skin cancer morbidity and mortality or all-cause mortality? | Datzmann, 2022^121^; German national skin cancer screening program; Good | Germany | 1,431,327 | Adults age 35 years and older who were enrolled in AOK PLUS (a statutory health insurer in Saxony, Germany) between 2010 and 2016 | 63.9 | 55.7 | NR | NR | NR; Melanoma in previous 3 years: 0 (0%); Other previous melanoma or KC: NR | NR
KQ1: What is the effectiveness of routine skin cancer screening with visual skin examination by clinicians in reducing skin cancer morbidity and mortality or all-cause mortality? | Kaiser, 2018^120,^ ^124^; German national skin cancer screening program; Fair | Germany | NR | National statutory health insurance enrollees (90% of German population) Excluding residents of Schleswig-Holstein region Age 35 years and older | Percent of population age ≥65:; Screening group: mean 19.4, SD 2.2; Comparison group (Europe): mean 17.4, SD 3.1 | Ratio of males to females: 0.96, SD 0.01 | NR | NR | NR | Medical doctor density per 100,000 inhabitants: Screening group: mean 366.41, SD 63.35; Comparison group (Europe): mean 366.16, SD 109.08; GDP per capita (Euros):; Screening group: mean 28,269.05. SD 8834.7; Comparison group (Europe): mean 23,585.02, SD 10,090.5; Percent with tertiary education^§^: Screening group: Mean 26.18, SD 4.57; Comparison group (Europe): Mean 20.83, SD 8.35 Employment rates (%): Screening group: 74.84, SD 3.65; Comparison group (Europe): 68.63, SD 6.26
KQ1: What is the effectiveness of routine skin cancer screening with visual skin examination by clinicians in reducing skin cancer morbidity and mortality or all-cause mortality? | Katalinic, 2015^104,^ ^122,^ ^125,^ ^126^; Skin Cancer Research to Provide Evidence for Effectiveness of Screening in Northern Germany (SCREEN); Fair | Germany | 360,288 screened | Residents of Schleswig-Holstein region; age 20 years or older; insured with German statutory health insurance | 49.7 | 73.6 | NR | NR | First-degree relative with malignant melanoma: 3,831 (6.1); Personal history of malignant melanoma: 1,642 (2.6); Personal history of KC: 4,063 (16.9) | Actinic keratosis, n (%): 7,490 (31.2); Multiple melanocytic nevi, n (%): 35,160 (56.2); Clinically atypical nevi, n (%): 32,468 (51.9); Congenital moles, n (%): 13,071 (20.9); UV-damaged skin, n (%): 17,301 (72.0); X-ray damaged skin n (%): 638 (2.6); Immunosuppression: n (%): 658 (2.7)
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care? | Aitken, 2010^129^; Fair | Australia | Total study population=7,586; Total skin cancer cases included for KQ2 analyses=3,762 | Queensland residents age 20–75 years diagnosed with histologically confirmed first primary invasive cutaneous melanoma (not including acral lentiginous melanoma) between Jan 1, 2000 and Dec 31, 2003 | Overall NR; 20–39: 16.4% 40–49:20.4% 50–59:26.2% 60+: 37.0% | 42.4 | UK: 67.3; European: 9.3; Other: 23.2 | 28.3% reported having had a clinical skin examination within 3 years before reference date; 35.3% reported having had a clinical skin examination within 3 years before melanoma first noticed | Family Hx of melanoma^†^: 553 (14.5%); Family Hx of KC^†^: 826 (21.6%); Previous diagnosis of KC^*^,^†^: 734 (19.2) | NR
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care? | Cristofolini, 2015^130^; Fair | Italy | Total study population=307,679; Total skin cancer cases included for KQ2 analyses=1,390^††^ | Residents of Trento, Italy, who participated in free whole-body skin screening program between Jan 2001 and Dec 2004 | 40.2 | 52.6 | NR | NR | NR | NR
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care? | Matsumoto, 2022^131,^ ^134^; INFORMED (INternet curriculum FOR Melanoma Early Detection); Good | US | Total study population=595,799; Total skin cancer cases included for KQ2 analysis=994 | Patients age 35 years and older who saw a UPMC-employed primary care physician for an office visit from 2014–2018 | 57 | 55.9 | Non-Hispanic White: 84.0 White, ethnicity unknown: 3.9 Hispanic White: 0.5 Black: 7.9 Asian: 1.5 AIAN: 0.1 Pacific Islander: 0.04 Not reported: 2.0 | NR | NR | NR
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care? | Hoorens, 2016^132^; Fair | Belgium | Total study population=1,982; Total skin cancer cases included for KQ2 analysis=47 | Residents of two communities (Wichelen and Nevele) in East Flanders, Belgium, age 18 years and older | 51.5 | 56.2 | NR | At least 1 previous skin check: 38.2% | Family Hx of SC: 220 (11.1); Personal Hx of SC: 46 (2.3) | N (%) Presence of actinic keratosis: 152 (7.8); Solar lentigines: 1,264 (65.3); Atypical nevi: 298 (15.4)
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care? | Krensel, 2020^133^; Fair | Germany | Total study population=NR; Total skin cancer cases included for KQ2 analysis=12,380 | Enrollees in health insurance company; age 35 years and older with incident diagnosis of cutaneous melanoma, KC, and preliminary stages of skin cancer who had undergone routine skin cancer screening within the quarter of the year in which the excision took place or the previous quarter | 69.0 | 56.4 | NR | NR | NR | NR
KQ2: Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care? | Trautmann, 2016^135^; German National Screening Program; Fair | Germany | Total study population = 2,022,467; Total skin cancer cases included for KQ2 analyses=34,295 | All persons continuously insured by AOK PLUS from Jan 1, 2005, to Dec 31, 2012, or death. AOK PLUS is a large German health insurance company covering 51% of inhabitants of the German state of Saxony. | 46.5 | 53.6 | NR | NR | NR | NR
KQ3: What are the harms of skin cancer screening and diagnostic followup? | Gambichler, 2000^136^; Fair | Germany | 45 | Individuals aged 15–54 years, from the outpatient setting who underwent routine skin cancer screening who were prospectively recruited after clinical and epiluminescence microscopic investigation. Only those with macular melanocytic nevi with diameter of less than 15 mm were included. | 32 | 51.0 | NR | NR | NR | NR
KQ3: What are the harms of skin cancer screening and diagnostic followup? | Risica, 2018^137,^ ^138^; Fair | US | 187 | UPMC: ≥35 years of age; having documentation of a visit where a skin cancer screen was done in two selected PCP practices | NR | 42.8 | White: 89.8 Black: 5.3 Other: 4.8 | 75 (40.1) | Family Hx of melanoma: 109 (58.6); Personal Hx of SC: 39 (20.9) | NR
KQ4: What is the association between detection of precancerous lesions or earlier stage skin cancer and morbidity and mortality due to skin cancer or all-cause mortality? | Dawes 2016^139^; Fair | US | 96,953 | Individuals diagnosed with melanoma between 1992 and 2009 with the data in SEER database; Data collected: 1992–2009 | Mean: NR 47% age 50 to 74 years (range, 0 to >74 years) | 45.3 | White: 94.8 Black: 0.5 AANAPI: 1.3 Hispanic: 3.4^¶^ | NR | NR | NR
KQ4: What is the association between detection of precancerous lesions or earlier stage skin cancer and morbidity and mortality due to skin cancer or all-cause mortality? | Enninga, 2017^140^; Fair | US | 106,511 | Adults diagnosed with melanoma between 1992 and 2011 with the data in SEER database; Data collected: 1992–2011 (followup for deaths was until 2012) | Mean: 59.1^‖^ 18–45: 28.1 46–54: 18.9 ≥55: 53.0 | 44.8 | White: 95.5 Black: 0.5 Asian or PI: 0.9 AI/AN: 0.2 Unknown: 2.9 Hispanic: 3.2 | NR | NR; 0% for previous melanoma^*^ | NR
KQ4: What is the association between detection of precancerous lesions or earlier stage skin cancer and morbidity and mortality due to skin cancer or all-cause mortality? | Farrow, 2020^141^; Fair | US | 268,668 | Adults age ≥18 years diagnosed with melanoma classified according to pathologic AJCC stage I–IV between 2004 and 2015 in the National Cancer Database; Data collected: 2004–2015 | 61^‡^ | 42.4 | White: 98.7 Black: 0.6 Other: 0.7 | NR | NR | NR
KQ4: What is the association between detection of precancerous lesions or earlier stage skin cancer and morbidity and mortality due to skin cancer or all-cause mortality? | Khosrotehrani, 2015^142^; Good | Australia | 28,979 | Histologically verified incident cases of first primary invasive melanomas diagnosed from 1995 to 2008 among people age 15–89 years in Queensland Cancer Registry and SEER database; Data collected: 1995–2008 (melanoma-specific deaths were ascertained up to 2010) | Mean: 56.1^‖^ 15–45: 27.5% 46–59: 28.1% 60–89: 44.5% | 43.3 | NR | NR | NR | NR
KQ4: What is the association between detection of precancerous lesions or earlier stage skin cancer and morbidity and mortality due to skin cancer or all-cause mortality? | Mahendraraj, 2017^143^; Fair | US | 213,827 | Patients of the White or Black^**^ race with cutaneous melanoma from the SEER database from 1988–2011; Data collected: 1988–2011 | Entire population: 58.9^‖^; White: 58.9; Black: 60.5 | M:F White: 1.33; Black: 1 | White: 99.5; Black: 0.5 | NR | NR | NR
KQ4: What is the association between detection of precancerous lesions or earlier stage skin cancer and morbidity and mortality due to skin cancer or all-cause mortality? | Qian, 2021^144^; Fair | US | 398,034 | Adults with cutaneous (95.7%), mucosal (1.2%), and uveal (3.1%) melanoma diagnosed between 1975 and 2016 | 60.1^‖^ | 43.0 | White: 95.40; Black: 0.57; Asian or PI: 0.73; AI/AN: 0.20; Hispanic: 3.09 | NR | NR | NR
KQ4: What is the association between detection of precancerous lesions or earlier stage skin cancer and morbidity and mortality due to skin cancer or all-cause mortality? | Robsahm, 2018^145^; Good | Norway | 8,087 | Individuals, age 2 to 98 years, with a first primary invasive melanoma diagnosis in the period 2008– 2012; Data collected: 2008–2012 (followup for deaths was until 2015) | 60.5^‖^; 64^‡^ | 50.1 | NR | NR | NR | Urban-rural area, n (%); Urban: 3,846 (47.6%); Rural: 4,241 (52.4%)
KQ4: What is the association between detection of precancerous lesions or earlier stage skin cancer and morbidity and mortality due to skin cancer or all-cause mortality? | Ward-Peterson, 2016^146^; Good | US | 185,219 | Adults age ≥18 years diagnosed with primary cutaneous melanoma from 1982 to 2011; Data collected: 1982–2011 | Mean: 57.2^‖^ <30: 6.0% 30–39: 13.8% 40–49: 18.1% 50–59: 19.4% 60–69: 18.5% ≥70: 24.3% | 43.0 | Non-Hispanic White: 91.7; Hispanic Black: 1.7; Hispanic: 2.5; Other: 1.2; Missing race data: 2.9 | NR | NR | NR
KQ4: What is the association between detection of precancerous lesions or earlier stage skin cancer and morbidity and mortality due to skin cancer or all-cause mortality? | Zheng, 2020^147^; Fair; KQ4 | Sweden | 19,773 | Patients in Swedish Cancer Registry who were diagnosed with first melanoma classified according to TNM staging system and who had tumor thickness data available; Data collected: 2003–2015 | Mean: 65.3^‖^ ≤50:27.0% 51–60:17.9% 61–70:22.9% 71–80:19.2% 81–90:11.0% ≥91:20.1% | 50.9 | NR | NR | NR; 0% for previous melanoma^*^ | NR

* Those with previous melanoma were excluded.

† Denominator=3,824.

‡ Median.

§ WHO definition: university or higher.

‖ Calculated, weighted mean.

¶ Categories are mutually exclusive; Hispanic persons were excluded from other groups, regardless of race.

** Study defined as African American and Caucasian.

†† Number of keratinocyte cancers not reported for comparison group of Trento population.

Abbreviations: AANAPI=Asian American/Native American/Pacific Islander; PI=Pacific Islander; AI/AN=American Indian/Alaska Native; AJCC=American Joint Committee on Cancer; Dec=December; GDP=Gross domestic product; Hx=History; Jan=January; KQ=Key question; Mm=Millimeter; NR=Not reported; PCP=Primary care physician; SC=Skin cancer; SD=Standard deviation; SEER=Surveillance, Epidemiology, and End Results program; TNM=Tumor size and spread to nearby tissue, tumor spread to nearby lymph nodes, metastases; UK=United Kingdom; UPMC=University of Pittsburgh Medical Center; US=United States; UV=Ultraviolet.

Among screened participants, the mean age was 49.7 years. Almost three-quarters of screened participants were females (73.6%). Nearly half of participants were judged to have at least one risk factor for melanoma based on family history of melanoma (6.1%), personal history of melanoma (1642 people, 2.6%), presence of atypical nevi (51.9%), multiple melanocytic nevi (56.2%) or congenital moles (20.9%). Other risk factors included UV-damaged skin (72.0%); actinic keratosis (31.2%), personal history of KC (16.9%); X-ray damaged skin (2.6%) or immunosuppression (2.7%).^104^ Data on other specific population subgroups (e.g., race and/or ethnicity) was not reported.

##### German National Screening Program

The total number of screened residents from the study period 2008–2013 is not reported in the included studies. However, an earlier publication describing the German program estimated that the population enrolled in the German health insurance plan DAK-Gesundheit was approximately 6.1 million members in an 18-month period in 2008–2009; in that time period approximately 920,000 people received screening.^148^

Characteristics of the screened population were not consistently reported. The German population during the screening period 2008–2012 was 51.2 percent female with a mean age of 43 years (including all ages) (Table 5).^135^ During that period, the mean quarterly screening participation was 30.8 percent, with screening participation significantly higher in females (age-and federal state- adjusted participation rates were 29.7% for males and 31.9% for females).^148^ Screening participation was highest in people over age 65, with state-adjusted rates among males between the ages 65 and 79 exceeding 40 percent.^148^

The good quality nonrandomized study by Datzmann and colleagues included enrollees in AOK PLUS, a health insurance plan that administers German national statutory health insurance and insures approximately 25 million people.^121^ The included sample was enrollees 35 years or older between 2010–2016 (n=1,431,327). The sample was mean age 63.9 years and 55.7% female. Neither race and ethnicity nor skin type was reported. Overall the screened and unscreened groups were similar, except for receipt of systemic therapy within 30 days (11.6% in screened vs 21.8% in unscreened group), suggesting a stage shift associated with screening. The study team identified all prevalent cases of melanoma during the study period (n=4,552) and limited their analysis to incident melanoma cases diagnosed during 2013–2016 with no evidence of melanoma in the previous 3 years (n=2475). People with documented skin cancer screening as identified through billing codes in the previous two years before diagnosis were considered to have received the screening intervention. The observation period was four years.

The outcome of interest was melanoma mortality. The team measured both the absolute risk difference as a difference in numbers of deaths during the observation period. They also conducted multivariable modeling and estimated both unadjusted and adjusted hazard ratios. Adjustment variables included age, sex, comorbidity, health-seeking behavior (estimated by receipt of flu vaccine), personal history of melanoma; and approximated stage categories of documented metastasis or receipt of systemic anticancer therapy. They also conducted sensitivity analyses to assess the potential for lead time bias by removing patients with survival of less than 360 days. Lead time bias associated with screening is when survival can appear longer because of detection, not because of intervention.^152^

#### Quality

For this key question, two included studies were rated fair quality and the Datzmann study was rated as good quality. Followup time was sufficient to observe skin cancer incidence and mortality over time, screening procedures were well described, populations were clearly defined, sources of outcome data were strong (use of national and regional health statistics), and sample sizes were large.

Quality concerns were primarily related to the known limitations of ecologic studies,^153–155^ including the lack of controlled intervention (e.g., selection bias with voluntary screening programs) and the lack of individual-level data on screening participants, including–importantly—previous screening participation and the presence of skin cancer risk factors. There is adequate biologic plausibility for an effect of screening to be observed at the population level, and the included studies’ followup times are sufficient to observe melanoma mortality. However, the included studies can neither directly compare individual-level changes in mortality among people receiving versus not receiving skin cancer screening, nor account for confounding through randomization or adjustment for environmental factors or socioeconomic, risk factor, or demographic variables. As such, our ability to infer a causal relationship between skin cancer screening and melanoma mortality is limited and should be viewed cautiously.

Another potential quality concern has been raised in a related study, where the authors examined the cause of death statistics for Schleswig-Holstein during the years of the SCREEN program evaluation (2007–2010), which overlaps with the years the mortality benefit was observed (2004–2009).^126^ They concluded that potential for misclassification existed during that time period, when an unusually high number of deaths were coded as “malignancies of ill-defined, secondary, and unspecified sites” (ICD-10 codes C76–C80) and an unusually low number of deaths were coded as due to malignant melanoma. They argue that this change would be sufficient to explain the mortality benefit observed in those years.^156^

#### Detailed Results by Outcome

No included studies reported all-cause mortality, SCC mortality, or BCC mortality.

##### Melanoma Mortality in the SCREEN Program

During the SCREEN study period from 2003 to 2004, 1,169 incident melanoma cases were reported to the state cancer registry, 585 of which were detected via the SCREEN study.^104^ Of these 585, 31 percent were melanoma in situ and 69 percent were invasive melanoma. The SCREEN study also detected 1,961 basal cell carcinomas, 392 SCC and 165 other skin cancers.

Incidence of melanoma, BCC, SCC, and melanoma in situ increased during the SCREEN pilot (Figures 3 and 4). Melanoma age-adjusted incidence rates (per 100,000 individuals) increased 27 percent from 14.2 (95% CI, 13.3 to 15.1) during 2001–2003 to 18.0 (95% CI, 16.6 to 19.4) during the active screening period (2003–2004). Similarly, melanoma in situ age-adjusted incidence rates (per 100,000 individuals) increased 48 percent between the pre-screening period versus during-screening period. SCC age-adjusted incidence rates (per 100,000 individuals) in the pre-screening period versus during-screening period were 11.2 (95% CI, 10.6 to 11.8) and 12.9 (95% CI, 12.0 to 13.8), respectively, a 15 percent increase. BCC age-adjusted incidence rates (per 100,000) increased 29 percent in the prescreening period versus during-screening period from 60.5 (95% CI, 59.0 to 62.1) to 78.4 (95% CI, 75.9 to 80.8).^104^

Figure 3 Incidence of BCC, SCC, and Melanoma Before and After Implementation of National Screening Programs, Germany^124^

This figure shows the incidence of melanoma, BCC, SCC, and melanoma during the Skin Cancer Research to Provide Evidence for Effectiveness of Screening in Northern Germany (SCREEN) pilot program and the German national screening program. During the SCREEN program, melanoma age-adjusted incidence rates (per 100,000 individuals) increased from 14.2 during 2001-2003 to 18.0 during the active screening period (2003-2004). During the same period, melanoma in situ age-adjusted incidence rates (per 100,000) increased from 5.8 to 8.5; SCC age-adjusted incidence rates (per 100,000) increased from 11.2 to 12.9; and BCC age-adjusted incidence rates (per 100,000) increased 60.5 to 78.4. During the German national program, age-standardized melanoma incidence rates increased from between 14.5 per 100,000 during 2003-2007, to 18.0 per 100,000 during 2008-2011.

Figure 4 Age-Standardized Annual Incidence for Melanoma and Keratinocyte Skin Cancer Before and After the Initiation of the German National Screening Program^135^

This figure shows trends in annual incidence for melanoma and keratinocyte cancer (KC) from 2007 (before the 2008 initiation of the German national screening program) until 2011. During that time period, the age-standardized incidence per 100,000 persons for melanoma ranged from 15.7 to 25.1 (mean 22.1), while KC incidence ranged from 128.0 to 169.4 (mean 158.2). For both types of skin cancer, there was an increase in 2008, the year in which the German national screening program was introduced.

In the previous evidence review,^106^ included data from the SCREEN study^126^ suggested a 49 percent mortality reduction in the screening region compared to the surrounding regions at 5 years of followup from the end of the program (2003–2004 program; evaluation through 2009). However, updated data with longer followup to 2013 suggests that the mortality improvement previously reported appears to attenuate over time (Table 6, Figure 5). It should be noted that Germany as a whole had a fairly stable melanoma mortality rate between 1998 and 2010 (between 1.9 and 2.1 per 100,000), with a marginal increase between 2011 and 2013 (2.2 to 2.3 per 100,000). The SCREEN region’s age-standardized mortality rate fluctuated more: higher than Germany's overall rate in the years preceding the SCREEN program (1998–2002); similar to Germany’s overall rate during the SCREEN program (2003–2004); and decreasing to below the German rate around 2008–2010 when compared to Germany as a whole.^125^ An additional analysis conducted of observed versus expected melanoma mortality in the SCREEN region (state of Schleswig-Holstein, northern Germany) compared to the state of Saarland (western Germany) from 2003–2008 found that observed melanoma deaths in the SCREEN region were lower than would be expected (age- and sex- adjusted standardized mortality rate 0.59, 95% CI, 0.40 to 0.83) (Table 7).^157^ This is consistent with the 49 percent mortality rate reported in earlier publications.^126^

Figure 5 Melanoma Mortality, Overall Population, Schleswig-Holstein vs. Germany, 1998-2013^124^ (In table form in (Table 6)

*Period of active screening

This figure shows trends in melanoma mortality in the SCREEN pilot project region (Schleswig-Holstein) and Germany as a whole from 1998 to 2013. These data, which are also reported in (Table 6, show that Germany had a fairly stable melanoma mortality rate between 1998 and 2010 (between 1.9 and 2.1 per 100,000), with a marginal increase between 2011 and 2013 (2.2 to 2.3 per 100,000). Schleswig-Holstein’s age-standardized mortality rate was higher than Germany’s overall rate in the years preceding the SCREEN program (1998-2002); similar to Germany’s overall rate during the SCREEN program (2003-2004); decreasing to below the German rate around 2008-2010, then once again similar to the German rate around 2011-2013.

Table 6 Age-Standardized Melanoma Mortality per 100,000, SCREEN Study Region and Germany, 1998–2013, Total and by Sex (KQ1, KQ1a, depicted graphically also in Figures 5 and 6)^125^

| Schleswig-Holstein^*^ | Schleswig-Holstein^*^ | Germany^†^ | Germany^†^ | Schleswig-Holstein^*^ | Schleswig-Holstein^*^ | Germany^†^ | Germany^†^ | Schleswig-Holstein^*^ | Schleswig-Holstein^*^ | Germany^†^ | Germany^†^
Katalinic, 2015 Fair | Age-standardized mortality rate per 100,000 | Number of melanoma deaths | Age-standardized mortality rate per 100,000 | Number of melanoma deaths | Age-standardized mortality rate per 100,000 | Number of melanoma deaths | Age-standardized mortality rate per 100,000 | Number of melanoma deaths | Age-standardized mortality rate per 100,000 | Number of melanoma deaths | Age-standardized mortality rate per 100,000 | Number of melanoma deaths
Year | Total | Total | Total | Total | Female | Female | Female | Female | Male | Male | Male | Male
1998 | 2.1 | 77 | 1.9 | 2,030 | 2.1 | 45 | 1.6 | 1,004 | 2.1 | 32 | 2.3 | 1,026
1999 | 2.6 | 95 | 1.9 | 2,021 | 2 | 44 | 1.5 | 964 | 3.3 | 51 | 2.4 | 1,057
2000 | 2.6 | 97 | 2 | 2,178 | 1.8 | 43 | 1.6 | 1,017 | 3.4 | 54 | 2.6 | 1,161
2001 | 2.8 | 109 | 2 | 2,217 | 2.2 | 52 | 1.6 | 1,046 | 3.4 | 57 | 2.5 | 1,171
2002 | 2.2 | 88 | 1.9 | 2,210 | 2 | 45 | 1.6 | 1,073 | 2.6 | 43 | 2.4 | 1,137
2003 | 1.8^‡^ | 76^‡^ | 2 | 2,295 | 1.8^‡^ | 41^‡^ | 1.5 | 1,009 | 1.9^‡^ | 35^‡^ | 2.7 | 1,286
2004 | 2.2^‡^ | 87^‡^ | 2 | 2,293 | 1.8^‡^ | 37^‡^ | 1.6 | 1,037 | 2.8^‡^ | 50^‡^ | 2.5 | 1,256
2005 | 2.2 | 86 | 2 | 2,327 | 1.2 | 29 | 1.6 | 1,089 | 3.2 | 57 | 2.4 | 1,238
2006 | 2.2 | 88 | 1.9 | 2,287 | 1.6 | 35 | 1.5 | 1,021 | 2.8 | 53 | 2.4 | 1,266
2007 | 1.8 | 78 | 2 | 2,467 | 1.4 | 36 | 1.6 | 1,099 | 2.3 | 42 | 2.6 | 1,368
2008 | 1^§^ | 44^§^ | 2 | 2,500 | 0.9^§^ | 21^§^ | 1.6 | 1,135 | 1.1^§^ | 23^§^ | 2.5 | 1,365
2009 | 1.4^§^ | 55^§^ | 2.1 | 2,657 | 1.1^§^ | 22^§^ | 1.7 | 1,203 | 1.8^§^ | 33^§^ | 2.6 | 1,454
2010 | 1.5^§^ | 64^§^ | 2.1 | 2,711 | 1^§^ | 24^§^ | 1.6 | 1,143 | 2^§^ | 40^§^ | 2.7 | 1,568
2011 | 2.3^§^ | 104^§^ | 2.3 | 2,921 | 1.9^§^ | 49^§^ | 1.7 | 1,212 | 2.7^§^ | 55^§^ | 3 | 1,709
2012 | 2.4^§^ | 105^§^ | 2.2 | 2,875 | 2.1^§^ | 50^§^ | 1.7 | 1,248 | 2.7^§^ | 55^§^ | 2.8 | 1,627
2013 | 2.4^§^ | 112^§^ | 2.3 | 3,042 | 2.2^§^ | 55^§^ | 1.7 | 1,255 | 2.7^§^ | 57^§^ | 3 | 1,787

* SCREEN study region.

† Germany data includes Schleswig-Holstein.

‡ Years of SCREEN skin cancer screening program (2003–2004).

§ Years of German national skin cancer screening (2008–2013).

Table 7 Observed vs. Expected Mortality, SCREEN Study Region and Saarland Region, Germany, 2003–2008 (KQ1)^122^

Eisemann, 2018 Fair | N | Followup period | Person years analyzed | Incident melanoma cases | Observed deaths, age- and sex-adjusted | Observed mortality rate per 100,000 (age- and sex-adjusted) | Expected deaths, adjusted for age, sex, and population size | Standardized mortality rate, age- and sex-adjusted (95% CI)
SCREEN participants (Schleswig-Holstein region)^*^ | 360,196 | July 2003– December 2008 | 1,981,078 | 1,472 | 31 | 1.56 | 52.7 | 0.59 (0.40, 0.83)
Saarland region^†^ | ~1 million | July 2003– December 2008 | 5,763,767 | 1,026 | 111 | 1.93 | 52.7 | 0.59 (0.40, 0.83)

* Routine skin cancer offered through SCREEN study 2003–2004.

† No routine skin cancer offered in this region until 2008.

Abbreviations: CI=Confidence interval; KQ=Key question.

##### Melanoma Mortality in the German Screening Program

Based on German incidence rates used as the comparator in the 10-year followup of the SCREEN program, age-standardized melanoma incidence rates increased markedly at the time when the German national program was introduced. Age-standardized melanoma incidence rates increased from between 14.0 and 14.9 per 100,000 during 2003–2007, to between 17.7 and 18.2 per 100,000 during 2008–2011.

An evaluation of the German national program examined change in incident melanoma diagnoses based on hospital discharges. The multivariable fixed effects model suggested an association of the German program with increased diagnoses in the unadjusted model (coefficient 0.276, SE 0.02, p<0.001). Although this effect was attenuated with the addition of covariates (coefficient 0.181, SE 0.02, p<0.001), an independent association of the screening program with new diagnoses appeared to remain. This finding suggests that the German program was effective in increasing new skin cancer diagnoses after 2008, while not in the surrounding European countries.^124^

Two included studies reported data on melanoma mortality in Germany related to the implementation of national skin cancer screening.^120,^ ^121,^ ^125^ The first, a study by Datzmann and colleagues, observed a total of 325 melanoma deaths during the 4-year observation period, and found a higher proportion of melanoma deaths in the unscreened group compared to the screened group (171 deaths, 9.5% of the screened group; 154 deaths, 22.8% of the unscreened group; unadjusted HR 0.37, p<0.05) (Table 8).^121^ On adjusted analyses, the association was attenuated but remained statistically significant (adjHR 0.62, p<0.05). The sensitivity analyses to assess potential lead time bias were similarly attenuated on both unadjusted (HR 0.50, p<0.05) and adjusted estimates (adjHR 0.75, NS).

Table 8 Melanoma Mortality for First-Onset Melanoma 2013–2016 Among Screened Enrollees in AOK Plus Health Insurer in Saxony, Germany

Datzmann, 2022^121^; Good | Total N | Screened N (%) | Unscreened N (%) | ARR in melanoma mortality for screening participants | Unadjusted HR^†^for melanoma mortality | Unadjusted HR^†^, lead time bias correction | Adjusted HR^†^,^§^ for melanoma mortality | Adjusted HR^†^,^§^, lead time bias correction
AOK Plus population | 1,431,327 | 688,708 (48.1) | 742,619 (51.9) | 13.3% | 0.37^‡^ | 0.50^‡^ | 0.62^‡^ | 0.75
Incident melanoma^*^ | 2,475 | 1,801 (72.8) | 674 (27.2) | 13.3% | 0.37^‡^ | 0.50^‡^ | 0.62^‡^ | 0.75
Melanoma deaths | 325 | 171 (9.5) | 154 (22.8) | 13.3% | 0.37^‡^ | 0.50^‡^ | 0.62^‡^ | 0.75

* First onset 2013–2016.

† Hazard ratios for dying within the observation period; screening participation within 2 years before diagnosis vs. no screening participation.

‡ p<0.05.

§ Adjusted for age group (three); sex; year of diagnosis; education; systemic anticancer therapy; history of nonmelanoma skin cancer; influenza vaccination in the year before the initial melanoma diagnosis; colorectal, prostate, and breast cancer screening within 3 years prior to diagnosis; health checkup (from age 35 years onward) within the 2 years prior to diagnosis; 22 Elixhauser comorbidities; stroke, ischaemic heart disease and heart failure in last 3 months; five strata for type/timing of metastasis.

Abbreviations: ARR=absolute risk reduction; HR=hazard ratio.

A separate analysis of melanoma mortality from 2000 to 2012 between Germany and 22 other European countries found that the unadjusted mean annual melanoma mortality rate per 100,000 increased, not decreased, between the time period 2000–2007 (before the German national skin cancer screening program began in 2008) and 2008–2012 (Table 9). Although point estimates were not reported, similar increasing melanoma mortality trends were observed in many of the other European countries.^124^ This evidence suggests that there is no observable benefit to national skin cancer screening.

Table 9. Melanoma Mortality Overall and by Sex and Age Group; Germany and Surrounding Countries, 1980–2012^120^

Boniol, 2015 Fair | Annual percent change (95% CI) All ages 1980–2012 | All ages 2008–2012^*^ | Age less than 60 years; 1980–2012 | Age 60–74 years; 1980–2012 | Age 75 years and older; 1980–2012
Men
Germany | 0.44 (0.26 to 0.62)^‡^ | 2.57 (−0.10 to 5.24) | −0.9 (−1.2 to −0.7)^¶^ | 1.4 (0.6 to 2.1)^**^ | 1.6 (1.1 to 2.1)^**^
Czech Republic^†^ | −0.55 (−0.91 to −0.20)^‡^ | 0.65 (−4.57 to 5.88) | −2.8 (−3.5 to −2.1)^¶^ | −0.3 (−0.9 to 0.4) | 2.1 (1.4 to 2.8)^**^
Poland | 2.70 (2.43 to 2.97)^‡^ | 1.19 (−0.64 to 3.01) | −0.4 (−1.6 to 0.7) | 3.1 (2.7 to 3.5)^**^ | 5.6 (4.9 to 6.2)^**^
Denmark^§^ | 0.60 (0.17 to 1.03)^‡^ | −1.70 (−7.51 to 4.11) | −1.2 (−1.8 to −0.6)^¶^ | 1.6 (0.9 to 2.2)^**^ | 2.8 (1.6 to 4.1)^**^
Austria | 0.84 (0.40 to 1.28)^‡^ | −0.06 (−1.17 to 1.04) | −0.9 (−1.5 to −0.3)^¶^ | 1.1 (0.5 to 1.7)^**^ | 1.5 (−0.3 to 3.3)
Belgium^‖^ | 2.10 (1.77 to 2.60)^‡^ | −2.74 (−7.18 to 1.71) | 2.2 (1.5 to 3.0)^**^ | 2.3 (1.7 to 2.9)^**^ | 1.7 (0.8 to 2.7)^**^
France^‖^ | 2.20 (2.03 to 2.37)^‡^ | 1.96 (−1.60 to 5.51) | 1.1 (0.9 to 1.4)^**^ | 2.2 (1.7 to 2.6)^**^ | 3.4 (2.9 to 3.9)^**^
The Netherlands | 2.54 (2.31 to 2.76)^‡^ | 1.04 (−3.34 to 5.42) | 1.2 (0.8 to 1.5)^**^ | 3.9 (3.5 to 4.4)^**^ | 3.9 (3.2 to 4.7)^**^
Switzerland^‖^ | 0.33 (−0.06 to 0.72) | 4.28 (−3.85 to 12.4) | −1.3 (−2.1 to −0.6)^¶^ | 0.6 (−0.0 to 1.2) | 0.1 (−1.6 to 1.9)
Women
Germany | −0.15 (−0.30 to 0.00) | 0.02 (−1.79 to 1.82) | 0.3 (−0.2 to 0.8) | −0.4 (−0.8 to −0.0)^¶^ | 1.0 (0.8 to 1.3)^**^
Czech Republic^†^ | −0.90 (−1.41 to −0.39)^‡^ | −0.25 (−4.40 to 3.90) | −2.2 (−3.0 to −1.4)^¶^ | −0.4 (−1.1 to 0.3) | 6.4 (−2.0 to 15.5)
Poland | 1.62 (1.28 to 1.97)^‡^ | 1.28 (−0.85 to 3.42) | −0.5 (−1.0 to −0.0)^¶^ | 2.0 (1.7 to 2.4)^**^ | 3.5 (3.1 to 4.0)^**^
Denmark^§^ | −0.11 (−0.64 to 0.41) | −1.70 (−9.61 to 6.21) | −1.7 (−2.5 to −0.8)^¶^ | 0.6 (−0.2 to 1.3) | 2.0 (1.4 to 2.6)^**^
Austria | 0.29 (−0.11 to 0.69) | 2.17 (−7.11 to 11.5) | −0.4 (−1.0 to 0.3) | 0.3 (−0.3 to 0.9) | −0.5 (−2.1 to 1.1)
Belgium^‖^ | 2.22 (1.74 to 2.84)^‡^ | −1.17 (−5.74 to 3.41) | 1.0 (0.1 to 2.0)^**^ | 0.8 (−0.6 to 2.3) | 2.2 (1.4 to 3.0)^**^
France^‖^ | 1.23 (0.97 to 1.49)^‡^ | 2.64 (−9.63 to 14.9) | 0.5 (0.1 to 0.9)^**^ | 0.4 (−0.7 to 1.4) | 2.2 (1.8 to 2.6)^**^
The Netherlands | 1.79 (1.48 to 2.10)^‡^ | −0.82 (−6.33 to 4.69) | 1.2 (0.8 to 1.6)^**^ | 2.3 (1.7 to 2.9)^**^ | 2.8 (2.4 to 3.3)^**^
Switzerland^‖^ | −0.37 (−0.78 to 0.04) | −1.21 (−3.11 to 0.69) | −1.4 (−2.0 to −0.8)^¶^ | 0.2 (−0.5 to 0.9) | 0.1 (−0.7 to 0.9)

* German national screening program began in 2008.

† Years of reporting for the Czech Republic: 1986–2012.

‡ Significant trends.

§ Years of reporting for Denmark: 1980–2011.

‖ Years of reporting for Belgium, France, and Switzerland: 1980–2010.

¶ Statistically significant decrease in melanoma mortality.

** Statistically significant increase in melanoma mortality.

Adjusted mortality rates were not provided, but the authors fit a multivariable fixed effects model using a hypothetical control group comprised of the included 22 European countries (excluding Germany) to estimate the screening program impact on melanoma mortality (Table 10). This model included population-level demographic variables (age, sex, physician density, education), and accounts for the years in Germany in which the SCREEN program took place (2003–2004) using dummy variables.^124^ There was an association between mortality and the German program in the unadjusted model (coefficient 0.242, p<0.01), but with the addition of covariates there was no significant independent relationship between the screening program and mortality (coefficient 0.077, not significant). The authors concluded there was no significant overall effect of the German skin cancer screening program on melanoma mortality.^124^

Table 10 Unadjusted Melanoma Mortality Rate per 100,000 Before and After Implementation of National Skin Cancer Screening, Germany, 2000–2012 (KQ1)

Study | Country | N in group | Number of deaths (2000–2012) | Unadjusted melanoma mortality rate per 100,0000^†^, mean (2000–2007) | Unadjusted melanoma mortality rate per 100,0000^†^, mean (2008–2012^‡^)
Kaiser 2018^124^ Fair | Germany (excluding Schlesweig-Holstein)^*^ | NR | NR | 2.733 | 3.429
Kaiser 2018^124^ Fair | Europe (excluding Germany)^§^ | NR | NR | 2.841 | 3.155

* SCREEN skin cancer screening program was conducted in Schleswig-Holstein region 2003–2004.

† ICD-10 C43.

‡ National German skin cancer screening implemented in 2008.

§ 22 European countries: Austria, Belgium, Bulgaria, Switzerland, Czech Republics, Germany, Denmark, Spain, Finland, France, Croatia, Hungary, Ireland, Italy, Netherlands, Norway, Poland, Portugal, Romania, Sweden, Slovenia, and Slovakia (Eurostat data).

Abbreviations: KQ=Key question; NR=Not reported.

#### Specific Population Results (KQ1a)

Three included publications from the two German screening programs reported age- and sex-specific melanoma mortality.^120,^ ^124,^ ^125^ Data on race and/or ethnicity-specific or other specific populations was not reported.

In the SCREEN study, mortality rates were lower in females than males throughout the followup period (Figure 6). Female mortality rates for Schleswig-Holstein dipped below that of Germany in 2005 (the year after the SCREEN pilot ended) and then again in 2007–2010. No statistical tests of significance were reported. Female mortality rates appeared fairly steady, fluctuating between 0.9 and 2.2 melanoma deaths per 100,000 for Schleswig-Holstein and 1.5 and 1.7 per 100,000 for Germany ((Table 6).^125^ Similar to the trend among females, for males the mortality rate was fairly steady, varying between 2.3 and 3 per 100,000 for Germany. The rate for Schleswig-Holstein males varied the most, with one dip in mortality in 2003 (the first year of the SCREEN program) and the lowest mortality observed in 2008 (1.1 per 100,000), then increasing steadily thereafter. Mortality rates increased in 2005 (just at the end of the SCREEN program) and appeared to be increasing toward the last 3 years of the followup period, approaching that of Germany as a whole (Table 6).^125^

Figure 6 Melanoma Mortality, Males and Females, Schleswig-Holstein vs. Germany, 1998-2013^124^ (In table form in (Table 6)

*Period of active screening

This figure shows trends in melanoma mortality in the SCREEN pilot project region (Schleswig-Holstein) and Germany as a whole from 1998 to 2013, separated by sex (male & female). These data, which are also reported in Table 6, show that mortality rates were lower in females than males throughout the followup period. Female mortality rates appeared fairly steady, fluctuating between 0.9 and 2.2 melanoma deaths per 100,000 for Schleswig-Holstein and 1.5 and 1.7 per 100,000 for Germany. For males in Germany, the mortality rate was fairly steady, varying between 2.3 and 3 per 100,000. The mortality rate for males in Schleswig-Holstein varied the most, with one dip in mortality in 2003 (the first year of the SCREEN program) and the lowest mortality observed in 2008 (1.1 per 100,000), then increasing steadily thereafter, approaching that of Germany as a whole.

The German National Screening Program publications reported findings on the impact of age on melanoma mortality. Although the fixed effects multivariable model in the Kaiser and colleagues study’s model did not support an overall impact of the screening program, the proportion of the population over the age of 65 years did appear independently linked to improved mortality (coefficient 0.094, SE 0.03, p<0.001) (data not shown).^124^

The fluctuation in melanoma mortality reported in the SCREEN program appeared primarily in people aged 65 years or over (Table 11). Melanoma mortality rates were highest in both males and females in this age group, in both the SCREEN region and in Germany as a whole (Figures 7 and 8). In females aged 65 years or over, the mortality rate in the SCREEN region was highest in 2001 (13.2 per 100,000, two years before the SCREEN program began) and lowest in 2008–2009 (3.8 per 100,000; five years after the SCREEN program), increasing thereafter.^125^ Similarly to females, in males aged 65 years or older, the mortality rate in the SCREEN region was also highest in 2001 (17.7 per 100,000; two years before the SCREEN program began), decreased to its lowest point in 2009 (5.7 per 100,000, 5 years after the end of the SCREEN program), then steadily increased to approach the German national mortality rate by the end of the followup period.^125^ Additionally, in both males and females, melanoma mortality was similar in both the SCREEN region and in Germany by the end of the followup period in all age groups.^125^

Figure 7 Melanoma Mortality, Males by Age Group, Schleswig-Holstein vs. Germany, 1998-2013^124^ (In table form in Table 11)

*Period of active screening

This figure shows trends in melanoma mortality in the SCREEN pilot project region (Schleswig-Holstein) and Germany as a whole from 1998 to 2013, for males of different age groups. These data, which are also reported in Table 10, show that melanoma mortality rates were highest in males aged 65 and older in both Schleswig-Holstein and Germany as a whole during the entire period from 1998 to 2013.

Figure 8 Melanoma Mortality, Females by Age Group, Schleswig-Holstein vs. Germany, 1998-2013^124^ (In table form in Table 11)

* Period of active screening

This figure shows trends in melanoma mortality in the SCREEN pilot project region (Schleswig-Holstein) and Germany as a whole from 1998 to 2013, for females of different age groups. These data, which are also reported in Table 10, show that melanoma mortality rates were highest in females aged 65 and older in both Schleswig-Holstein and Germany as a whole during the entire period from 1998 to 2013.

Table 11 Unadjusted Melanoma Mortality Rates per 100,000, Germany and Schleswig-Holstein, by Age Group and Sex (KQ1a depicted graphically also in Figures 7 and 8)^125^

Katalinic, 2015 Fair | Schleswig-Holstein | Germany | Schleswig-Holstein | Germany | Schleswig-Holstein | Germany | Schleswig-Holstein | Germany | Schleswig-Holstein | Germany | Schleswig-Holstein | Germany
| Male | Male | Male | Male | Male | Male | Female | Female | Female | Female | Female | Female
Year | 35 to 49 | 35 to 49 | 50 to 64 | 50 to 64 | 65+ | 65+ | 35 to 49 | 35 to 49 | 50 to 64 | 50 to 64 | 65+ | 65+
1998 | 1.7 | 1.5 | 4.3 | 4 | 9.1 | 10.5 | 2.1 | 1.1 | 3.2 | 3 | 10.5 | 7.7
1999 | 3.3 | 1.6 | 6.7 | 4.2 | 12.3 | 10.3 | 2.4 | 1.1 | 3.6 | 2.6 | 9.7 | 7.3
2000 | 2.9 | 1.6 | 7.8 | 4.6 | 11.8 | 11.1 | 0.7 | 1.2 | 3.9 | 2.7 | 10.6 | 7.7
2001 | 1.9 | 1.6 | 6.4 | 4.4 | 17.7 | 11.3 | 1.9 | 1 | 2.9 | 2.7 | 13.2 | 8
2002 | 1.2 | 1.4 | 3.6 | 4.2 | 12.7 | 10.9 | 1.3 | 1.1 | 3.6 | 2.8 | 9.8 | 8.1
2003 | 0.3^*^ | 1.6 | 4.0^*^ | 4.7 | 11.1^*^ | 12 | 1.5^*^ | 1.2 | 3.3^*^ | 2.8 | 8.3^*^ | 7.2
2004 | 1.2^*^ | 1.4 | 6.3^*^ | 4.3 | 13.3^*^ | 11.8 | 1.8^*^ | 1.3 | 3.7^*^ | 2.6 | 5.8^*^ | 7.4
2005 | 2.6 | 1.3 | 5.6 | 4.2 | 13.9 | 11.3 | 0.3 | 1.1 | 2.6 | 2.9 | 6.6 | 7.7
2006 | 1.7 | 1.4 | 6.5 | 4.1 | 12 | 11.4 | 1.5 | 1.2 | 3.4 | 2.5 | 6.4 | 7.1
2007 | 1.1 | 1.5 | 5.4 | 4.5 | 9.6 | 11.9 | 1.2 | 1.1 | 2.6 | 2.7 | 7.5 | 7.6
2008 | 0.6^†^ | 1.5^†^ | 1.5^†^ | 3.9^†^ | 6.2^†^ | 12.1^†^ | 0.9^†^ | 1.3^†^ | 1.5^†^ | 2.8^†^ | 3.8^†^ | 7.8^†^
2009 | 1.5^†^ | 1.3 ^†^ | 5^†^ | 4.3^†^ | 5.7^†^ | 13^†^ | 0.6^†^ | 1.3^†^ | 1.9^†^ | 2.7^†^ | 3.8^†^ | 8.3^†^
2010 | 1.5^†^ | 1.6 ^†^ | 3.7^†^ | 4.4^†^ | 9^†^ | 13.8^†^ | 1.2^†^ | 1.4^†^ | 1.1^†^ | 2.6^†^ | 4.9^†^ | 7.8^†^
2011 | 2.5^†^ | 1.7 ^†^ | 3.6^†^ | 4.6^†^ | 14^†^ | 16.5^†^ | 1.2^†^ | 1.3^†^ | 3.5^†^ | 2.9^†^ | 9.9^†^ | 8.8^†^
2012 | 1.6^†^ | 1.3 ^†^ | 5.3^†^ | 4.4^†^ | 12.6^†^ | 15.8^†^ | 4.1^†^ | 1.4^†^ | 2.4^†^ | 2.9^†^ | 8.7^†^ | 9.1^†^
2013 | 1.3^†^ | 1.5 ^†^ | 5.1^†^ | 4.5^†^ | 13.5^†^ | 17.3^†^ | 1.9^†^ | 1.5^†^ | 3.7^†^ | 2.6^†^ | 10.9^†^ | 9.3^†^

* Years in which skin cancer screening (pilot project in Schleswig-Holstein or national skin cancer screening) was performed.

† Years of German national skin cancer screening (2008–2013).

In the analysis of the annual percent change in melanoma mortality in Germany compared to eight other European countries, there was little evidence of differential annual percent change in melanoma mortality in either males or females that could be attributable to the German program (Table 9).^120^ Overall, in males, all countries except the Czech Republic saw a slight annual increase in melanoma mortality between 1980 and 2012. However, for the period 2008–2012 (the German program began 2008), the annual percent change was flat for all countries, including Germany.^120^ For females in Germany, there was no significant annual percentage change for either the entire period 1980–2012 or the screening program period 2008–2012. Other countries saw more annual fluctuations in the percent change in female melanoma mortality over the longer observation period. The annual percent change among females remained flat for all countries, including Germany, for 2008–2012.^120^

Annual percent change in mortality data were only reported for both sex and age for the entire period 1980–2012. These data suggest that several countries, including Germany, observed a significant increase in melanoma mortality in males aged 60–74 years (Germany 1.4 APC, 95% CI, 0.6 to 2.1) and 75 years and older (Germany's was 1.6 APC, 95% CI, 1.1 to 2.1) compared to males under age 60 years. Germany's annual percentage change increase was smaller in the two age groups of males aged 60–74 years and 75 years or more compared to other countries observing a significant increase in the annual percent change.^120^ For females, a similar pattern was observed (Germany: age 60–74 APC −0.4, 95% CI −0.8 to 0; age 75+ APC 1.0, 95% CI 0.8 to 1.3), although the annual percent change increases were smaller than for males.^120^

## KQ2. Does Routine Skin Cancer Screening Lead to Higher Rates of Detection of Precancerous Lesions or Earlier Stage Skin Cancer Compared to Usual Care (e.g., Lesion-Directed Skin Examination)? Do Rates of Earlier Skin Cancer Detection Vary by Subgroups (e.g., Age, Sex, Skin Type, Race/Ethnicity, Socioeconomic Status, or UV Exposure)?

### Summary of Results

Based on nonrandomized observational data from four evaluations of three skin cancer screening programs (all fair-quality, n=2,344,210),^130,^ ^132,^ ^133,^ ^135^ and one good-quality physician-focused skin cancer examination initiative (n=595,799),^134^ routine clinician skin examination does not appear to be associated with increased detection of KC, melanoma, or skin cancer precursor lesions compared to usual care or lesion-directed examination.

Three studies reporting heterogeneous categories of stage at detection suggested a similar lack of association between screening and stage at melanoma detection. Routine clinician skin examination was not associated with earlier detection in two studies, one using AJCC stage categories of melanoma in situ, stage I/II, and stage III/IV^133^ and the other using SEER-comparable stages (presence of lymph node and distant metastasis).^135^ However, in another study, the distribution of melanoma in situ at detection favored the screened group.^134^

There is mixed evidence on the association between clinician skin examination and lesion thickness at detection based on three nonrandomized studies reporting clinically relevant lesion thickness categories, with one study suggesting no association with lesions <1mm at detection but some association for lesions <2mm at detection,^130^ and one study finding association for lesions <1mm only and not for lesions thicker than 1mm.^134^ The third, a case-control study, found higher odds of having received a clinician skin examination in people with melanomas detected at <0.75mm thickness compared to unaffected controls, but not for thicker lesions; though people with lesions ≥3.00mm had significantly lower odds of having received an examination compared to controls.^129^

### Detailed Results

#### Overview of Included Studies

Per our inclusion criteria, all studies included evaluations of visual skin examinations conducted by primary care physicians or dermatologists and compared precursor lesion detection or stage at skin cancer detection between groups receiving either routine skin cancer screening or usual care.

Six nonrandomized studies with data on approximately 2.9 million individuals and 53,329 skin cancer or precursor lesions met inclusion criteria (Tables 3–5),^129–133,^ ^135^ one of which was carried forward from the previous review.^129^ One of the six studies was conducted in the United States.^134^ Study populations ranged from 497 to 34,295 skin cancer or precursor lesion cases. The outcomes assessed included precursor lesions (2 studies),^130,^ ^132^ stage at melanoma detection (3 studies),^133–135^ and stage at KC detection (1 study).^133^ Three studies reported thickness at melanoma detection,^129,^ ^130,^ ^134^ and one study reported the odds of having received a clinical skin examination in people with and without skin cancer.^129^

We included four studies that reported analyses of three skin cancer examination programs that included outreach to patients. These three programs varied in their implementation and comparison group composition (Tables 3 and 4). Two included publications used data from the German National Skin Cancer Screening Program to compare people with skin cancer who had documented skin cancer screening to those without documented screening.^133,^ ^135^ One study compared skin cancer detection in people who had participated in a community-based screening program conducted in Trento, Italy, in 2001–2004 to skin cancer detection in the general population of the same city through 2013.^130^ Lastly, a study conducted in Belgium compared skin cancer detection in two communities where different public outreach strategies were used for single 4- to 5-day screening events: in one community, people were invited to receive whole body examination; in the other community, people were invited to have suspicious skin lesions examined.^132^ Screening participation rates were reported for two studies and were overall quite low: 12.4 percent in the German screening program;^135^ and 17.9 percent in the total body screening group in Belgium compared to 3.3 percent for the lesion directed screening group in the Belgian study.^132^

The intervention in the U.S.-based study was a physician-focused decision support intervention and did not include direct outreach to patients.^134^ In this quality improvement initiative in academic primary care clinics, full-body skin examination was added to the list of preventive care recommendations in the electronic health record of patients aged 35 years or older. Primary care physicians were offered training in diagnosing skin cancer and encouraged to participate in the initiative by medical center leadership.^131,^ ^134^

Finally, a case-control study conducted in Queensland, Australia, identified cases among those with incident melanoma (n=3,762) and matched unaffected controls randomly selected through electoral rolls (n=3,824). The authors measured the association between self-reported whole-body physician skin examination during the three years before either the melanoma diagnosis for cases or referent date for controls and assessed the odds of having received a clinician skin exam within strata of melanoma lesion thickness at diagnosis.^129^

#### Population Summary

Screening population sizes were not always reported, but when reported they ranged from 1,328 to 533,393 in screened groups and 248 to 1,489,074 for unscreened/usual care groups (Table 5).

The largest population was for the German National Screening Program,^135^ and the smallest was for the Belgian study.^132^ In total, 53,329 detected skin cancer or precursor lesions were reported in this included body of evidence (n=11,182 melanoma cases; 41,686 KC cases, and 461 precursor lesion cases).

Overall, the intended screening populations were broadly defined adult populations (Table 5). The Italian study also included adolescents aged 15 years and older (mean age 40.2 years, range 15–84 years).^130^ The screening populations were majority female, except for the Australian case-control study,^129^ which used age- and sex-matching to select control participants. The sex distribution of the case group was not reported, whereas the control group was 57 percent male.^129^ Only the U.S.-based study reported race and/or ethnicity for the screened group (88.4% White).^134^

Only the Belgian study reported measures of socioeconomic status, reporting the highest education level attained for both study groups.^132^ There was a statistically significant different distribution of educational categories between groups, with the total body exam (screening) group trending slightly toward a lower educational level than the lesion-directed screening group (45.8% with no more than a high school education in the total body exam group compared to 38.9% in the lesion-directed screening group; p<0.01 for trend).^132^

Only one study reported skin cancer risk factors for screening populations.^132^ In the Belgian study, distributions of Fitzpatrick skin type and nevus count were similar between the study groups (e.g., nevus counts of less than 25 were observed in 57.1% of the total body exam screening group and 58.0% of the lesion-directed exam group; p=0.96 for trend).^132^ Family history of skin cancer was also reported at similar frequencies between the two groups (10.7% of total body exam screening group and 13.1% of lesion directed exam group, p=0.17).^132^ Additionally, personal history of skin cancer was reported in similar small proportions of both study groups (2.4% in the total body exam screening group and 2.0% in the lesion directed exam group; p=0.84).

Demographic characteristics of detected cases were reported for three studies.^130,^ ^134,^ ^135^ Two of these reported age and sex distributions of detected cases,^130,^ ^135^ and one noted that 99.2% of melanomas were diagnosed in patients who identified their race as Non-Hispanic White.^134^ Risk factor characteristics were not reported for any detected case populations.

#### Quality

The single U.S.-based study was rated as good quality,^134^ and the five other nonrandomized studies were rated as fair quality.^129,^ ^130,^ ^132,^ ^133,^ ^135^ Quality concerns included unclear reporting of demographic and risk factors of study groups, unclear reporting of completeness of data and outcome assessment methods, handling of missing data, and the use of self-reported data for outcomes. In addition, one of the publications using German national screening data used a previously-published algorithm for estimating stage at melanoma detection from claims data, rather than direct observation of medical records, which could introduce misclassification errors.^133^ Staging conventions, stage categories, and melanoma thickness categories were heterogeneous across studies. None of the studies reported adjusting for lead time bias when reporting KQ2-relevant outcomes.

In the U.S.-based study, screened and unscreened groups were overall similar in age, sex, and insurance status, but some statistically significant differences were observed between screened and unscreened populations. The screened population was reported to be somewhat older (median age 60 years vs. 57 years, p<0.001), and race and/or ethnicity differed between groups (e.g., 6.8% of the screened population was Black, compared to 7.2% of the unscreened population, p<0.001).^134^ Further, insurance coverage appeared more generous in the screened population compared with the unscreened population (3.0% Medicaid in the screened group compared to 6.3% in the unscreened group; p<0.001). Outcomes, however, were adjusted for age, sex, and insurance status.^134^

#### Detailed Results

##### Melanoma

Melanoma detection rates. Five included publications reported data on overall melanoma detection rates associated with routine screening in three European skin cancer screening programs and in one United States health system-based skin cancer screening initiative (Table 12).^130,^ ^132–135^ Across all three European programs, overall melanoma detection rates were similar between screened populations compared to usual care or lesion-directed examination populations. One evaluation of the German program using AOK PLUS data from 2005–2012 found melanoma detection rates were similar in the group receiving routine screening (0.31% case detection rate) compared to those receiving usual care (0.13% case detection rate).^135^ A separate evaluation of the German program reported numbers of skin cancers detected but did not provide sufficient data to calculate the difference in detection rates.^133^ In the Belgian study, melanoma case detection rates were 0.5 percent in the total body exam group vs. 0.4 percent in the lesion-detected exam group, p=0.87.^132^ In the Italian screening program, the melanoma detection rate was 0.4 percent in both the screened group (initial screening and during the followup period after screening) and in the unscreened group.^130^ In the U.S.-based study, melanoma detection rates were higher in the group with documented skin exam compared to the group without (0.25% in screened group, 0.14% in unscreened group; p<0.001).^134^

Table 12 Skin Cancer or Precursor Lesion Detection Rates, Screened vs. Unscreened (KQ2)

Study, year Quality Country | Population Description | Participation Rate in Screening Program, % | Screening Population, N | Type of Skin Cancer or Precursor Lesion | Total Detected in the Screened Population, n (%) | Total Detected in the Comparison Population, n (%) | Between Group Difference
Cristofolini, 2015^130^; Fair; Italy | Screening: Residents of Trento, Italy, who participated in free whole-body skin screening program between January 2001 and Dec 2004; participants were followed until 2013 (excluding those with a history of melanoma); No routine screening: Residents of Trento, Italy 2005–2017 (excluding people with previous melanoma diagnosis) | NR | Routine screening: 3,635 (initial screening group); 3,618 (followup period); No routine screening: 307,679 | Melanoma | Screening group: 15 (0.4); Followup period: 14 (0.4) | 1,362 (0.4)^*^ | NR
Cristofolini, 2015^130^; Fair; Italy | | NR | Routine screening: 3,635 (initial screening group); 3,618 (followup period); No routine screening: 307,679 | BCC, SCC | Screening group:; BCC: 12 (0.3); SCC: 1 (0.03) | NR | NR
Cristofolini, 2015^130^; Fair; Italy | | NR | Routine screening: 3,635 (initial screening group); 3,618 (followup period); No routine screening: 307,679 | Dysplastic nevi | Dysplastic nevi: 11 (0.3) | NR | NR
Matsumoto, 2022^131,^ ^134^; Good US | Primary care patients age ≥35 years with office visit in 2014–2018; Routine screening: EHR documentation of full body skin examination during study period; No routine screening: no EHR documentation of full body skin examination during study period | NR | Routine screening: 144,851; No routine screening: 450,948 | Melanoma | 356 (0.25); Age-sex adjusted incidence per 100,000 person-years (95% CI): 65.3 (57.9–73.7) | 638 (0.14); Age-sex adjusted incidence per 100,000 person-years (95% CI): 42.2 (39.0–45.6) | AdjHR (95% CI): 1.8 (1.6–2.1); p<0.001^║^
Hoorens, 2016^132^; Fair; Belgium | Routine screening: participants receiving single TBE during 5-day screening event; No routine screening: participants in lesion-directed 4-day examination event | Routine screening: 17.9; No routing screening: 3.3 | Routine screening: 1,668; No routine screening: 248 | All skin cancer | 39 (2.3) | 8 (3.2) | Screened minus Unscreened (95% CI): −0.89 (−3.96 to 0.90); p=0.40
Hoorens, 2016^132^; Fair; Belgium | Routine screening: participants receiving single TBE during 5-day screening event; No routine screening: participants in lesion-directed 4-day examination event | Routine screening: 17.9; No routing screening: 3.3 | Routine screening: 1,668; No routine screening: 248 | Melanoma | 8 (0.5) | 1 (0.4) | Screened minus Unscreened (95% CI): 0.08 (−1.78 to 0.65); p=0.87
Hoorens, 2016^132^; Fair; Belgium | Routine screening: participants receiving single TBE during 5-day screening event; No routine screening: participants in lesion-directed 4-day examination event | Routine screening: 17.9; No routing screening: 3.3 | Routine screening: 1,668; No routine screening: 248 | BCC | 30 (1.8) | 7 (2.8) | Screened minus Unscreened (95% CI): −1.02 (−3.96 to 0.61); p=0.28
Hoorens, 2016^132^; Fair; Belgium | Routine screening: participants receiving single TBE during 5-day screening event; No routine screening: participants in lesion-directed 4-day examination event | Routine screening: 17.9; No routing screening: 3.3 | Routine screening: 1,668; No routine screening: 248 | SCC or Bowen disease | 1 (0.1) | 0 (0) | Screened minus Unscreened (95% CI): 0.06 (−1.47 to 0.34); p=0.99
Hoorens, 2016^132^; Fair; Belgium | Routine screening: participants receiving single TBE during 5-day screening event; No routine screening: participants in lesion-directed 4-day examination event | Routine screening: 17.9; No routing screening: 3.3 | Routine screening: 1,668; No routine screening: 248 | Actinic keratosis | 130 (7.9) | 22 (7.8) | NR, p=0.90
Hoorens, 2016^132^; Fair; Belgium | Routine screening: participants receiving single TBE during 5-day screening event; No routine screening: participants in lesion-directed 4-day examination event | Routine screening: 17.9; No routing screening: 3.3 | Routine screening: 1,668; No routine screening: 248 | Atypical nevi | 249 (15.1) | 49 (17.3) | NR, p=0.33
Krensel, 2020^133^; Fair; Germany | German national skin cancer screening program 2013–2016 | NR | NR | Melanoma | 815 (NR) | 721 (NR)^*^ | NR
Krensel, 2020^133^; Fair; Germany | German national skin cancer screening program 2013–2016 | NR | NR | NMSC/KC^†^ | 5,378 (NR) | 5,466 (NR) | NR
Trautmann, 2016^135^; Fair; Germany | German national skin cancer screening program 2005–2012 (Saxony) | 12.4 | Screened: 533,393; Unscreened: 1,489,074 | Melanoma | 1,668 (0.3) | 1,836 (0.1) | RR (95% CI): 2.50 (2.34 to 2.67)^§^
Trautmann, 2016^135^; Fair; Germany | German national skin cancer screening program 2005–2012 (Saxony) | 12.4 | Screened: 533,393; Unscreened: 1,489,074 | NMSC | 13,535 (2.5) | 17,256 (1.2) | RR (95% CI): 2.16 (2.11 to 2.21)§

* No routine screening.

† Nonmelanoma skin cancer/keratinocyte cancer (includes squamous cell carcinoma and basal cell carcinoma).

‡ Adjusted for age, sex, race/ethnicity, and insurance status.

§ Calculated; unadjusted.

║ Cox proportional hazard ratio, adjusted for age, sex, and White race

Abbreviations: Adj=Adjusted; BCC=Basal cell carcinoma; CI=Confidence interval; KC=Keratinocyte carcinoma; KQ=Key question; NMSC=Nonmelanoma skin cancer; NR=Not reported; RR=Relative risk; SCC=Squamous cell carcinoma; TBE=Total body examination.

Stage at melanoma detection. The three studies reporting data on stage at melanoma detection used heterogeneous stage categories (Table 13, Appendix E Figure 3). Two of these were analyses of German national screening program data. One analysis used AJCC stage categories, including in situ melanoma,^133^ and one analysis reported lymph node and distant metastases at detection.^135^ The U.S.-based study reported distributions of in situ versus various thickness categories of invasive melanoma.^134^

Table 13 Stage or Thickness at Melanoma or KC Detection, Screened vs. No Routine Skin Cancer Screening (KQ2)

Study, year Quality Country | Population description | Type of skin cancer | Cases detected, N | Stage or thickness at detection^*^ | Routine skin cancer screening n (% of cases); 95% CI | No routine skin cancer screening n (% of cases); 95% CI | Between group difference
Aitken 2010^129^; Fair; Australia | Cases: Queensland residents age 20–75 years diagnosed with histologically confirmed first primary invasive cutaneous melanoma^§§^ between Jan 1, 2000 and Dec 31, 2003 Controls: Adults selected from Queensland Electoral Roll using stratified random sampling based on 5-year age groups and sex distribution of cases (excluding those with confirmed melanoma diagnoses) | Melanoma | 3,762 | 0.01 to 0.75 mm^‖‖^ | 2049 (54.5) | NR | adjOR of clinical skin examination in 3 years prior to noticing lesion (95% CI)^††,^ ^‡‡^ 1.38 (1.22 to 1.56) [Control reference group]
Aitken 2010^129^; Fair; Australia | | Melanoma | 3,762 | 0.76 to 1.49 mm | 1017 (27.0) | NR | adjOR, 0.93 (0.79 to 1.10)
Aitken 2010^129^; Fair; Australia | | Melanoma | 3,762 | 1.50 to 2.99 mm | 443 (11.8) | NR | adjOR, 0.83 (0.66 to 1.05)
Aitken 2010^129^; Fair; Australia | | Melanoma | 3,762 | ≥3.00 mm | 253 (6.7) | NR | adjOR, 0.60 (0.43 to 0.83)
Aitken 2010^129^; Fair; Australia | | Melanoma | 3,762 | ≤0.75 mm | NR | NR | adjOR, 1.38 (1.22 to 1.56)
Aitken 2010^129^; Fair; Australia | | Melanoma | 3,762 | >0.75 mm | NR | NR | adjOR, 0.86 (0.75 to 0.98)
Cristofolini, 2015^130^; Fair; Italy | Screening: Residents of Trento, Italy, who participated in free whole-body skin screening program between January 2001 and Dec 2004; followup participants were followed until 2013 (those with a history of melanoma were excluded from this group); No routine screening: Residents of Trento, Italy 2005–2017 (excluding people with previous melanoma diagnosis) | Melanoma | 1,389 | In situ (screening period) | 1 person of 15 (6.7%) | NR | NR
Cristofolini, 2015^130^; Fair; Italy | | Melanoma | 1,389 | >1 mm (screening period) | 4/14=28.6% | NR | NR
Cristofolini, 2015^130^; Fair; Italy | | Melanoma | 1,389 | Mean (screening period) | 0.87 mm (median: 0.52 mm) | NR | NR
Cristofolini, 2015^130^; Fair; Italy | | Melanoma | 1,389 | <1 mm (screening + followup) | 19/27=70.4% | 786 (57.7) | Unadjusted difference between combined screening groups and unscreened group, p=0.242
Cristofolini, 2015^130^; Fair; Italy | | Melanoma | 1,389 | <2 mm (screening + followup) | 25/27=92.6% | 1,034 (75.9) | Unadjusted difference between combined screening groups and unscreened group, p=0.043
Cristofolini, 2015^130^; Fair; Italy | | Melanoma | 1,389 | In situ (followup screening group^¶^) | 0/13=0% | NR | NR
Cristofolini, 2015^130^; Fair; Italy | | Melanoma | 1,389 | <1 mm (followup screening group^¶^) | 9/13=69.2% | NR | NR
Cristofolini, 2015^130^; Fair; Italy | | Melanoma | 1,389 | >1 mm (followup screening group^¶^) | 4/13=30.8% | NR | NR
Cristofolini, 2015^130^; Fair; Italy | | Melanoma | 1,389 | Mean (followup screening group^¶^) | 0.83 mm (median 0.60 mm) | NR | NR
Matsumoto, 2022^131^; Good; US | Primary care patients age ≥35 years diagnosed with melanoma following office visit in 2014–2018 | Melanoma | Total: 994; Screened: 356; Unscreened: 638 | In situ | 172 (48.3) | 221 (34.6) | AdjHR (95% CI): 2.6 (2.1–3.1); p<0.001^¶¶^
Matsumoto, 2022^131^; Good; US | Primary care patients age ≥35 years diagnosed with melanoma following office visit in 2014–2018 | Melanoma | Total: 994; Screened: 356; Unscreened: 638 | ≤1 mm | 132 (37.1) | 238 (37.3) | AdjHR (95% CI): 1.8 (1.5–2.2); p<0.001^¶¶^
Matsumoto, 2022^131^; Good; US | Primary care patients age ≥35 years diagnosed with melanoma following office visit in 2014–2018 | Melanoma | Total: 994; Screened: 356; Unscreened: 638 | >1 mm | 52 (14.6) | 179 (28.1) | AdjHR (95% CI): 1.0 (0.7–1.3); p=0.75^¶¶^
Matsumoto, 2022^131^; Good; US | Primary care patients age ≥35 years diagnosed with melanoma following office visit in 2014–2018 | Melanoma | Total: 994; Screened: 356; Unscreened: 638 | >2 mm | 28 (7.9) | 101 (15.8) | AdjHR (95% CI): 0.9 (0.6–1.4); p=0.61)^¶¶^
Matsumoto, 2022^131^; Good; US | Primary care patients age ≥35 years diagnosed with melanoma following office visit in 2014–2018 | Melanoma | Total: 994; Screened: 356; Unscreened: 638 | >4 mm | 12 (3.4) | 51 (8.0) | AdjHR (95% CI): 0.8 (0.4–1.4); p=0.38^¶¶^
Krensel, 2020^133^,^†^; Fair; Germany | German national skin cancer screening program 2013–2016 | Melanoma | 1,536 | In situ | 10 (1.23); NR | In situ: 10 (1.43); NR | Screening – no screening (%): 0 (−0.20)
Krensel, 2020^133^,^†^; Fair; Germany | German national skin cancer screening program 2013–2016 | Melanoma | 1,536 | Stage I/II: | 799 (98.04); NR | 707 (98.09); NR | Screening – no screening (%): 92 (−0.05)
Krensel, 2020^133^,^†^; Fair; Germany | German national skin cancer screening program 2013–2016 | Melanoma | 1,536 | Stage III/IV: | 6 (0.74); NR | 3 (0.48); NR | Screening – no screening (%): 3 (0.26)
Krensel, 2020^133^,^†^; Fair; Germany | German national skin cancer screening program 2013–2016 | KC | 10,844 | In situ | 4 (0.07); NR | 10 (0.18); NR | Screening – no screening (%): −6 (−0.10)
Krensel, 2020^133^,^†^; Fair; Germany | German national skin cancer screening program 2013–2016 | KC | 10,844 | Stage I/II | 5373 (99.91); NR | 5454 (99.77); NR | Screening – no screening (%): −81 (0.13)
Krensel, 2020^133^,^†^; Fair; Germany | German national skin cancer screening program 2013–2016 | KC | 10,844 | Stage III/IV | 1 (0.02); NR | 3 (0.05); NR | Screening – no screening (%): −2 (−0.03)
Trautmann, 2016^135^; Fair; Germany | German national skin cancer screening program 2005–2012 (State of Saxony) | Melanoma | 3,504 | Lymph node metastasis | 98 (5.9); ~3.4% to ~9.6%^‡^ | 156 (8.5%); ~5.7%, ~10.4%^‡^ | NS
Trautmann, 2016^135^; Fair; Germany | German national skin cancer screening program 2005–2012 (State of Saxony) | Melanoma | 3,504 | Distant metastasis | 25 (1.5); ~0.4% to ~3.4%^‡^ | 64 (3.5) ~1.3%, ~7.8%^‡^ | NS^‡^

* Author-reported stage/thickness data categories.

† Uses TNM / AJCC staging system to report on melanoma and KC stage at detection. This information was calculated using an algorithm used in other publications for estimating stage from claims data.

‡ Estimated from the graphic representation of confidence intervals (point estimates of confidence intervals not reported).

§ Cases excluded due to missing information.

‖ Adjusted for age, sex, race/ethnicity, and insurance status.

¶ Data available on n=13/14 people.

** Sampling for this study included all cases in registry with thick (≥0.75 mm) melanoma and a 60% sample of cases with thinner melanoma (<0.75 mm).

†† Adjusted for age group, sex, education, employment status, marital status, eye color, hair color, skin color, degree of freckling, number of moles on back, age of arrival in Australia, average lifetime sun exposure, family history of melanoma, family history of nonmelanoma skin cancer, and ethnicity.

‡‡ Ascertained via self-report.

§§ Does not include acral lentiginous melanoma.

‖‖ Thickness categories comparable to thickness/depth categories used in SEER summary staging, localized stage (≤0.75 mm (II) 0.76–1.50 mm (III) >1.5 mm (IV), See Table 1.

¶¶ Cox proportional hazard ratio, adjusted for age, sex, and White race.

Abbreviations: Adj=Adjusted; CI=Confidence interval; Dec=December; EHR=Electronic health record; Jan=January; KC=Keratinocyte carcinoma; KQ=Key question; Mm=millimeter; NR=Not reported; NS=Not significant; OR=Odds ratio

Findings were inconsistent between two studies including in situ melanoma at detection. In the German study using AJCC stage categories (n=1536 melanoma cases), there was no association between screening and detection of in situ melanoma.^133^ In the U.S.-based study (n=994 melanoma cases), in situ melanoma made up a larger proportion of cases in the screened group compared to the unscreened group (48.3% of all melanomas detected at in situ stage in screened group vs 34.6% in unscreened group, adjusted hazard ratio [adjHR], 2.6 [95% CI, 2.1 to 3.1]; p<0.001).^134^

Findings were more consistent across two studies reporting stage at invasive melanoma only (i.e., excluding melanoma in situ); neither study found an association between skin cancer screening and stage at invasive melanoma detection. In the German study using AJCC stage categories (n=1536 melanoma cases), there was no difference between screened and unscreened groups at AJCC combined stages I/II, or combined stages III/IV at detection.^133^ In the German study using AOK PLUS data from 2005–2012 (n=3504 melanoma cases), lymph node metastasis and distant metastasis were observed at similar rates between screened and unscreened groups. For example, lymph node metastases at detection were similarly detected in persons with documented whole-body screening (5.9%), and those without such documentation (8.5 percent).^135^

Thickness at melanoma detection. Findings were inconsistent between three studies reporting data on heterogeneous categories of melanoma thickness at detection from three countries: the United States, Italy, and Australia (Table 13, Appendix E Figure 4).^129,^ ^130,^ ^134^ In the U.S.-based study, there was a higher adjusted hazard ratio in the screened group of detection at thickness ≤1mm (AJCC 7^th^ edition sub-category T1) (adjHR1.8, 95% CI, 1.5 to 2.2; p<0.001), but not in the greater than 1mm category (AJCC sub-category T2-T4) (adjHR 1.0, NS).^134^ In the Italian study of routine screening compared to usual care, the proportion of melanomas detected at <1mm thickness was similar between groups (70.4% in the screened group and 57.7% in the usual care group, p=0.242), but was higher for screen-detected melanomas detected at <2mm thickness (AJCC sub-category T3-T4; 92.6% of in the screened group and 75.9% of melanomas in the usual care group, p=0.043).^130^

In the Australian case-control study, 28.3 percent (1083 out of 3,824) of controls reported receiving a clinical skin exam by a physician within the previous 3 years compared to 35.3 percent (1328 out of 3,762) of melanoma cases. The odds of having had a clinical skin exam by a physician decreased as thickness increased in an inverse linear pattern: 7 percent decreased odds for lesions 0.76 to 1.49 mm (95% CI, 0.79 to 1.10); 17 percent decreased odds for lesions 1.50 to 2.99 mm (95% CI, 0.66 to 1.05); and 40 percent decreased odds for lesions ≥3.0 mm (95% CI, 0.43 to 0.83).^129^

##### Keratinocyte Cancer

Keratinocyte skin cancer detection. Four included studies provided data on KC rates associated with routine screening from three screening programs (Table 12).^130,^ ^132,^ ^133,^ ^135^ Two of these used data from Germany during the German National Screening Program at different periods. One found a similar KC detection rate in the screened population compared to those who were unscreened (2.5% vs 1.2%, RR [95% CI] 2.16 [2.11 to 2.21]).^135^ The other German study found similar numbers of KC cases in both screened and unscreened groups.^133^ The Belgian study, a comparison of total body exam compared to lesion-detected exam as a result of community skin examination events in two neighboring communities, reported similar detection rates of both BCC and SCC in both the total body exam group compared to the lesion-directed exam group (BCC 1.8% detection rate vs 2.8%, p=0.28; SCC 0.1% vs 0%, p=0.99).^132^ The Italian study only reported BCC (12 [0.3%]) and SCC (1 [0.03%]) identified in the screening population making comparisons to the unscreened population impossible.^130^

Keratinocyte skin cancer stage at detection. Only a single study reported the stage of KC detection (Table 13, Appendix E Figure 1). In the German program (n=10,844 KC cases), similar distributions of KC stage in each group were reported (99.9% of KC cases detected at stage I/II in screened group; 99.8% in unscreened group).^133^

Precursor lesion detection. Two studies – the Belgian study of one-time total body examination compared to one-time lesion-directed examination, and the Italian study of total body examination compared with no screening – reported rates of detection of skin cancer precursor lesions (Table 12, Appendix E Figure 2).^130,^ ^132^ In the Belgian study, rates of actinic keratoses and atypical nevi were similar in both groups. Actinic keratoses was detected in 7.9 percent of the total body exam group and 7.8 percent of the lesion-directed exam group (p=0.90). Atypical nevi were detected at 15.1 percent of the total body exam group and 17.3 percent of the lesion-directed group (p=0.33).^132^ As was the case with the KC data, in the Italian study the number of dysplastic nevi were only reported in the screening population (11 out of 3635 [0.3%]) and not the unscreened population.^130^

### Specific Population Results (KQ2a)

No studies reported KC detection rates or KC stage at detection comparisons stratified by specific population groups.

The Australian case-control study (n=7,586), reported age- and sex-specific adjusted odds of having reported a clinical skin exam by a physician in melanoma cases according to increasing thickness compared to controls (Table 14).^129^ The odds of having received a clinical skin exam followed similar patterns as the main result for age and sex subgroups, with thinner melanomas associated with higher odds of having received a clinical skin exam. Males with the thinnest melanomas (0.01mm to 0.75mm) were more likely to have received a clinical skin exam (adjOR 1.54, p<0.01), while males with the thickest melanomas (≥ 3mm) were less likely to have received a clinical exam (adjOR 0.62, p<0.05). The trend was present but not statistically significant among females.^129^ Within both age strata (age 20–49 and age 50–74, males and females combined) the highest odds of having received a clinical skin exam were observed for people with the thinnest melanomas (0.01mm–0.75mm), while people with the thickest melanomas (≥3mm) had the lowest odds of clinical skin exam.^129^

Table 14 Stage or Thickness at Melanoma Detection, Specific Populations, Routine Clinician Skin Examination Compared to Usual Care or No Screening (KQ2a)

Study, year Quality | Population N | Type of skin cancer or precursor lesion | Subgroup | Stage at detection^*^, n (% of cases); 95% CI Routine skin cancer screening | Stage at detection^*^, n (% of cases); 95% CI No routine skin cancer screening | Between group difference
Aitken 2010^129^; Fair | Cases: 3,762; Controls: 3,824 | Melanoma | Sex | NR | NR | Melanoma thickness at detection: adjOR of clinical skin examination in 3 years prior to noticing lesion (95% CI)^†^,^‡^; Males; 0.01 to 0.75 mm: 1.54 (1.31 to 1.82), p<0.01 0.76 to 1.49 mm: 0.96 (0.78 to 1.19), NS 1.50 to 2.99 mm: 0.85 (0.63 to 1.15), NS ≥3.00 mm: 0.62 (0.42 to 0.91), P<0.05; Females; 0.01 to 0.75 mm: 1.20 (0.99 to 1.45), NS 0.76 to 1.49 mm: 0.90 (0.70 to 1.16), NS 1.50 to 2.99 mm: 0.79 (0.54 to 1.16), NS ≥3.00 mm: 0.55 (0.29 to 1.03), NS
Aitken 2010^129^; Fair | Cases: 3,762; Controls: 3,824 | Melanoma | Age | NR | NR | Melanoma thickness at detection adjOR of clinical skin examination in 3 years prior to noticing lesion (95% CI)^†^,^‡^; Age 20–49 yrs; 0.01 to 0.75 mm: 1.32 (1.08 to 1.62), p<0.05 0.76 to 1.49 mm: 0.98 (0.76 to 1.27), NS 1.50 to 2.99 mm: 0.67 (0.41 to 1.07), NS ≥3.00 mm: 0.48 (0.22 to 1.06), NS; Age 50–74 yrs; 0.01 to 0.75 mm: 1.43 (1.22 to 1.67), p<0.01 0.76 to 1.49 mm: 0.91 (0.74 to 1.12), NS 1.50 to 2.99 mm: 0.90 (0.68 to 1.18), NS ≥3.00 mm: 0.62 (0.43 to 0.89) p<0.05
Cristofolini, 2015^30^; Fair | Routine screening: 3,635 (screening group); 3,618 (followup screening group)No routine screening: 307,679 | Melanoma | Sex | Screening group: Male: 9/15=60% Female: 6/15=40%; Followup screening group: Male: 5/14=35.7% Female: 9/14=64.3%; Breslow thickness; Screening group:; Mean thickness; Female: 0.65 mm (median 0.52 mm); Male: 1.15 mm (median 0.825 mm); Thickness <1 mm: 10/14=71.4% (3 male, 7 female); Thickness >1 mm: 4/14=28.6% (3 male, 1 female); Followup screening group:; Mean thickness; Female: 0.61 mm (median 0.45 mm); Male: 1.19 mm (median 1.10 mm); Thickness <1 mm: 9/13=69.2% (2 male, 7 female); Thickness >1 mm: 4/13=30.8% (3 male, 1 female) | NR | NR

* Author-reported stage/thickness data categories.

† Adjusted for age group, sex, education, employment status, marital status, eye color, hair color, skin color, degree of freckling, number of moles on back, age of arrival in Australia, average lifetime sun exposure, family history of melanoma, family history of nonmelanoma skin cancer, and ethnicity.

‡ Ascertained via self-report.

Abbreviations: Adj=Adjusted; CI=Confidence intervals; KQ=Key question; NR=Not reported; NS=Not significant; Mm=millimeter; OR=Odds ratio.

The Italian study reported melanoma detection and thickness by sex and age in the screening population (n=3,635) (Table 14).^130^ During the initial screening period, the majority of those with melanoma <1mm thick were females (7 of 10), whereas the majority of those with melanoma >1mm thick were males (3 of 4). This pattern was mirrored in the followup period (n=3,618).

The U.S.-based study reported melanoma detection rates and thickness at detection among those age 65 and older (Table 15). Findings were similar to those in the full study population. For example, melanoma detection rates were higher in the screened population (0.33%) compared to the unscreened population (0.21%; adjHR 1.6 [95% CI, 1.3 to 2.0]; p<0.001). In addition, in situ melanomas made up a larger proportion of melanoma cases in the screened group (45.8%) compared with the unscreened group (38.5%; adjHR 1.9 [95% CI, 1.4 to 2.6]; p<0.001). There was a higher adjusted hazard ratio in the screened group for detection at thickness ≤1mm (adjHR 1.9 [95% CI, 1.3 to 2.6]; p<0.001) but not for thickness >1mm (adjHR 1.0 [95% CI, 0.7 to 1.6]; p=0.90).^134^

Table 15 Melanoma Detection Rates and Thickness at Melanoma Detection, Population Age ≤65, Screening Compared to No Screening (KQ2a)

Study, year Quality | Population N | Melanoma detected in screened population; N (%) | Melanoma detected in unscreened population; N (%) | Between group difference; adjHR (95% CI)^*^; p-value | Stage at detection | Screened group; n (% of cases) | Unscreened group; n (% of cases) | Between group difference; adjHR (95% CI)^*^; p-value
Matsumoto, 2022^131,^ ^134^; Good; US | Age ≥65 years screened: 47,603; Age ≥65 years unscreened: 127,777 | 155 (0.33); Adj incidence per 100,000 person-years (95% CI): 98.7 (83.2–117.2)^†^ | 270 (0.21); Adj incidence per 100,000 person years (95% CI): 66.5 (58.7– 75.3)^†^ | 1.6 (1.3–2.0); p<0.001 | In situ | 71 (45.8) | 104 (38.5) | 1.9 (1.4–2.6); p<0.001
Matsumoto, 2022^131,^ ^134^; Good; US | Age ≥65 years screened: 47,603; Age ≥65 years unscreened: 127,777 | 155 (0.33); Adj incidence per 100,000 person-years (95% CI): 98.7 (83.2–117.2)^†^ | 270 (0.21); Adj incidence per 100,000 person years (95% CI): 66.5 (58.7– 75.3)^†^ | 1.6 (1.3–2.0); p<0.001 | ≤1 mm | 56 (36.1) | 83 (30.7) | 1.9 (1.3–2.6); p<0.001
Matsumoto, 2022^131,^ ^134^; Good; US | Age ≥65 years screened: 47,603; Age ≥65 years unscreened: 127,777 | 155 (0.33); Adj incidence per 100,000 person-years (95% CI): 98.7 (83.2–117.2)^†^ | 270 (0.21); Adj incidence per 100,000 person years (95% CI): 66.5 (58.7– 75.3)^†^ | 1.6 (1.3–2.0); p<0.001 | >1 mm | 28 (18.1) | 83 (30.7) | 1.0 (0.7–1.6); p=0.90
Matsumoto, 2022^131,^ ^134^; Good; US | Age ≥65 years screened: 47,603; Age ≥65 years unscreened: 127,777 | 155 (0.33); Adj incidence per 100,000 person-years (95% CI): 98.7 (83.2–117.2)^†^ | 270 (0.21); Adj incidence per 100,000 person years (95% CI): 66.5 (58.7– 75.3)^†^ | 1.6 (1.3–2.0); p<0.001 | >2 mm | 16 (10 .3) | 60 (22.2) | 0.8 (0.5–1.4); p=0.42
Matsumoto, 2022^131,^ ^134^; Good; US | Age ≥65 years screened: 47,603; Age ≥65 years unscreened: 127,777 | 155 (0.33); Adj incidence per 100,000 person-years (95% CI): 98.7 (83.2–117.2)^†^ | 270 (0.21); Adj incidence per 100,000 person years (95% CI): 66.5 (58.7– 75.3)^†^ | 1.6 (1.3–2.0); p<0.001 | >4 mm | 5 (3.2) | 33 (12.2) | 0.5 (0.2–1.2); p=0.11

* Cox proportional hazard ratio, adjusted for age, sex, and White race.

† Adjusted for age and sex.

## KQ3. What Are the Harms of Skin Cancer Screening and Diagnostic Followup? Do the Harms of Screening Vary by Subgroups (e.g., Age, Sex, Skin Type, Race/Ethnicity, Socioeconomic Status, or UV Exposure)?

### Summary of Results

We identified only two small fair-quality nonrandomized studies that explicitly addressed the harms of skin cancer screening. One was conducted in Germany (n=45)^136^ and assessed cosmetic acceptance of shave biopsy in a screened population at 6-month followup; lesions suspected of melanoma were excluded. The other was conducted in the United States (n=187)^137,^ ^138^ and assessed psychological wellbeing at 5 and 8 months after screening.

In the German study, 27 patients rated 7 percent (4 out of 56) of shave sites as having poor cosmetic outcomes at 6-month followup (median score 1.5, IQR [1–2], excellent to good). In the U.S.-based study of adults who underwent skin cancer screening by trained primary care providers (n=187), participants at 5- and 8-month followup assessment scored within the normal range on measures of anxiety, depression, or none to minimal psychological impacts of screening.

### Detailed Results

#### Overview of Included Studies

Two fair-quality nonrandomized studies^136,^ ^138^ (n=232) met inclusion criteria, one of which was brought forward from the previous review (Tables 3–5).^136^ One German study examined the cosmetic harms of shave biopsy excision.^136^ The other study set in the United States reported on the potential psychological harms^137,^ ^138^ of skin cancer screening. The U.S. study was an evaluation of the same physician-focused decision support intervention that was included for KQ2^134^ and was newly identified since the previous review. No included studies for KQ1 reported harms data. No included studies reported on procedure-related adverse events beyond 30 days (e.g., scar revisions) in screened populations.

One small study was conducted in Germany (n=45) in 2000 (Table 16).^136^ This study assessed patient-reported cosmetic acceptance of deep shave excisions at 6-months of followup after excision. Only razor blade excisions of macular melanocytic nevi less than 15 mm in diameter were included in this study; lesions suspected of melanoma were excluded. Participants were identified during routine skin cancer screening before the implementation of the German National Screening Program.

Table 16 Cosmetic Harms of Routine Skin Cancer Screening or Diagnostic Workup (KQ3)

Study, year Quality Country | Population | Procedure and Provider Type | Harms Assessment | Reported Harms
Gambichler, 2000^136^; Fair; Germany | 45 patients (51% women) with a mean age of 32 years who had been identified by skin cancer screening with 77 nevi and received biopsy; 25 patients and 56 shave sites were examined for cosmetic harms at 6-month followup | Deep shave excision with razor blade biopsy | Assessed on a 4-point scale 6 months after excision (scale: 1=excellent, 2=good, 3=moderate, 4=poor) | Patients: median score=1.5, (IQR 1–2, excellent to good)^†^ 7.1% (4 of 56) shave sites were rated as having poor cosmetic outcomes

† Calculated.

Abbreviations: KQ=key question. IQR=interquartile range.

The other study was conducted in a United States academic medical center (n=187)^137,^ ^138^ (Table 17). Primary care providers who had completed an online training program for detecting and diagnosing skin cancer conducted skin cancer screenings. This study used various scales to estimate patient-reported psychological harms (e.g., anxiety, depression, physical and social consequences) and health-related quality of life at 5 and 8 months after screening. The study compared results between two screened patient groups—patients classified as those with “full body exam” and those with “partial body exam.” Another comparison examined psychological indicators among patients who underwent biopsy following screening and those without biopsy at 5 months after screening. Although only people with skin cancer screening documented in their electronic medical record were included, group allocation was based on patients’ self-reported screening and experience (i.e., recall of screening, the level of undress, and body parts examined).

Table 17 Psychological Measures and Quality of Life Among Individuals Who Reported Full-Body Skin Cancer Screening and Those Who Reported Partial Body Examination (KQ3)

Study, Year Quality | Measure | Construct | Scoring range | Interpretation | 5-month followup result, median (range), p | 8-month followup result, median (range), p
Risica, 2018^137,^ ^138^; Fair | Hospital Anxiety and Depression scale (HADS-A) | Anxiety | 0 to 21 | <8 No depression or anxiety; 8–10 Mild; 11–14 Moderate; 15–21; Severe; For anxiety and depression separately. | Full body exam^*^: 3.5 (0– 15); Partial body exam^†^: 4 (0– 18); p=0.9 | Full body exam^*^: 3 (0–14); Partial body exam^†^: 4 (0– 16); p=0.6
Risica, 2018^137,^ ^138^; Fair | Hospital Anxiety and Depression scale (HADS-D) | Depression | 0 to 21 | <8 No depression or anxiety; 8–10 Mild; 11–14 Moderate; 15–21; Severe; For anxiety and depression separately. | Full body exam^*^: 1 (0–20); Partial body exam^†^: 2 (0– 15); p=0.1 | Full body exam^*^: 1 (0–19); Partial body exam^†^: 2 (0– 12); p=0.3
Risica, 2018^137,^ ^138^; Fair | Spielberger State-Trait Anxiety Index – form 6 (STAI-6) | Anxiety | 20 to 80 | Higher score indicates greater disease severity. In research, individuals with >44 points are often referred to as being highly anxious. | Full body exam^*^: 23.3 (20–70); Partial body exam^†^: 26.7 (20–80); p=0.6 | Full body exam^*^: 23.3 (20– 80); Partial body exam^†^: 23.3 (20–63.7); p=0.6
Risica, 2018^137,^ ^138^; Fair | Psychological Consequences Questionnaire (PCQ) | Negative emotional consequences | 0 to 15 | Higher score indicates greater distress from screening. | Full body exam^*^: 0 (0–9); Partial body exam^†^: 0 (0– 8); p=0.5 | Full body exam^*^: 0 (0–10); Partial body exam^†^: 0 (0– 11); p=0.8
Risica, 2018^137,^ ^138^; Fair | Psychological Consequences Questionnaire (PCQ) | Negative physical consequences | 0 to 12 | Higher score indicates greater distress from screening. | Full body exam^*^: 0 (0–5); Partial body exam^†^: 0 (0– 4); p=0.3 | Full body exam^*^: 0 (0–8); Partial body exam^†^: 0 (0– 10); p=0.8
Risica, 2018^137,^ ^138^; Fair | Psychological Consequences Questionnaire (PCQ) | Negative social consequences | 0 to 9 | Higher score indicates greater distress from screening. | Full body exam^*^: 0 (0–8); Partial body exam^†^: 0 (0– 6); p=0.7 | Full body exam^*^: 0 (0–7); Partial body exam^†^: 0 (0–9); p=0.8
Risica, 2018^137,^ ^138^; Fair | Psychological Consequences Questionnaire (PCQ) | Positive emotional consequences | 0 to 15 | Higher score indicates greater positive effect from screening. | Full body exam^*^: 6 (0–15); Partial body exam^†^: 4 (0– 15); p=0.0002 | Full body exam^*^: 7 (0–15); Partial body exam^†^: 6 (0– 15); p=0.6
Risica, 2018^137,^ ^138^; Fair | Psychological Consequences Questionnaire (PCQ) | Positive physical consequences | 0 to 9 | Higher score indicates greater positive effect from screening. | Full body exam^*^: 0 (0–9); Partial body exam^†^: 0 (0– 9); p=0.4 | Full body exam^*^: 0 (0–9); Partial body exam^†^: 0 (0–9); p=0.9
Risica, 2018^137,^ ^138^; Fair | Psychological Consequences Questionnaire (PCQ) | Positive social consequences | 0 to 6 | Higher score indicates greater positive effect from screening. | Full body exam^*^: 0 (0–6); Partial body exam^†^: 0 (0– 6); p=0.5 | Full body exam^*^: 0 (0–6); Partial body exam^†^: 0 (0–6); p=0.8
Risica, 2018^137,^ ^138^; Fair | Psychological Consequences Questionnaire (PCQ) | 12-Item Short Form Health Survey, Physical Component Summary (SF-12 PCS) | Health-related Quality of life: physical component | 0 to 100 | The US population average is 50 points. Higher scores indicate better-perceived health. | Full body exam^*^: 40.6 (30.9–47.3); Partial body exam^†^: 40.5 (31.4–48.7); p=0.7 | Full body exam^*^: 41.0 (4.0); Partial body exam^†^: 40.4 (3.8); p=0.4
Risica, 2018^137,^ ^138^; Fair | Psychological Consequences Questionnaire (PCQ) | 12-Item Short Form Health Survey, Mental Component Summary (SF-12 MCS) | Health-related Quality of life: mental component | 0 to 100 | The US population average is 50 points. Higher scores indicate better-perceived health. | Full body exam^*^: 49.3 (36.9–56.6); Partial body exam^†^: 49.1 (28.5–60.5); p=0.4 | Full body exam^*^: 49.2 (28.6–56.9); Partial body exam^†^: 49.5 (35.5–59.2); p=0.02

* Full body examination defined as patients reporting that they had their skin thoroughly examined by their PCP (based on questions that included if screening was performed, the level of undress, and whether certain body parts were examined).

† Partial body examination defined as patients reporting that they did not have their whole body screened by their PCP, did not disrobe, or did not have certain body parts examined.

Abbreviations: KQ=Key Question; PCP=Primary care physician; US=United States.

#### Population Summary

The German study included persons aged 15–54 years (mean age 32 years);^136^ the other study included adults aged 35 years and older (Table 5).^138^ An estimated 44.4 percent of total participants in both studies were females.

In the U.S.-based study,^137,^ ^138^ 89.8 percent of participants were White, and 5.3 percent were Black. In this study, 20.9 percent of participants had a personal history of skin cancer, 58.6 percent had a family history of melanoma, and 40.1 percent had received previous skin exams.

#### Quality

Both included studies for this key question were rated fair quality. Both were nonrandomized cross-sectional studies with a very small number of participants and no unscreened comparator group. In the German study,^136^ only 60 percent (27 out of 45) of recruited persons evaluated cosmetic outcomes of the shave sites. The results do not assess cosmetic results from excisional biopsies needed for melanoma diagnosis, which are more invasive procedures. Further, this study reports the number of shave sites, rather than the number of patients dissatisfied with the shave sites’ appearance. The U.S.-based study^137,^ ^138^ did not assess for psychological or quality of life outcomes at baseline. The authors compared outcomes between two groups of patients based on the patients’ recall of whether part of their body was examined or whether their whole body was examined for skin cancer five months prior to completing the survey.

#### Detailed Results by Outcome

A fair-quality study of routine outpatient cancer screening (n=45 patients, 56 deep shave excisions) assessed patients’ perceptions of the cosmetic acceptance of deep shave excisions of macular melanocytic nevi with the razor blade technique at 6-months of followup (Table 16).^136^ Patients used a four-point scale (1=excellent, 2=good, 3=moderate, or 4=poor) to evaluate cosmetic outcomes with no prespecified judgment criteria. The median patient evaluation score was similar (1.5) and IQR [1–2] (excellent to good). Patients judged 7 percent (4 of 56) of shave sites as having poor cosmetic outcomes, 4 percent (2) as moderate outcomes, 39 percent (22) as good outcomes, and 50 percent (28) as excellent outcomes.

A fair-quality study^137,^ ^138^ estimated the potential for psychological harms and health-related quality of life after skin cancer screening among 187 adults at 5-months of followup and 126 (67.4% of 187) at 8-months of followup (Table 17). This study also estimated the potential for psychological harms associated with skin biopsy among 186 patients at 5-months following skin cancer screening.^137^ This study assessed patients’ anxiety and depression with the Hospital Anxiety and Depression rating scale (HADS), general anxiety with the Spielberger State-Trait Anxiety Index—form 6 (STAI-6), positive and negative psychological impacts of screening with the Psychological Consequences Questionnaire (PCQ), and health-related quality of life with the 12-Item Short-Form Health Survey (SF-12).

Participants had undergone skin cancer screening and were classified as having “full body examined” or only “partial body exam.” Participants in both groups scored within the normal range on various scales, with no indication of anxiety, depression, or other negative psychological impacts from screening at 5- and 8-month followup assessment.^138^ Participants with skin biopsy (n=23) and without biopsy (n=163) also scored within the normal range on psychological scales. Overall, there were no meaningful differences in psychological indicators between biopsied and non-biopsied patients.^137^

#### Specific Population Results (KQ3a)

We did not identify evidence on the potential harms of screening for specific populations.

## KQ4. What Is the Association Between Detection of Precancerous Lesions or Earlier Stage Skin Cancer and Morbidity and Mortality Due to Skin Cancer or All-Cause Mortality? Does This Association Vary by Subgroups (e.g., Age, Sex, Skin Type, Race/Ethnicity, Socioeconomic Status, or UV Exposure)?

### Summary of Results

In three included nonrandomized studies (two good-quality, one fair-quality; n=407,133) reporting melanoma-specific mortality and three nonrandomized studies (one good-quality, two fair-quality; n=473,660) reporting all-cause mortality, progression of stage at detection was consistently and positively associated with increased risk of melanoma mortality. Risk estimates varied according to referent groups used. Compared to in situ disease at detection, adjusted hazard ratios for melanoma mortality were 5.8 (95% CI, 5.3 to 6.3) for localized, 31.5 (95% CI, 28.9 to 34.2) for regional, and 169.6 (95% CI, 154.2 to 186.6) for distant stage in one U.S.-based study (n=185,219).^146^ Two studies using localized stage at detection as the referent group found a similar pattern of increasing melanoma mortality risk with increasing stage.

In two studies (one good-quality, one fair-quality; n=135,490), melanoma mortality was higher for males than for females. Three studies (n=708,814) that examined melanoma mortality risk with respect to racial and ethnic groups found a higher risk among Black, Hispanic, and Asian American, Native American or Pacific Islander (AANAPI) adults compared with White adults. One of these found similar odds of melanoma mortality risk for White and Black persons within each stage of detection. In the other two studies with overlapping populations, melanoma mortality risk was higher among Black, Hispanic, and AANAPI adults with melanoma AJCC Stage I and SEER localized stages compared to White adults. One of these studies also demonstrated a higher risk of melanoma mortality among Hispanic persons with regional or distant melanoma stages compared with White adults.

Regarding all-cause mortality, the same pattern was observed over three large nonrandomized studies using varying referent groups. In one study (n=185,219), the risk for all-cause mortality was adjHR 1.5 (95% CI, 1.5 to 1.5) for localized, 3.9 (95% CI, 3.8 to 4.1) for regional, and 15.8 (95% CI, 14.9 to 16.7) for distant disease, compared to in situ melanoma at detection.

No included studies addressed KC mortality by stage at detection. We did not identify studies that evaluated the association between stage at diagnosis and skin cancer morbidity.

### Detailed Results

#### Overview of Included Studies

A total of nine fair- or good-quality nonrandomized studies with data collected between 1975 and 2016 (n=1,326,051) were included^139–143,^ ^145–147^ (Tables 18–23). All nine studies were newly identified since the prior recommendation; however, some studies had overlapping populations. Seven studies (n=1,037,610) reported the association between stage at diagnosis and melanoma mortality,^139,^ ^140,^ ^142–146^ and three studies^141,^ ^146,^ ^147^ (n=473,660) reported the association between the stage of melanoma at diagnosis and all-cause mortality in adults. No included studies evaluated the association between stage at diagnosis and skin cancer morbidity. No studies contributed data for KC mortality.

Table 18 Study Characteristics, Included Studies (KQ4)

Study, Year Quality Country | Population | N | Data source Years of data collection Staging system | Measure of risk | Adjustment variables | Outcomes assessed (melanoma mortality, all-cause mortality) | Summary of analyses for KQ4; Referent group | Specific population group for KQ4a
Dawes, 2016^139^; Fair; US | Adults diagnosed with primary cutaneous melanoma | 96,953 | SEER-13 registry database; 1992–2009; AJCC | HR | None | Melanoma mortality | NR | 1. Race group by stage I–IV (White vs. Black).; Referent group: White persons, within each stage strata.; 2. Race/ethnicity group (White, AANAPI, Black, Hispanic) by age group (0–24 years, 25–49 years, 50–74 years, ≥75 years).; 3. Referent group: White persons, within each stage strata.
Enninga, 2017^209^; Fair; US | Adults age ≥18 years with primary cutaneous melanoma | 106,511 | SEER-13 registry database; 1992–2011 (followup for deaths was until 2012); SEER | HR | Age (main analysis only) | Melanoma mortality | NR | 1. Analyses stratified by stage at diagnosis (females vs. males).; Referent group: female persons, within each stage strata.; 2. Females vs. males, stratified analysis by stage and age group (18–45 years, 46–54 years, ≥55 years).; Referent group: female persons, within each stage strata.
Farrow, 2020^141^; Fair; US | Adults age ≥18 years with melanoma | 268,668 | National Cancer Database 2004–2015 AJCC | Adjusted HR | Age, sex, race, insurance coverage, income, education, and CD score, tumor characteristics (stage, location, margin positivity), and facility characteristics (academic vs. comprehensive community vs. community hospital, facility location) | All-cause mortality | Risk estimates by stage at diagnosis (Stages I– IV); Referent group: Stage IV | NR
Khosrotehrani, 2015^‡^,^142^; Good; Australia | Individuals age 15–89 years with primary melanoma | 28,979 | Queensland Cancer Registry (Australia); 1995–2008 (melanoma-specific deaths were ascertained up to 2010); AJCC | OR | Age, sex, body site, thickness of primary tumor, ulceration, nodal spread, metastasis | Melanoma mortality | NR | 1. Analyses stratified by stage at diagnosis (males vs. females).; Referent group: male persons, within each stage strata.; 2. Males vs. females, stratified analysis by stage and age group (15–45 years, 46–59 years, ≥60 years).; Referent group: male persons, within each stage strata.
Mahendraraj, 2017^143^; Fair US | White and Black adults diagnosed with cutaneous melanoma | 213,827 | SEER registry database^*^; 1988–2011; SEER | OR | Age, gender, ethnicity, geographic region, tumor histology, site, depth, stage, grade, lymph node status, presence of ulceration, type of treatment received | Melanoma mortality | Multivariable risk estimates by stage at diagnosis (localized, regional, and distant).; Referent group: Localized stage | Multivariable risk estimates provided for White and Black persons independently^†^.; Referent group: Localized stage.
Qian, 2021^144^; Fair US | Adults with cutaneous (95.7%), mucosal (1.2%), and uveal (3.1%) melanoma diagnosed between 1975 and 2016 | 398,034 | SEER registry database; 1975–2016 (data analysis was stratified by years of data collection: 1975–1999; 2000–2009; 2010–2016) | HR | Age, gender, primary site, histologic subtype, and stage | Melanoma mortality | NR | 1. Race/ethnicity group (Hispanic, Black, API, AIAN) by stage (localized, regional, distant); Referent group: White persons, within each stage strata.; 2. Race/ethnicity group (Hispanic, Black, API, AIAN) by stage (localized, regional, distant) for age ≥65 years; Referent group: White persons, within each stage strata.
Robsahm, 2018^145^; Good Norway | Individuals age 2–98 years diagnosed with primary melanoma | 8,087 | Norwegian Malignant Melanoma Registry, which is part of the Cancer Registry of Norway; 2008–2012 (followup for deaths was until 2015); SEER | HR | Age, sex, anatomic site, melanoma subtype, T-stage, ulceration, second primary melanoma | Melanoma mortality | Risk estimates by stage at diagnosis (localized, regional, and distant).; Referent group: Localized stage | NR
Ward-Peterson-2016^146^; Good US | Adults age ≥18 diagnosed with primary cutaneous melanoma | 185,219 | SEER registry database; 1982–2011; SEER | HR | Age, sex, decade of diagnosis, site at diagnosis, stage at diagnosis | Melanoma mortality; All-cause mortality | Risk estimates by stage at diagnosis (in situ, localized, regional, and distant).; Referent group: In situ melanoma | NR
Zheng, 2020^147^; Fair; Sweden | Adults diagnosed with first melanoma | 19,773 | Swedish Cancer Registry; 2003–2015; Tumor (T), node (N), and metastasis (M) components of AJCC | HR | Age, gender, year of diagnosis, tumor thickness, ulceration and histology, locoregional and distant metastasis, diagnosis of second primary cancer | All-cause mortality | Stratified risk estimated within T (primary tumor), N (regional lymph nodes) and M (distant metastasis) components.; Referent groups: T: T1a (≤1.0 mm with no ulceration or mitosis) N: N0 M: M0 | NR

* The SEER registries pulled from include: Alaska Native Tumor Registry, Arizona Indians, Cherokee Nation, Connecticut, Detroit, Georgia Center for Cancer Statistics, Greater Bay Area Cancer Registry, Greater California, Hawaii, Iowa, Kentucky, Los Angeles, Louisiana, New Jersey, New Mexico, Seattle-Puget Sound, and Utah.

† Authors refer to the analyzed groups as Caucasian and African American persons.

‡ Additionally, this study used the SEER data collected between 1995 and 2010 to compare the risk (ORs) for melanoma mortality between females and males at I, II, and combined III and IV AJCC stages (n=57,402). For this review, we did not analyze the US data/estimates as another included study (Enninga, 2017)140 used HRs to compare the risk in these two groups with the data collected over a longer period—1992 to 2011 (n=106,511).

Abbreviations: AANAPI=Asian American/Native American/Pacific Islander; AJCC=American Joint Committee on Cancer; CD=Charlson-Deyo; HR=Hazard ratio; KQ=Key Question; NR=Not reported; OR=Odds ratio; SEER=Surveillance, Epidemiology, and End Results Program; US=United States

Table 19 Melanoma Stage at Diagnosis and Melanoma Mortality (KQ4)

Author, Year Quality | Years of data collection Country | Study N | Mean age, years | Female, % | Race/Ethnicity, % | History of skin cancer screening, % | Summary stage, SEER | Stage distribution at diagnosis, % | Melanoma deaths, n | Risk of melanoma mortality
Mahendraraj, 2017^210^; Fair | 1988–2011; US | 213,827 | Entire population: 58.9^‖^; White: 58.9; Black: 60.5 | 43.0 | White: 99.5; Black: 0.5; Other/Mixed: 0 | Hx of SC: NR; Family Hx of SC: NR | Localized | 82.4 | NR | Referent group
Mahendraraj, 2017^210^; Fair | 1988–2011; US | 213,827 | Entire population: 58.9^‖^; White: 58.9; Black: 60.5 | 43.0 | White: 99.5; Black: 0.5; Other/Mixed: 0 | Hx of SC: NR; Family Hx of SC: NR | Regional | 9.5 | NR | OR^‡^, 3.8 (95% CI, 3.5 to 4.1)
Mahendraraj, 2017^210^; Fair | 1988–2011; US | 213,827 | Entire population: 58.9^‖^; White: 58.9; Black: 60.5 | 43.0 | White: 99.5; Black: 0.5; Other/Mixed: 0 | Hx of SC: NR; Family Hx of SC: NR | Distant | 3.8 | NR | OR^‡^, 7.5 (95% CI, 6.3 to 8.9)
Mahendraraj, 2017^210^; Fair | 1988–2011; US | 213,827 | Entire population: 58.9^‖^; White: 58.9; Black: 60.5 | 43.0 | White: 99.5; Black: 0.5; Other/Mixed: 0 | Hx of SC: NR; Family Hx of SC: NR | Unstaged | 4.3 | NR | --
Robsahm, 2018^145^; Good | 2008–2012 (followup for deaths was until 2015); Norway | 8,087 | 60.5^‖^; 64 (median) | 50.1 | NR | NR | Local | 91.8 | 438 | Referent group
Robsahm, 2018^145^; Good | 2008–2012 (followup for deaths was until 2015); Norway | 8,087 | 60.5^‖^; 64 (median) | 50.1 | NR | NR | Regional | 5.0 | 156 | adjHR^†^, 4.00 (95% CI, 3.26 to 4.90)
Robsahm, 2018^145^; Good | 2008–2012 (followup for deaths was until 2015); Norway | 8,087 | 60.5^‖^; 64 (median) | 50.1 | NR | NR | Distant | 3.2 | 159 | adjHR^†^, 16.82 (95% CI, 12.88 to 21.95)
Ward-Peterson, 2016^146^; Good | 1982–2011; US | 185,219 | Mean: 57.2^‖^ | 43.0 | White: 91.7; Black: 1.7; Other/Mixed: NR | Hx of SC: NR; Family Hx of SC: NR | In situ | 32.8 | NR | Referent group
Ward-Peterson, 2016^146^; Good | 1982–2011; US | 185,219 | Mean: 57.2^‖^ | 43.0 | White: 91.7; Black: 1.7; Other/Mixed: NR | Hx of SC: NR; Family Hx of SC: NR | Localized | 56.8 | NR | adjHR^*^, 5.8 (95% CI, 5.3 to 6.3)
Ward-Peterson, 2016^146^; Good | 1982–2011; US | 185,219 | Mean: 57.2^‖^ | 43.0 | White: 91.7; Black: 1.7; Other/Mixed: NR | Hx of SC: NR; Family Hx of SC: NR | Regional | 7.9 | NR | adjHR^*^, 31.5 (95% CI, 28.9 to 34.2)
Ward-Peterson, 2016^146^; Good | 1982–2011; US | 185,219 | Mean: 57.2^‖^ | 43.0 | White: 91.7; Black: 1.7; Other/Mixed: NR | Hx of SC: NR; Family Hx of SC: NR | Distant | 2.5 | NR | adjHR^*^, 169.6 (95% CI, 154.2 to 186.6)

* Adjusted for age, gender, decade of diagnosis, site at diagnosis, and stage at diagnosis.

† Adjusted for sex, age, anatomic site, melanoma subtype, T-stage, ulceration, and second primary melanoma.

‡ Unadjusted.

‖ Calculated, weighted mean.

Abbreviations: Adj=Adjusted; CI=Confidence interval; HR=Hazard ratio; Hx=History; KQ=Key Question; NR=Not reported; OR=Odds ratio; SC=Skin cancer; SD=Standard deviation; SEER=Surveillance, Epidemiology, and End Results Program; US=United States.

Table 20 Melanoma Stage at Diagnosis and All-Cause Mortality (KQ4)

Author, Year (Study) Quality | Data Collection Country | Study N | Mean Age, years | Female, % | Race/Ethnicity, % Hx of SC, % | Stage | Stage Distribution at Diagnosis, % | All-Cause Mortality, n | All-Cause Mortality adjHR, 95% CI
Farrow, 2020^140^; Fair | 2004–2015; US | 268,668 | 61^*^ | 42.4 | White: 98.7; Black: 0.6; Other/mixed race: NR; Hx of SC: NR Family; Hx of SC: NR | I | 8.3 | NR | 0.09 (0.08 to 0.10)^†^
Farrow, 2020^140^; Fair | 2004–2015; US | 268,668 | 61^*^ | 42.4 | White: 98.7; Black: 0.6; Other/mixed race: NR; Hx of SC: NR Family; Hx of SC: NR | II | 43.4 | NR | 0.19 (0.18 to 0.20)^†^
Farrow, 2020^140^; Fair | 2004–2015; US | 268,668 | 61^*^ | 42.4 | White: 98.7; Black: 0.6; Other/mixed race: NR; Hx of SC: NR Family; Hx of SC: NR | II | 36.6 | NR | 0.38 (0.36 to 0.40)^†^
Farrow, 2020^140^; Fair | 2004–2015; US | 268,668 | 61^*^ | 42.4 | White: 98.7; Black: 0.6; Other/mixed race: NR; Hx of SC: NR Family; Hx of SC: NR | IV | 11.7 | NR | Referent group
Ward-Peterson, 2016^146^; Good | 1982–2011; US | 185,219 | 57.2 | 43.0 | White: 91.7; Black: 1.7; Other/mixed race: NR; Hx of SC: NR Family; Hx of SC: NR | In situ | 32.8 | NR | Referent group
Ward-Peterson, 2016^146^; Good | 1982–2011; US | 185,219 | 57.2 | 43.0 | White: 91.7; Black: 1.7; Other/mixed race: NR; Hx of SC: NR Family; Hx of SC: NR | Localized | 56.8 | NR | 1.5 (1.5 to 1.5)^‡^
Ward-Peterson, 2016^146^; Good | 1982–2011; US | 185,219 | 57.2 | 43.0 | White: 91.7; Black: 1.7; Other/mixed race: NR; Hx of SC: NR Family; Hx of SC: NR | Regional | 7.9 | NR | 3.9 (3.8 to 4.1)^‡^
Ward-Peterson, 2016^146^; Good | 1982–2011; US | 185,219 | 57.2 | 43.0 | White: 91.7; Black: 1.7; Other/mixed race: NR; Hx of SC: NR Family; Hx of SC: NR | Distant | 2.5 | NR | 15.8 (14.9 to 16.7)^‡^
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | Total | NR | 3,182 (calculated) | NA
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | T1a | 48.0 | 664 | Referent group
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | T1b | 7.8 | 127 | 1.44 (1.20 to 1.73)^§^
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | T2a | 16.3 | 349 | 1.46 (1.28 to 1.66)^§^
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | T2b | 3.9 | 142 | 2.38 (1.98 to 2.86)^§^
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | T3a | 7.3 | 369 | 2.71 (2.36 to 3.11)^§^
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | T3b | 5.9 | 425 | 3.71 (3.23 to 4.27)^§^
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | T4a | 3.6 | 313 | 4.37 (3.72 to 5.13)^§^
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | T4b | 7.3 | 793 | 5.90 (5.17 to 6.74)^§^
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | N0^‖^ | 71.2 | 1,700 | Referent group
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | Nx^‖^ | 26.3 | 1,225 | 1.29 (1.11 to 1.50)^§^
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | N+^‖^ | 2.5 | 257 | 2.24 (1.82 to 2.75)^§^
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | M0^¶^ | 69.2 | 1,661 | Referent group
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | Mx^¶^ | 29.9 | 1,395 | 0.92 (0.79 to 1.07)^§^
Zheng, 2020^147^; Fair | 2003–2015; Sweden | 19,773 | 65.3 | 50.9 | White: NR; Black: NR; Other/mixed race: NR; Hx of melanoma: 0; Family Hx of SC: NR | M+^¶^ | 0.9 | 126 | 3.17 (2.40 to 4.19)^§^

* Median.

† Adjusted for age, gender, race, insurance coverage, income, education, and CD score, tumor characteristics (stage, location, margin positivity), and facility characteristics (academic vs. comprehensive community vs. community hospital, facility location).

‡ Adjusted for age, gender, decade of diagnosis, site at diagnosis, stage at diagnosis.

§ Adjusted for age, gender, year of diagnosis, tumor thickness, ulceration and histology, locoregional and distant metastasis, diagnosis of second primary cancer.

‖ Locoregional metastasis to lymph nodes.

¶ Distant metastasis.

Abbreviations: Adj=Adjusted; CD=Charlson-Deyo; CI=Confidence interval; HR=Hazard ratio; Hx=History; KQ=Key Question; NR=Not reported; SC=Skin cancer; US=United States.

Table 21 Melanoma Stage at Diagnosis and Melanoma Mortality, by Race and/or Ethnicity (KQ4a)

Author, Year Quality | Data Collection Country | Study N | Race/Ethnicity Group | Age Group, years | Stage, SEER and AJCC | Stage Distribution at Diagnosis, % | Melanoma Deaths, n | Risk of Melanoma Mortality
Mahendraraj, 2017^143^; Fair | 1988–2011; US | 213,827 | White | All ages (mean 58.8 [SD 17.12]) | Local | 82.5 | 19,207 | Referent group
Mahendraraj, 2017^143^; Fair | 1988–2011; US | 213,827 | White | All ages (mean 58.8 [SD 17.12]) | Regional | 9.5 | 19,207 | OR, 3.0 (95% CI, 2.8 to 3.2)
Mahendraraj, 2017^143^; Fair | 1988–2011; US | 213,827 | White | All ages (mean 58.8 [SD 17.12]) | Distant | 3.7 | 19,207 | OR, 4.7 (95% CI, 4.0 to 5.4)
Mahendraraj, 2017^143^; Fair | 1988–2011; US | 213,827 | White | All ages (mean 58.8 [SD 17.12]) | Unstaged | 4.3 | 19,207 | --
Mahendraraj, 2017^143^; Fair | 1988–2011; US | 213,827 | Black | All ages (mean 60.5 [SD 18.16]) | Local | 56.3 | 241 | Referent group
Mahendraraj, 2017^143^; Fair | 1988–2011; US | 213,827 | Black | All ages (mean 60.5 [SD 18.16]) | Regional | 21.9 | 241 | OR, 4.3 (95% CI, 2.5 to 7.3)
Mahendraraj, 2017^143^; Fair | 1988–2011; US | 213,827 | Black | All ages (mean 60.5 [SD 18.16]) | Distant | 14.3 | 241 | OR, 3.7 (95% CI, 1.3 to 10.5)
Mahendraraj, 2017^143^; Fair | 1988–2011; US | 213,827 | Black | All ages (mean 60.5 [SD 18.16]) | Unstaged | 7.5 | 241 | --
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | White | All ages (≥0) | I | 75.97 | NR | Referent group
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | White | All ages (≥0) | II | 12.93 | NR | Referent group
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | White | All ages (≥0) | III | 6.65 | NR | Referent group
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | White | All ages (≥0) | IV | 4.45 | NR | Referent group
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | All ages (≥0) | I | 52.68 | NR | HR, 3.04 (95% CI, 2.34 to 3.95)^*^
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | All ages (≥0) | II | 22.82 | NR | HR, 1.34 (95% CI, 0.92 to 1.95)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | All ages (≥0) | III | 13.42 | NR | HR, 1.86 (95% CI, 1.21 to 2.87)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | All ages (≥0) | IV | 11.07 | NR | HR, 1.03 (95% CI, 0.68 to 1.57)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | 0 to 24 | I | -- | NR | HR, 5.80 (0.79 to 42.34)^*^
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | 0 to 24 | II | -- | NR | HR, 9.50 (1.23 to 73.62)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | 0 to 24 | III | -- | NR | HR, 1.34e-8 (0.0 to Inf.)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | 0 to 24 | IV | -- | NR | HR, 3.62e-8 (0.0 to Inf.)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | 25 to 49 | I | -- | NR | HR, 2.98 (1.33 to 6.65)^*^
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | 25 to 49 | II | -- | NR | HR, 1.52 (0.49 to 4.72)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | 25 to 49 | III | -- | NR | HR, 2.36 (1.05 to 5.30)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | 25 to 49 | IV | -- | NR | HR, 2.18 (1.13 to 4.22)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | 50 to 74 | I | -- | NR | HR, 2.76 (1.83 to 4.15)^*^
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | 50 to 74 | II | -- | NR | HR, 1.33 (0.81 to 2.19)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | 50 to 74 | III | -- | NR | HR, 1.71 (0.85 to 3.44)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | 50 to 74 | IV | -- | NR | HR, 0.94 (0.47 to 1.89)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | ≥75 | I | -- | NR | HR, 2.36 (1.60 to 3.47)^*^
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | ≥75 | II | -- | NR | HR, 1.45 (0.72 to 2.90)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | ≥75 | III | -- | NR | HR, 1.23 (0.58 to 2.60)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Black | ≥75 | IV | -- | NR | HR, 0.79 (0.33 to 1.91)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | All ages (≥0) | I | 61.17 | NR | NR
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | All ages (≥0) | II | 16.48 | NR | NR
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | All ages (≥0) | III | 12.13 | NR | NR
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | All ages (≥0) | IV | 10.22 | NR | NR
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | 0–24 | I | -- | NR | HR, 2.52 (0.61 to 10.46)^*^
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | 0–24 | II | -- | NR | HR, 5.15e-7 (0.0 to Inf.)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | 0–24 | III | -- | NR | HR, 1.33e-8 (0.0 to Inf.)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | | IV | -- | | HR, 2.01 (0.47 to 8.57)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | 25–49 | I | -- | NR | HR, 2.70 (1.73 to 4.21)^*^
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | 25–49 | II | -- | NR | HR, 0.71 (0.26 to 1.90)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | 25–49 | III | -- | NR | HR, 1.11 (0.53 to 2.35)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | 25–49 | IV | -- | NR | HR, 1.22 (0.71 to 2.07)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | 50–74 | I | -- | NR | HR, 2.59 (2.02 to 3.33)^*^
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | 50–74 | II | -- | NR | HR, 1.48 (0.97 to 2.2)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | 50–74 | III | -- | NR | HR, 1.57 (0.99 to 2.47)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | 50–74 | IV | -- | NR | HR, 1.13 (0.78 to 1.65)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | ≥75 | I | -- | NR | HR, 1.51 (1.11 to 2.06)^*^
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | ≥75 | II | -- | NR | HR, 0.85 (0.52 to 1.40)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | ≥75 | III | -- | NR | HR, 1.34 (0.79 to 2.30)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | AANAPI | ≥75 | IV | -- | NR | HR, 1.15 (0.68 to 1.78)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | All ages (≥0) | I | 69.17 | NR | NR
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | All ages (≥0) | II | 15.33 | NR | NR
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | All ages (≥0) | III | 9.36 | NR | NR
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | All ages (≥0) | IV | 6.14 | NR | NR
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | 0–24 | I | -- | NR | HR, 1.71 (0.61 to 4.81)^*^
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | 0–24 | II | -- | NR | HR, 3.75 (1.22 to 11.56)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | 0–24 | III | -- | NR | HR, 1.35e-8 (0.0 to Inf.)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | 0–24 | IV | -- | NR | HR, 0.79 (0.27 to 2.27)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | 25–49 | I | -- | NR | HR, 1.94 (1.53 to 2.46)^*^
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | 25–49 | II | -- | NR | HR, 1.70 (1.19 to 2.42)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | 25–49 | III | -- | NR | HR, 0.82 (0.52 to 1.29)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | 25–49 | IV | -- | NR | HR, 0.53 (0.31 to 0.90)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | 50–74 | I | -- | NR | HR, 1.99 (1.69 to 2.34)^*^
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | 50–74 | II | -- | NR | HR, 1.31 (0.99 to 1.74)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | 50–74 | III | -- | NR | HR, 1.16 (0.82 to 1.63)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | 50–74 | IV | -- | NR | HR, 1.04 (0.79 to 1.37)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | ≥75 | I | -- | NR | HR, 1.28 (1.06 to 1.56)^*^
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | ≥75 | II | -- | NR | HR, 1.16 (0.83 to 1.63)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | ≥75 | III | -- | NR | HR, 1.49 (0.85 to 2.60)
Dawes 2016^139^; Fair | 1992–2009; US | 96,953 | Hispanic | ≥75 | IV | -- | NR | HR, 1.04 (0.61 to 1.78)

* White=Referent group.

Abbreviations: AANAPI=Asian American/Native American/Pacific Islander; Adj=Adjusted; AJCC=American Joint Committee on Cancer; CI=Confidence interval; HR=Hazard ratio; KQ=Key Question; NR=Not reported; OR=Odds ratio; SD=Standard deviation; SEER=Surveillance, Epidemiology, and End Results Program; US=United States.

Table 22. Melanoma Stage at Diagnosis and Melanoma Mortality, by Race and/or Ethnicity (KQ4a) From Qian 2021 Study (n=398,034)^*^

Author, Year Quality Country | Age Group | Race/Ethnicity Group | Stage, SEER | Stage Distribution at Diagnosis, % | Risk of Melanoma Mortality, adj HR (95% CI) 1975–2000 | Risk of Melanoma Mortality, adj HR (95% CI) 2000–2009 | Risk of Melanoma Mortality, adj HR (95% CI) 2010–2016
Author, Year Quality Country | Age Group | Race/Ethnicity Group | Stage, SEER | Stage Distribution at Diagnosis, % | n=85,609 (all ages) | n=164,192 (all ages) | n=148,233 (all ages)
Qian, 2021; Fair; US | All ages (n=398,034) | White | Localized | 77.1 | Referent group | Referent group | Referent group
Qian, 2021; Fair; US | All ages (n=398,034) | White | Regional | 8.8 | Referent group | Referent group | Referent group
Qian, 2021; Fair; US | All ages (n=398,034) | White | Distant | 3.8 | Referent group | Referent group | Referent group
Qian, 2021; Fair; US | All ages (n=398,034) | Hispanic^†^ | Localized | 66.5 | 1.05 (0.90–1.24) | 1.44 (1.26–1.66) | 1.54 (1.21–1.96)
Qian, 2021; Fair; US | All ages (n=398,034) | Hispanic^†^ | Regional | 14.2 | 1.01 (0.83–1.22) | 1.32 (1.17–1.49) | 1.56 (1.30–1.87)
Qian, 2021; Fair; US | All ages (n=398,034) | Hispanic^†^ | Distant | 6.8 | 0.83 (0.66–1.05) | 1.06 (0.92–1.23) | 1.17 (0.99–1.38)
Qian, 2021; Fair; US | All ages (n=398,034) | Black^†^ | Localized | 51.1 | 1.49 (1.12–1.98) | 1.92 (1.44–2.57) | 4.08 (2.70–6.16)
Qian, 2021; Fair; US | All ages (n=398,034) | Black^†^ | Regional | 20.5 | 1.62 (1.22–2.15) | 1.49 (1.19–1.86) | 1.74 (1.24–2.45)
Qian, 2021; Fair; US | All ages (n=398,034) | Black^†^ | Distant | 13.6 | 1.33 (1.00–1.76) | 0.78 (0.60–1.01) | 1.01 (0.74–1.39)
Qian, 2021; Fair; US | All ages (n=398,034) | Asian or Pacific Islander^†^ | Localized | 58.6 | 1.19 (0.90–1.58) | 1.46 (1.09–1.94) | 2.19 (1.41–3.40)
Qian, 2021; Fair; US | All ages (n=398,034) | Asian or Pacific Islander^†^ | Regional | 18.2 | 1.17 (0.88–1.56) | 1.26 (1.02–1.56) | 1.28 (0.85–1.93)
Qian, 2021; Fair; US | All ages (n=398,034) | Asian or Pacific Islander^†^ | Distant | 10.4 | 1.18 (0.86–1.62) | 1.03 (0.81–1.32) | 1.68 (1.27–2.23)
Qian, 2021; Fair; US | All ages (n=398,034) | American Indian or Alaska Native^†^ | Localized | 69.2 | 0.79 (0.42–1.46) | 1.20 (0.68–2.12) | 2.14 (1.02–4.50)
Qian, 2021; Fair; US | All ages (n=398,034) | American Indian or Alaska Native^†^ | Regional | 12.9 | 2.30 (1.27–4.16) | 1.19 (0.75–1.90) | 2.86 (1.66–4.94)
Qian, 2021; Fair; US | All ages (n=398,034) | American Indian or Alaska Native^†^ | Distant | 5.7 | 1.25 (0.59–2.62) | 0.64 (0.31–1.35) | 0.77 (0.37–1.61)
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | White | Localized | NR | Referent group | Referent group | Referent group
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | White | Regional | NR | Referent group | Referent group | Referent group
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | White | Distant | NR | Referent group | Referent group | Referent group
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | Hispanic^†^ | Localized | NR | 0.94 (0.68–1.29) | 1.54 (1.11–2.14) | 1.49 (1.01–2.22)
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | Hispanic^†^ | Regional | NR | 1.11 (0.80–1.53) | 1.45 (0.86–2.45) | 1.76 (1.06–2.94)
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | Hispanic^†^ | Distant | NR | 1.22 (0.82–1.81) | 0.92 (0.80–1.06) | 1.24 (0.005–318.2)
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | Black^†^ | Localized | NR | 1.28 (0.81–2.02) | 1.54 (0.37–6.42) | 4.19 (1.91–9.19)
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | Black^†^ | Regional | NR | 1.39 (0.93–2.08) | 1.53 (0.15–15.3) | 1.71 (0.31–9.30)
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | Black^†^ | Distant | NR | 1.55 (1.03–2.33) | 0.81 (0.68–0.97) | 1.21 (0.74–2.00)
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | Asian or Pacific Islander^†^ | Localized | NR | 1.26 (0.78–2.04) | 1.36 (0.1–17.73) | 1.24 (0–17225.3)
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | Asian or Pacific Islander^†^ | Regional | NR | 1.57 (1.06–2.30) | 1.31 (0.61–2.81) | 1.48 (0.02–143.3)
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | Asian or Pacific Islander^†^ | Distant | NR | 1.31 (0.85–2.03) | 1.16 (0.58–2.33) | 1.68 (0.48–5.89)
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | American Indian or Alaska Native^†^ | Localized | NR | 0.99 (0.32–3.08) | 1.14 (0.28–4.70) | 1.85 (0.38–8.99)
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | American Indian or Alaska Native^†^ | Regional | NR | 2.82 (1.17–6.80) | 1.65 (0.57–4.79) | 1.96 (0.17–22.74)
Qian, 2021; Fair; US | Age ≥65 (n=162,456) | American Indian or Alaska Native^†^ | Distant | NR | NR | NR | NR

* Number of melanoma deaths not reported.

† White=Referent group.

Abbreviations: AANAPI=Asian American/Native American/Pacific Islander; Adj=Adjusted; AJCC=American Joint Committee on Cancer; CI=Confidence interval; HR=Hazard ratio; KQ=Key Question; NR=Not reported; OR=Odds ratio; SD=Standard deviation; SEER=Surveillance, Epidemiology, and End Results Program; US=United States.

Table 23 Melanoma Stage at Diagnosis and Melanoma Mortality, Sex and Age Group (KQ4a)

Author, Year (Study) Quality | Data Collection Country | Study N | Sex | Age Group, years | Stage, SEER and AJCC | Stage Distribution at Diagnosis, % | Melanoma Deaths, n | Risk of Melanoma Mortality
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Females | ≥18 | Localized | 85.9 | 1,423 | Referent group
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Females | ≥18 | Regional | 8.5 | 1,195 | Referent group
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Females | ≥18 | Distant | 2.5 | 791 | Referent group
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Females | ≥18 | Unstaged | 3.0 | -- | Referent group
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Males | ≥18 | Localized | 81.4 | 2,856 | adjHR, 1.59 (95% CI, 1.49 to 1.70)^*^
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Males | ≥18 | Regional | 11.1 | 2,444 | adjHR, 1.37 (95% CI, 1.28 to 1.47)^*^
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Males | ≥18 | Distant | 4.2 | 1,706 | adjHR, 1.10 (95% CI, 1.01 to 1.20)^*^
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Males | ≥18 | Unstaged | 3.3 | -- | --
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Males | 18–45 | Localized | -- | -- | HR, 2.05 (95% CI, 1.79 to 2.35)
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Males | 18–45 | Regional | -- | | HR, 1.65 (95% CI, 1.42 to 1.92)
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Males | 18–45 | Distant | -- | | HR, 1.14 (95% CI, 0.93 to 1.38)
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Males | 46–54 | Localized | -- | -- | HR, 1.89 (95% CI, 1.62 to 2.20)
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Males | 46–54 | Regional | -- | | HR, 1.40 (95% CI, 1.18 to 1.66)
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Males | 46–54 | Distant | -- | | HR, 1.07 (95% CI, 0.86 to 1.33)
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Males | ≥55 | Localized | -- | -- | HR, 1.42 (95% CI, 1.30 to 1.54)
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Males | ≥55 | Regional | -- | | HR, 1.25 (95% CI, 1.14 to 1.36)
Enninga, 2017^140^; Fair | 1992–2011 (followup for deaths was until 2012); US | 106,511 | Males | ≥55 | Distant | -- | | HR, 1.09 (95% CI, 0.99 to 1.21)
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Males | ≥15 | I | 87 | -- | Referent group
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Males | ≥15 | II | 12 | -- | Referent group
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Males | ≥15 | III, IV | 1 | -- | Referent group
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Males | ≥15 | Unknown | 5 | -- | Referent group
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Females | ≥15 | I | 83 | 1,712 for the entire study population | adjOR^†^, 0.64 (95% CI, 0.51 to 0.82)
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Females | ≥15 | II | 16 | 1,712 for the entire study population | adjOR^†^, 0.71 (95% CI, 0.58 to 0.87)
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Females | ≥15 | III, IV | 1 | 1,712 for the entire study population | adjOR^†^, 0.70 (95% CI, 0.44 to 1.10)
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Females | ≥15 | Unknown | 6 | 1,712 for the entire study population | --
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Females | 15–45 | I | -- | -- | adjOR^†^, 0.80 (95% CI, 0.51 to 1.17)
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Females | 15–45 | II | -- | | adjOR^†^, 0.56 (95% CI, 0.33 to 0.98)
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Females | 15–45 | III, IV | -- | | adjOR^†^, 0.88 (95% CI, 0.30 to 2.58)
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Females | 46–59 | I | -- | -- | adjOR^†^, 0.81 (95% CI, 0.53 to 1.23)
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Females | 46–59 | II | -- | | adjOR^†^, 0.95 (95% CI, 0.61 to 1.49)
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Females | 46–59 | III, IV | -- | | adjOR^†^, 1.76 (95% CI, 0.66 to 3.80)
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Females | ≥60 | I | -- | -- | adjOR^†^, 0.43 (95% CI, 0.30 to 0.63)
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Females | ≥60 | II | -- | | adjOR^†^, 0.70 (95% CI, 0.55 to 0.89)
Khosrotehrani, 2015^142^; Good | 1995–2008 (melanoma-specific deaths were ascertained up to 2010); Australia | 28,979 | Females | ≥60 | III, IV | -- | | adjOR^†^, 0.46 (95% CI, 0.24 to 0.87)

* Male:Female (Female=Referent category), adjusted for age.

† Female:Male (Male=Referent category); adjusted for sex, age, body site and thickness of the primary tumor, ulceration, nodal spread, and metastasis.

Abbreviations: Adj=Adjusted; AJCC=American Joint Committee on Cancer; CI=Confidence interval; HR=Hazard ratio; KQ=Key Question; OR=Odds ratio; SEER=Surveillance, Epidemiology, and End Results Program; US=United States.

No studies included in the 2016 review were carried forward for this KQ due to the change in our inclusion criteria to focus on stage at detection rather than independently on melanoma thickness, which is included in the AJCC staging criteria.

#### Population Summary

Studies used large databases with patient information from the United States (SEER, National Cancer Database), Australia (Queensland Cancer Registry), Norway (data from the Norwegian Malignant Melanoma Registry matched with data from other sources), and Sweden (Swedish Cancer Registry). The six U.S.-based studies used the SEER and National Cancer Database data collected between 1975 and 2016 (median data collection period 22 [range 11 to 41] years) with the longest period in the U.S.-based Qian 2021^144^ study. Studies not conducted in the United States used data that were collected between 2003–2005 in Sweden,^147^ 2008–2012 in Norway,^145^ and 1995–2008 in Australia.^142^

Although the patient populations across the included United States studies overlap, these studies differed in the outcomes they presented (i.e., all-cause mortality, melanoma-specific mortality), melanoma staging systems they used (AJCC or SEER), referent stages the authors used to estimate the risk of melanoma mortality, and subgroup analysis (Table 18).

The weighted average age across all included studies was 59.0 years. Across included studies, 45.4 percent of all participants were female. All six U.S.-based studies provided information on participants’ race and/or ethnicity.^139–141,^ ^143,^ ^144,^ ^146^ Most participants in these studies (96.0%) were white, 0.7% were Black, 0.8% were Asian American or Pacific Islanders, 0.2% were American Indian or Alaska Natives, and 3.0% of participants were of Hispanic ethnicity. Participants’ personal, family, or environmental risk factors for skin cancer were rarely reported.

#### Quality

Among the nine included studies, six^139–141,^ ^143,^ ^144,^ ^147^ were rated fair- and three^142,^ ^145,^ ^146^ were rated good-quality nonrandomized studies. The included studies used large national-level databases with the data systematically collected over many decades (i.e., SEER, Swedish Cancer Registry, Queensland Cancer Registry [Australia], Norwegian Malignant Melanoma Registry). The followup time was sufficient to observe mortality.

Quality concerns were primarily related to the limitations of nonrandomized studies using retrospectively collected data, which include the incompleteness and inaccuracy of the collected data, incompleteness of individual-level data, and unreported handling of missing data. For example, miscoding and missing data in the SEER database resulted in a restaging of a large number of diagnoses.^158,^ ^159^ In addition, the included studies either did not report how they handled missing data or reported omitting missing data from their analyses.

#### Detailed Results by Outcome

##### Melanoma Mortality and Stage at Diagnosis

Overall, seven fair- and good-quality studies reported an association between the stage of melanoma at diagnosis and melanoma mortality using either the AJCC or SEER stages (Table 19).^139,^ ^140,^ ^142–146^ Four studies contributed data only for specific populations (see Specific Population Results subsection).^139,^ ^140,^ ^142,^ ^144^

All three studies^143,^ ^145,^ ^146^ with estimates across all participants demonstrated a consistent and statistically significant increase in the risk of melanoma mortality with disease progression. Two large U.S.-based studies using SEER staging with overlapping populations used different referent categories.^143,^ ^146^ A good-quality Ward-Peterson 2016 study (n=185,219) compared the risk for melanoma mortality at localized, regional, and distant melanoma with in situ melanoma diagnosed between 1982 and 2011.^146^ Using in situ melanoma as the reference category, the adjusted HR of risk for melanoma mortality was 5.8 (95% CI, 5.3 to 6.3) for localized, 31.5 (95% CI, 28.9 to 34.2) for regional, and 169.6 (95% CI, 154.2 to 186.6) for distant stages. The fair-quality Mahendraraj 2017 study (n=213,827) also demonstrated a statistically significantly increased risk of melanoma mortality at regional (OR, 3.8 [95% CI, 3.5 to 4.1]) and distant (OR, 7.5 [95% CI, 6.3 to 8.9]) stages compared to the reference group of local disease.^143^ Another smaller study using SEER staging of 8,087 Norwegian adults demonstrated a trend similar to the U.S. studies—increasing risk for melanoma mortality within disease progression. Using the localized stage as the reference category, the adjusted risk of melanoma mortality was adjHR 4.00 (95% CI, 3.26 to 4.90) for regional disease and 16.82 (95% CI, 12.88 to 21.95) for distant disease.^145^

##### All-Cause Mortality and Stage at Diagnosis

Two fair-quality studies and one good-quality study (n=473,660) reported an association between the stage of melanoma at diagnosis and all-cause mortality in adults (Table 20). The studies used the AJCC,^141^ SEER,^146^ and tumor, node, metastasis (TNM)^147^ sub-stages.

Two U.S.-based studies with overlapping populations (Farrow 2020 and Ward-Peterson 2016) used different staging systems. The Farrow 2020 study (n=268,668)^141^ used the AJCC’s stage IV as a referent stage and demonstrated that the risk for all-cause mortality was statistically significantly lower in patients with earlier stages. The risk of all-cause mortality was 62 percent lower in persons with stage III (adjHR, 0.38 [95% CI, 0.36 to 0.40]), 81 percent lower among those with stage II (adjHR, 0.19 [95% CI, 0.18 to 0.20]), and 91 percent lower in persons diagnosed with stage I (adjHR, 0.09 (95% CI, 0.08 to 0.10]), compared to persons diagnosed with stage IV melanoma between 2004 and 2015. The Ward-Peterson 2016 study used the SEER stages of in situ, localized, regional, and distant melanoma for adults diagnosed between 1982 and 2011. This study demonstrated similar results—disease progression is statistically significantly associated with a higher risk of all-cause mortality. In this study, the risk of all-cause mortality was 50 percent higher in persons with the localized stage (adjHR, 1.5 [95% CI, 1.5 to 1.5]), 290 percent higher in persons with the regional stage (adjHR, 3.9 [95% CI, 3.8 to 4.1]), and 1,480 percent higher among persons diagnosed with distant melanoma (adjHR, 15.8 [95% CI, 14.9 to 16.7]), compared with the reference group of in situ melanoma.

A third study^147^ using TNM sub-staging of 19,773 Swedish adults found an increased risk of all-cause mortality within each T, N, and M stages. For example, the risk for all-cause mortality was statistically significantly higher among persons diagnosed with T4b (adjHR, 5.90 [95% CI, 5.17 to 6.74]) compared to those diagnosed with T1a, higher in persons diagnosed with N+ (adjHR, 2.24 [95% CI, 1.82 to 2.75]) compared to those with N0, and higher in those with M+ (adjHR, 3.17 [95% CI, 2.40 to 4.19]) compared to patients with the M0 substage.

##### Mortality and Lesion Thickness at Diagnosis

Lesion thickness at diagnosis was not an exposure of interest for this review, as the association of increasing tumor thickness and melanoma mortality was previously established by the systematic review to support the 2016 recommendation.^106^ Two included studies (n=27,860)^145,^ ^147^ also reported the association between melanoma thickness and risk for either all-cause or melanoma mortality. Consistent with the prior review, both studies showed an increased risk for either all-cause or melanoma mortality with increasing melanoma thickness at diagnosis.

In the Zheng 2020 study (n=19,773), the risk for all-cause mortality was higher among persons diagnosed with T4a (adjHR, 4.37 [95% CI, 3.72 to 5.13]) compared to those diagnosed with T1a.^147^ In the Robsahm 2018 study (n=8,087), the risk for melanoma mortality was also statistically significantly higher among persons diagnosed with T4 (adjHR 9.68 [95% CI, 7.06 to 13.28]) compared to persons diagnosed with T1.^145^

### Specific Population Results (KQ4a)

Three overlapping studies provided estimates of melanoma mortality risk stratified by race and/or ethnicity (Table 21). The Dawes 2016 study (n=96,953) used AJCC stages and White persons as a reference group to estimate the risk for melanoma mortality among Black, AANAPI, and Hispanic persons diagnosed with melanoma between 1992 and 2009.^139^ This study demonstrated that Black persons, compared to White persons, had a statistically significantly higher risk of melanoma mortality at stages I (HR, 3.04 [95% CI, 2.34 to 3.95]) and III (HR, 1.86 [95% CI, 1.21 to 2.87]), but not at stages II (HR, 1.34 [95% CI, 0.92 to 1.95]) and IV (HR, 1.03 [95% CI, 0.68 to 1.57]). Additionally, the risk for melanoma mortality was statistically significantly higher among Black, AANAPI, and Hispanic adults aged 25–49, 50–74, and ≥75 years with melanoma stage I compared with White adults. Among pediatric patients and young adults aged 0–24 years, Black (HR, 9.50 [95% CI, 1.23 to 73.62]) and Hispanic (HR, 3.75 [95% CI, 1.22 to 11.56]) patients with stage II melanoma had a higher risk for melanoma mortality than White patients. The Qian 2021 study^144^ (n=398,034) used SEER stages and White persons as a reference group to estimate the risk for melanoma mortality among Black, Asian or Pacific Islanders (API), American Indian or Alaska Native (AIAN), and Hispanic persons diagnosed with melanoma between 1975 and 2016 (Table 22). This study, which provided similar risk estimates as the Dawes 2016 study,^139^ demonstrated that Black, Hispanic, API and AIAN persons diagnosed with localized melanoma between 2010 and 2016 had a statistically significantly higher risk (HRs) of melanoma mortality compared with White persons diagnosed at the same stage. This study also found that Hispanic individuals diagnosed with regional and distant melanoma between 2010 and 2016 had a higher risk of melanoma mortality compared with White persons at the same stages. The Mahendraraj 2017 study^143^ (n=213,827) used SEER stages to estimate melanoma mortality risk for White (n=212,721) and Black (n=1,106) persons diagnosed with melanoma between 1988 and 2011. Overall, 19,207 (9.0%) of White and 241 (21.8%) of Black persons died of melanoma during the observation period. The risk for melanoma mortality was statistically significantly higher among persons with regional and distant stages for both White and Black persons than the reference group of localized disease (Table 21).

Two studies (n=135,490) compared the difference in the risk of melanoma mortality between females and males by stage (Table 23). The U.S.-based Enninga 2017 study^140^ (n=106,511) used SEER stages to compare the risk for melanoma mortality among females and males diagnosed with melanoma between 1992 and 2011. The age-adjusted risk of melanoma mortality among males was higher at the localized (adjHR 1.59, [95% CI 1.49 to 1.70]), regional (adjHR 1.37, [95% CI 1.28 to 1.47]), and distant (adjHR 1.10, [95% CI 1.01 to 1.20]) stages than among female patients. The higher risk for melanoma mortality for males persisted across all age categories (i.e., 18–45, 46–54, and ≥55) for persons with the localized and regional stages; however, the difference between males and females with distant disease for the same age groups was not statistically significant. The Australian Khosrotehrani 2015 study^142^ (n=28,979) compared the risk for melanoma mortality at different AJCC stages among females and males by stage. The data for AJCC stages III and IV were combined due to the small number of persons diagnosed with these stages. In this study, the risk of melanoma mortality for females of any age (15–45 years, 46–59 years, and ≥60 years) was 36 percent lower (adjOR, 0.64 [95% CI, 0.51 to 0.82]) at stage I and 29 percent lower (adjOR, 0.71 [95% CI, 0.58 to 0.87]) at stage II compared with male patients. There was no statistically significant difference in the risk of melanoma mortality between females and males with the combined III and IV stages (adjOR, 0.70 [95% CI, 0.44 to 1.10]). Female patients with stage II and aged 15–45 and those with any stage aged ≥60 years also had a statistically significantly lower risk of melanoma mortality compared with male patients.