# Chapter 2 Methods

## Scope and Purpose

This systematic review provides updated evidence regarding the effectiveness of routine skin cancer screening by a clinician in reducing skin cancer morbidity and mortality, as well as the harms of screening. In addition, this review addresses whether routine screening leads to higher rates of detection of precancerous lesions or earlier stage skin cancer, as well as the association of earlier detection and morbidity/mortality from skin cancer or all-cause mortality. The USPSTF will use this evidence review to update their 2016 recommendation^99^ on screening for skin cancer.

## Key Questions and Analytic Framework

The analytic framework is presented in Figure 2.

Figure 2 Analytic Framework

*Previously referred to as nonmelanoma skin cancer; includes basal cell carcinoma and squamous cell carcinoma.

The analytic framework depicts the four Key Questions (KQs). Specifically, it illustrates the following questions: what is the effectiveness of routine skin cancer screening with visual skin examination by clinicians in reducing skin cancer morbidity and mortality or all-cause mortality? (KQ1); does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care (for example, lesion-directed skin examination)? (KQ2); what are the harms of skin cancer screening and diagnostic followup? (KQ3); and what is the association between detection of precancerous lesions or earlier stage skin cancer and morbidity and mortality due to skin cancer or all-cause mortality? (KQ4).

### Key Questions

1. What is the effectiveness of routine skin cancer screening with visual skin examination by clinicians in reducing skin cancer morbidity and mortality or all-cause mortality?
  a. Does the effectiveness of screening vary by subgroups (for example, age, sex, skin type, race/ethnicity, socioeconomic status, or ultraviolet [UV] exposure)?
2. Does routine skin cancer screening lead to higher rates of detection of precancerous lesions or earlier stage skin cancer compared to usual care (for example, lesion-directed skin examination)?
  a. Do rates of earlier skin cancer detection vary by subgroups (for example, age, sex, skin type, race/ethnicity, socioeconomic status, or UV exposure)?
3. What are the harms of skin cancer screening and diagnostic followup?
  a. Do the harms of screening vary by subgroups (for example, age, sex, skin type, race/ethnicity, socioeconomic status, or UV exposure)?
4. What is the association between detection of precancerous lesions or earlier stage skin cancer and morbidity and mortality due to skin cancer or all-cause mortality?
  a. Does this association vary by subgroups (for example, age, sex, skin type, race/ethnicity, socioeconomic status, UV exposure)?

## Data Sources and Searches

We searched the following databases for English-language literature: MEDLINE ALL via Ovid, Embase via Elsevier, and the Cochrane Central Register of Controlled Trials via Wiley. We updated the search used in the 2016 systematic review on January 12, 2021, and we ran a bridge search on January 7, 2022. A research librarian developed and executed the search, which was peer-reviewed by a second research librarian (Appendix A). We also reviewed all included studies from the prior review,^106^ which identified studies prior to 2015. We then supplemented our database searches with expert suggestions and by reviewing reference lists from other recent relevant systematic reviews.^107–115^ We also searched ClinicalTrials.gov for ongoing screening trials. We imported the literature from these sources directly into EndNote X7 (Thomson Reuters, New York, NY).

## Study Selection

A total of 20,320 abstracts were reviewed. Initial identification of low-relevance abstracts was conducted using keywords relating to exclusion criteria. This identified 10,115 citations that were reviewed by a single investigator. The remaining 10,205 abstracts were dual-reviewed by independent reviewers against a priori specified inclusion criteria using an online platform (DistillerSR). The team then reviewed 522 full-text articles (Appendix A Figure 1) against specified inclusion criteria (Appendix A Table 1). We resolved discrepancies through consensus and consultation with a third investigator.

For screening key questions (KQs 1, 2, 3), the population of interest was asymptomatic adolescents and adults aged 15 years or older with or without a family history of melanoma. We excluded studies focused solely on persons already under surveillance for skin cancer (e.g., because of previous skin cancer, genetic syndromes associated with increased skin cancer risk, or conditions associated with a suppressed immune system). We included studies of any visual skin examination conducted by a clinician with or without tools to aid examination (e.g., dermatoscopy; whole-body photography). We excluded studies of patient skin self-examination as this topic is covered in the 2018 evidence review^48^ on behavioral counseling for skin cancer prevention. For KQ1, we excluded studies focused exclusively on lesion-directed diagnostic skin examination (e.g., in response to patient concern). For KQ1 and KQ2, we excluded studies conducted exclusively in specialty care settings, such as dermatology or plastic surgery.

For KQ4 (the association between stage at detection and health outcomes), the population of interest was adolescents and adults age 15 and older diagnosed with skin cancer. Since lesion thickness is used in determining skin cancer stage, the primary exposure of interest for KQ4 was stage at detection. Specifically, we included studies reporting measures of association between mortality outcomes (excluding relative survival measures such as 5-year survival) and stage at detection using either AJCC or SEER staging (Table 1). To identify and focus on the strongest available evidence within a large literature base of nonrandomized studies, we included population-based studies with data collected across multiple sites. We excluded studies that did not report data on stage at detection (e.g., those that only reported lesion thickness, depth, or Clark levels), that compared grouped stages only (e.g., Stage I+II vs. Stage III+IV) or sub-stages only (e.g., IIA vs. IIB vs. IIC), or that were limited to a single body part or cancer subtype. Where included studies reported thickness, we also abstracted and reported those data.

Included study designs were randomized controlled trials (RCTs) and controlled clinical trials. Also, anticipating limited to no data from randomized trials, we included nonrandomized studies with a contemporaneous control for all key questions. For KQ3 only, we additionally included large screening registry or database nonrandomized studies, cohort studies, and systematically selected case series. Outcomes of interest were morbidity or mortality associated with skin cancer, including quality of life, skin cancer mortality, or all-cause mortality (KQ1 and KQ4), stage or lesion thickness at detection of skin cancer or precancerous lesion (KQ2), and any harm of skin cancer screening, biopsy, or excision persisting beyond 30 days, including psychosocial harms and procedure-related adverse events (KQ3).

For all key questions, we limited studies to those conducted in primary care-relevant settings and in countries categorized as “Very High” in the 2019 Human Development Index.^116^ We included only studies that published their results in English because of resource constraints. We excluded studies that were not original research (e.g., editorials, opinion pieces, and narrative reviews) and studies that were not peer-reviewed (e.g., conference abstracts).

## Quality Assessment and Data Abstraction

At least two reviewers independently critically appraised all articles that met the inclusion criteria based on the Newcastle Ottawa Scales for nonrandomized studies^117^ and the USPSTF’s design-specific quality criteria for trials (Appendix A Table 2). We rated articles as good, fair, or poor quality. In general, a good-quality study met all criteria. A fair-quality study did not meet, or it was unclear whether it met, at least one criterion, but also had no known important limitations that could invalidate its results. A poor-quality study had a single fatal flaw or multiple important limitations. We excluded all poor-quality studies from this review. Disagreements about critical appraisal were resolved by consensus and, if needed, consultation with a third independent reviewer.

One reviewer extracted key elements of included studies into standardized evidence tables in DistillerSR (Evidence Partners, Ottawa, Canada). A second reviewer checked the data for accuracy. Evidence tables were tailored for each key question. Tables generally included details on: study design/quality, setting and population (e.g., country, inclusion criteria, age, sex, race and/or ethnicity, skin type), screening exam/protocol (e.g., who administered, how administered), length of followup, and outcomes (e.g., skin cancer morbidity or mortality, all-cause mortality, stage or lesion thickness at detection, harms of screening).

## Data Synthesis and Analysis

We synthesized results by KQ. We used a standardized summary of evidence table to summarize the overall strength of evidence for each KQ. This table included the number and design of included studies, summary of results, consistency or precision of results, reporting bias, summary of study quality, limitations of the body of evidence, and applicability of the findings. We also assessed the potential for population overlap between studies. For population-based studies with substantially overlapping patient populations (e.g., SEER data from identical time periods) and the same outcomes presented, we used studies with the largest sample size and the most extended followup.

Because of the limited number of studies and the population heterogeneity, we provided a narrative synthesis of results and used summary tables to facilitate comparisons across studies. Heterogeneity in outcomes precluded pooling or meta-analysis.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidence-based Practice Center (EPC) approach,^118^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^119^ Our method explicitly addresses four of the five EPC-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). The body-of-evidence limitations reflect potential reporting bias, study quality, and other important restrictions in answering the overall KQ (e.g., lack of replication of interventions, nonreporting of outcomes important to patients).

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect, and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” indicates moderate confidence that the evidence reflects the true effect, and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect, and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimation of an effect. We developed our overall strength-of-evidence grade based on consensus discussion involving at least two reviewers.

## Expert Review and Public Comment

The draft Research Plan was posted on the USPSTF website for public comment from January 7, 2021, to February 3, 2021. In response to public comment, the USPSTF clarified the wording of KQs 2 and 4 to more clearly delineate precancerous lesions from early-stage skin cancer; clarified that the exclusion of “lesion-directed diagnostic skin examination (e.g., in response to patient concern)” applies to KQ1 only; added race/ethnicity and socioeconomic status as additional examples of subpopulations that will be examined for each KQ; and added KQ4a to assess whether the association varies by subgroups. The USPSTF made no other substantive changes that altered the scope of the review.

A draft version of this report was reviewed by invited content experts and federal partners, who are listed in the acknowledgements. Comments received during this process were presented to the USPSTF during its deliberation of the evidence and, subsequently, addressed in this version of the report.

## USPSTF and AHRQ Involvement

The authors worked with USPSTF liaisons at key points throughout the review process to develop and refine the analytic framework and key questions and to resolve issues around scope for the final evidence synthesis.

AHRQ staff provided oversight for the project, coordinated systematic review, reviewed the draft report, and assisted in an external review of the draft evidence synthesis.