# Chapter 1 Introduction

## Condition Definition

Skin cancer is the abnormal growth of cells in skin tissue and is broadly classified as cutaneous melanoma and keratinocyte carcinoma (KC, previously referred to as nonmelanoma skin cancer). Cutaneous melanoma arises from pigment-producing cells called melanocytes in the epidermis, the outermost skin layer. Melanoma is less common than KC but is more likely to grow and spread.^1,^ ^2^ Noncutaneous (nonskin) melanoma develops from melanocytes in other areas of the body (e.g., the eye in ocular melanoma, mucosal surfaces in mucosal melanoma).^3^

This review’s scope is limited to cutaneous melanoma, hereafter described as “melanoma,” and KC. KC includes squamous cell carcinoma and basal cell carcinoma. Squamous cell carcinoma of the skin (SCC) can develop in the skin or in other parts of the body, such as the squamous mucosal epithelium. SCC of the skin is the only type of SCC addressed in this report. Basal cell carcinoma (BCC) develops in basal cells in the lower epidermis. Precursor lesions that may develop into skin cancer include actinic keratosis and atypical or dysplastic nevi; however, many dysplastic nevi never develop into melanoma and melanoma can develop de novo without arising from pre-existing nevi.^4^

Melanoma progression is described using two main staging conventions (Table 1). The Surveillance, Epidemiology and End Results (SEER) Program of the National Cancer Institute’s staging convention describes three summary stages: localized (limited to skin tissue); regional (spread to lymph nodes); and distant (spread or metastasis to other parts of the body). Localized skin cancers may be further described in terms of thickness or depth, terms that describe how deep into the skin tissue the cancer has grown. The second staging system, developed and updated by the American Joint Committee on Cancer (AJCC, a program of the American College of Surgeons), is a histopathologic system that establishes standardized, clinically meaningful categories of tumor (T) thickness, ulceration, and mitotic rate; lymph node involvement (N); and metastasis (M) to assign Stage I, II, III, or IV (Table 1). The AJCC system was developed as a tool for assessing prognosis and guiding care. The current version (8^th^ edition, implemented in 2018) is based on analysis of survival data from an international cohort (n=43,792) of persons diagnosed with melanoma since 1998.^5^

Table 1 Comparison of AJCC (7th Edition) and SEER Staging Systems Used in the Included Studies

AJCC 7 Stage^207,^ ^208,*^ | AJCC 7 Tumor Thickness | | | AJCC 7 Node | | AJCC 7 Metastasis | | SEER Stage^161^ | SEER Thickness/Depth (Clark’s level of invasion)
0 | Tis | Melanoma in situ | | N0 | No melanoma in lymph nodes | M0 | No metastasis found | In situ | In situ (I)
IA | T1a | ≤1.0mm | No ulceration and mitosis <1/mm^2^ | N0 | | M0 | | Localized | ≤0.75 mm (II) 0.76–1.50 mm (III) >1.5 mm (IV)
IB | T1b | ≤1.0mm | with ulceration or mitoses ≥1/mm^2^ | N0 | | M0 | | Localized | ≤0.75 mm (II) 0.76–1.50 mm (III) >1.5 mm (IV)
IB | T2a | 1.01–2.0mm | without ulceration | N0 | | M0 | | Localized | ≤0.75 mm (II) 0.76–1.50 mm (III) >1.5 mm (IV)
IIA | T2b | 1.01–2.0mm | with ulceration | N0 | | M0 | | Localized | ≤0.75 mm (II) 0.76–1.50 mm (III) >1.5 mm (IV)
IIA | T3a | 2.01–4.0mm | without ulceration | N0 | | M0 | | Localized | ≤0.75 mm (II) 0.76–1.50 mm (III) >1.5 mm (IV)
IIB | T3b | 2.01–4.0mm | with ulceration | N0 | | M0 | | Localized | ≤0.75 mm (II) 0.76–1.50 mm (III) >1.5 mm (IV)
IIB | T4a | >4.0mm | without ulceration | N0 | | M0 | | Localized | ≤0.75 mm (II) 0.76–1.50 mm (III) >1.5 mm (IV)
IIC | T4b | >4.0mm | with ulceration | N0 | | M0 | | Localized | ≤0.75 mm (II) 0.76–1.50 mm (III) >1.5 mm (IV)
III | Any T | | | N1 | Melanoma in 1 lymph node | M0 | | Regional | Direct extension: Thru entire dermis (V); satellite nodules ≤2 cm from primary site Lymph node: spread to regional lymph nodes
III | Any T | | | N2 | Melanoma in 2–3 lymph nodes | M0 | | Regional | Direct extension: Thru entire dermis (V); satellite nodules ≤2 cm from primary site Lymph node: spread to regional lymph nodes
III | Any T | | | N3 | Melanoma in 4 or more lymph nodes | M0 | | Regional | Direct extension: Thru entire dermis (V); satellite nodules ≤2 cm from primary site Lymph node: spread to regional lymph nodes
IV | Any T | | | Any N | | M1 | Metastasis to in skin, subcutaneous tissue, or distant lymph nodes (M1a); lung (M1b); or other distant organs (M1c) | Distant | Metastasis to cartilage, bone, muscle, or metastatic (generalized) skin lesions or organs

* This table describes the AJCC 7th edition criteria because the included studies in this review use that version. In the 8th edition, published in 2017, T1a is defined as nonulcerated melanomas <0.8 mm in thickness, and T1b is defined as melanomas from 0.8 to 1.0 mm in thickness regardless of ulceration status and ulcerated melanomas less than 0.8 mm in thickness.^5^

Abbreviations: AJCC=American Joint Committee on Cancer; cm=Centimeter; mm=millimeter; SEER=Surveillance, Epidemiology, and End Results Program.

## Prevalence and Burden

KCs comprise the vast majority (99%) of all incident skin cancers, with BCC making up about 80 percent of all incident cases and SCC making up about 20 percent.^6^

KCs are not required to be reported to cancer registries in the United States, so precise epidemiological estimates are not available. Based on Medicare and national survey data, a 2015 study estimated that 5.4 million KC cases were diagnosed among 3.3 million people in the United States population in 2012.^7^ The incidence of KC increases with age and is more common in males than in females.^8–10^ KC incidence appears to be increasing in recent decades,^7^ possibly related to increased exposure to ultraviolet radiation (UVR), increased detection, and increased longevity. Reliable estimates of KC mortality are not available, but death from KC is relatively uncommon (e.g., 0.32/100,000 for SCC-specific and 0.14 for BCC-specific mortality among Rhode Island residents between 1985 and 1987).^11^ An emerging body of evidence suggests that the currently known SCC-related mortality rate is underestimated.^12^

Approximately one percent of all skin cancers are melanoma.^13^ Melanoma causes the most skin cancer mortality compared to KC, with 7,990 melanoma deaths expected in the United States in 2023.^14^ Melanoma incidence has been increasing consistently since 1975, with an average increase of 1.4 percent each year from 2009–2018. The increase in melanoma incidence has been attributed to increased UVR exposure^15^ and increased detection.^16^ There will be an estimated 97,610 new cases of melanoma in the United States in 2023 (22.9 per 100,000 persons).^14^ Melanoma accounts for 5.2 percent of all new cancer cases in the U.S.^17^ and is the fifth leading cancer in terms of incidence (new cases) in males and females.^18^

Although melanoma incidence has been steadily increasing over the past four decades, survival rates have remained stable over the same time period and have even begun improving in recent years (Figure 1).^18^ According to United States SEER data, age-adjusted melanoma incidence rates increased on average 1.2 percent each year between 2010 and 2019.^14^ An analysis of SEER data from 1975–2017 found that melanoma in situ incidence has increased more rapidly than that of invasive melanoma.^19^ According to 2012–2018 SEER data, 5-year survival for melanoma ranges from 99.5 percent for localized stage disease to 31.9 percent for distant stage disease.^14^ Age-adjusted death rates have decreased on average 3.3 percent each year between 2011 and 2020.^14,^ ^19^

Figure 1 Incidence and Mortality Trends, Melanoma Skin Cancer, United States, SEER 2000-2019

Accessed 11/30/2021

The figure shows trends in U.S. melanoma skin cancer incidence and mortality from 2000-2019 based on Surveillance, Epidemiology, and End Results (SEER) program data. The figure shows that U.S. melanoma skin cancer incidence gradually increased from 16.59 per 100,000 in 2000 to 22.05 per 100,000 in 2019. Meanwhile, U.S. melanoma skin cancer mortality has remained fairly steady or decreased slightly, varying from 2.66 per 100,000 in 2000 to 2.01 per 100,000 in 2019.

Incidence and mortality of melanoma increases with age, and is highest in males and in White persons (Table 2).^14,^ ^20,^ ^21^ Melanoma incidence is lower in Black persons, but less likely to be diagnosed at early stage, when treatment works best. The percentage of new skin cancer cases diagnosed at a local stage is lower in Black persons (50.6%) and Asian/Pacific Islanders (64.2%), compared to White persons (78.1%).^22^ The 5-year relative survival rate for those diagnosed at a local stage also is lower in Black persons (88.5%; 95% CI, 78.9% to 93.9%) and Asian/Pacific Islanders (89.7%; 95% CI, 84.8% to 93.1%) than in white persons (99.1%; 95% CI, 98.7% to 99.3%).^23^ Notably, skin cancer has primarily been studied in persons with light skin, which may contribute to disparities in diagnosis, care, and treatment. Clinical presentation (e.g., melanoma subtype, location of lesion) of skin cancer can differ in people with darker skin tones.^24,^ ^25^ Other factors that may contribute to disparities in skin cancer outcomes include socioeconomic status, insurance status, place of residence, and access to care.^26^

Table 2 Melanoma of the Skin, 5-Year Age-Adjusted Incidence and Mortality Rates, per 100,000, SEER, 2015–2019^*^,^14,^ ^52^

Race/ethnicity | Males | Males | Females | Females
Race/ethnicity | Incidence | Mortality | Incidence | Mortality
All Races (includes Hispanic) | 27.6 | 3.2 | 17.0 | 1.4
Hispanic (any race) | 4.6 | 0.9 | 4.5 | 0.5
American Indian/Alaska Native (non-Hispanic) | 8.7 | 1.0 | 8.3 | 0.6
Asian/Pacific Islander (non-Hispanic) | 1.4 | 0.3 | 1.2 | 0.3
Black (non-Hispanic) | 1.0 | 0.4 | 0.9 | 0.3
White (non-Hispanic) | 38.6 | 4.0 | 25.5 | 1.8
Age-Specific Data
<50 years | 5.4 | 0.4 | 7.9 | 0.3
50–64 years | 42.5 | 4.0 | 31.3 | 2.0
≥65 years | 137.3 | 17.9 | 52.4 | 6.6

* All stages.

## Etiology and Natural History

BCC develops from the basal layer of the epidermis. SCC on the other hand arises from keratinocytes in the mid-layer of the epidermis. Unlike BCCs, which rarely metastasize, a small proportion (estimated metastatic rate 1.9%–4.9%) of SCCs metastasize in the absence of treatment.^27–29^ The most common location of melanoma and KC is skin that has been exposed to the sun; however, skin cancer on nonexposed skin is more likely to develop in Black, Asian, and native Hawaiian persons.^30^ SCC commonly appears on the face, ears, neck, lips, and back of hands, whereas BCC is especially prevalent on the head and neck.^31^

Melanomas develop through the unregulated growth of melanocytes, melanin-producing cells found between the epidermal and dermal layers of the skin. Melanocytes may grow in a horizontal lentiginous pattern to appear on the skin as a freckle, and clusters of melanocytes may develop into nevi. Melanomas have metastatic potential when they infiltrate the dermis and begin a vertical growth phase into deeper skin layers.

There are four major histologic subtypes of melanoma skin cancer: 1) superficial spreading; 2) lentigo maligna; 3) acral lentiginous; and 4) nodular. Of these, superficial spreading and nodular melanomas are the most common subtypes,^32^ though incidence of lentigo maligna has been increasing in recent years.^33,^ ^34^ Nodular melanomas begin their vertical growth phase immediately, whereas other types may take decades.^35,^ ^36^ Ten-year relative survival rates are lowest for nodular (61.5%) and acral lentiginous melanoma (69.9%) compared with superficial spreading (96.5%) and lentigo maligna melanoma (99.4%).^33^ Acral lentiginous melanoma (ALM), which occurs on the palms of hands, soles of feet, fingers, toes, and nail units, is the least common melanoma subtype.^37^ Incidence of ALM is highest in Hispanic white persons followed by non-Hispanic white persons;^38^ however, among Black populations, ALM is the most frequently occurring melanoma subtype.^37^

The degree to which melanoma has spread at detection is highly prognostic of survival, making skin cancer a candidate for population screening programs. Melanoma thickness and ulceration are the primary prognostic indicators of survival in early stage disease,^39^ and depth of vertical growth is directly related to prognosis.^39–41^ Both the AJCC and SEER staging systems recognize this and include clinically meaningful categories of thickness in early stage disease, as well as lymph node involvement and metastasis for more advanced stages (Table 1). In addition, the systematic review supporting the United States Preventive Services Taskforce’s (USPSTF) 2016 recommendation on skin cancer screening identified eight nonrandomized studies that examined the association between either melanoma-specific or all-cause mortality and lesion thickness or stage at diagnosis.^42^ All studies demonstrated a consistent linear increase in risk of melanoma mortality with increasing tumor thickness or stage.^43^

## Risk Factors

The epidemiology and risk factors for skin cancer, especially for melanoma, are well-characterized. Exposure to UVR is the major environmental risk factor for all types of skin cancer in exposed skin.^44,^ ^45^ The World Health Organization’s International Agency for Research on Cancer has classified UVR, UVR-emitting devices, solar radiation, and indoor tanning devices as carcinogenic to humans with sufficient evidence linking their use to melanoma and other skin cancers.^46^

Sunlight is the primary source of UVR exposure. Melanoma risk is associated with intense intermittent sun exposure and a frequent history of sunburn is associated with a 2-fold increased risk of melanoma.^47^ Cumulative sun exposure, such as long-term outdoor occupational exposure, appears to increase KC risk, but not risk of melanoma.^47,^ ^48^

Another important source of UVR exposure, especially in adolescents, is the use of indoor tanning beds, which is associated with both KC and melanoma. Ever use of tanning beds is associated with a 1.7-fold increased risk of SCC,^49^ a 1.3-fold increased risk of BCC,^49^ and a 1.2-fold increased risk of melanoma.^49,^ ^50^ Associations with indoor tanning are stronger for persons with a younger age at exposure (1.8-fold increased melanoma risk for <35 years compared to ≥35 years at first exposure).^51^

Increased age, as well as male sex are associated with increased risk of skin cancer incidence and mortality. Epidemiological studies have shown that melanoma incidence and mortality rapidly increase with age, with the mean age at diagnosis being 65 years.^14^ Melanoma incidence during 2015–2019 was 6.6 cases per 100,000 persons aged <50 years, 36.7 cases per 100,000 persons aged 50 to 64 years, and 88.5 cases per 100,000 persons in adults aged ≥65 years (Table 2). Mortality rates mirror this trend, showing that during 2015–2019 persons from these age groups had adjusted rates of 0.4, 3.0, and 11.3 deaths per 100,000 persons (Table 2).^20^ Data consistently show that males are at a higher risk of melanoma incidence and mortality compared to females (Table 2). Age-adjusted melanoma incidence during 2015–2019 was reported as 27.6 per 100,000 in males and 17.0 per 100,000 in females.^14^ However, this sex-specific difference is not consistent across all ages. Younger females, particularly those aged 15–39 years, had modestly higher incidence rates than their male counterparts, likely related to higher use of tanning and tanning beds among females. The highest rates were observed in older males aged ≥65 years (137.3 per 100,000) and nearly tripled those of similarly aged females (52.4 per 100,000);^52^ this may reflect a combination of behavioral risk factors and tendency for thicker skin in males.^53^ Although 5-year survival is similar for males and females, age-adjusted melanoma mortality rates are higher in males, with 3.2 and 1.4 deaths per 100,000, respectively. The difference in age-adjusted melanoma mortality increases with age and increases faster in males (Table 2).^52^

As estimated according to socially constructed race and ethnicity categories, melanoma incidence is highest among White persons (38.6 per 100,000 persons in males; 25.5 per 100,000 persons in females) (Table 2). Melanoma incidence is lower among American Indian/Alaska Native persons (8.7 per 100,000) and persons of Hispanic ethnicity (any race; 4.6 per 100,000) (Table 2). Black persons have the lowest rates of melanoma (1.0 per 100,000).^21^ The incidence of melanoma varies in persons with different skin phenotypes—type I (sun-unexposed skin color is white and always burns, not tans) through VI (sun-unexposed skin color is dark brown to black and never burns, always tans) according to the Fitzpatrick Skin Phototype Classification.^54^ The higher melanoma incidence seen in White persons, compared with other races and ethnicities, could be due to fair skin being susceptible to sunburning more easily.^55^ In addition, having light-colored eyes and red or blond hair are associated with an increased risk of skin cancer, and these traits are more common in White persons.^56–58^ Natural red hair and natural blond hair confer a 3.6-fold and 2-fold increase in melanoma risk, respectively, compared to naturally dark hair.^58^ Emerging evidence suggests no to weak association between UV exposure and melanoma incidence in skin of color (broadly defined as any race or ethnicity other than non-Hispanic White, Fitzpatrick skin types IV through VI, or tanning ability of rarely or never burns).^59^

Other melanoma risk factors include an increase in the number of nevi, or moles, on the skin (especially moles that are atypical).^55,^ ^60^ Number of typical nevi is associated with an increased risk of melanoma in a dose-response manner.^61,^ ^62^ Atypical nevi also confer risk in a dose-response relationship with number, with a 1.5-fold increased risk associated with a single atypical nevus and a more than 6-fold increased risk associated with five atypical nevi compared to none.^55^

Persons with a previous history of KC have been shown to have an increased risk of developing melanoma,^63^ and a history of melanoma is associated with an increased risk of developing a second primary melanoma.^64,^ ^65^

Melanoma has a genetic component, as measured by both family history^66,^ ^67^ and by polygenic heritable factors such as skin type, nevus count, hair color, and eye color.^68,^ ^69^ Pooled estimates suggest that family history of the disease increases melanoma risk 1.7-fold.^58^ Other hereditary components account for <7 to 10 percent of melanomas.^66,^ ^67^ Additionally, persons with familial atypical multiple mole and melanoma (FAMMM) syndrome have a high lifetime risk of developing melanoma, and those with basal cell nevus syndrome develop multiple BCCs at an early age. Three large U.S.-based cohort studies found evidence that persons with a family history of melanoma skin cancer have 74 percent increased risk of melanoma (HR, 1.74 [95% CI, 1.45 to 2.09]), a 22 percent increased risk of SCC (HR, 1.22 [95% CI, 1.06 to 1.40]), and a 27 percent increased risk of BCC (HR, 1.27 [95% CI, 1.12 to 1.44]) compared to those without a family history.^70^ Hereditary melanoma is most commonly attributed to a mutation in CDKN2A/p16. Other commonly cited melanoma hereditary genes include CDKN2A/AFR, CDK4, TERT, MITF, BAP1, POT1.^71^ In addition to FAMMM syndrome, several rare genetic conditions confer increased skin cancer risk.^69,^ ^72^ For example, xeroderma pigmentosum impairs the ability to repair UVR-induced DNA damage and increases the risk of both KC and melanoma at an early age.^73^ Albinism is characterized by hypopigmentation and confers an increased risk of KC.

## Screening, Diagnosis, and Treatment

The rationale for screening for skin cancer is to detect skin cancers earlier in their clinical course than would happen without screening, allowing earlier and more effective treatment and thereby leading to a reduction in skin cancer morbidity and mortality. Visual skin cancer screening is either a whole or partial body skin examination conducted by a clinician to detect suspicious skin lesions. Clinicians are trained in the detection and diagnosis of skin cancer using mnemonics such as the ABCDE mnemonic^74^ to identify characteristics of skin lesions that may signify melanoma (asymmetry, border irregularity, color, diameter, and evolution over time). Another approach to skin cancer screening is the “ugly duckling” sign. In this approach, the clinician identifies pigmented lesions which look different than the other nevi in a given patient.^75^ In addition to visual inspection of the skin with the naked eye, dermatologists often use a magnifying device called a dermatoscope (also called a dermascope or dermoscope) to further inspect the lesion. The use of dermoscopy by primary care providers is increasing, particularly in Australia.^76–78^

A definitive diagnosis of both KC and melanoma is through biopsy, including partial biopsy (for KC) and deep shave/saucerization biopsy, punch excision, or elliptical excision (for melanoma).^79^ Some lesions can be removed at the time of examination, or individuals with suspicious lesions may be referred to a dermatologist for virtual or in-person consultation.

### Treatment

KC is removed by either surgical excision, Mohs micrographic surgery (i.e., tissue is removed in layers until the microscopic examination of the layers indicates that cancer has been completely removed), or electrodesiccation and curettage (i.e., tissue destruction by electric current and removal by scraping with a curette).^80^ Photodynamic therapy (i.e., combined use of a photosensitizing agent with light) is mainly used to treat superficial KC.^81,^ ^82^ Radiation therapy or topical medications might also be used.

For melanoma, the primary tumor and surrounding normal tissue are surgically removed, possibly with sentinel lymph node biopsy to determine stage. More extensive surgery (e.g., complete lymph node dissection) may be conducted if the sentinel lymph node is positive. Unresectable melanoma (e.g., stage III-IV) may be treated with palliative surgery, immunotherapy, radiation therapy, chemotherapy, or a combination.^83^

Since 2011, major advancements in the development of immunotherapies and targeted therapies have changed how advanced melanoma is treated. These treatments are now considered the standard of care and are used as the first line treatment because of improved survival and are associated with fewer side effects than traditional approaches.^79,^ ^84–86^ Immunotherapies and targeted therapies fall mainly into two groups based on their primary targets: those that inhibit the mitogen-activated kinase pathway in tumors with BRAFV600 (known as MAPK or BRAF inhibitors), and those that inhibit various checkpoints involved in the activation of the immune system (known as checkpoint inhibitors). The U.S. Food and Drug Administration (FDA) has approved a number of immunotherapies for the treatment of advanced and metastatic melanoma, including the checkpoint inhibitors ipilimumab (a monoclonal antibody that targets CTLA-4), nivolumab (a monoclonal antibody that targets PD-1), vemurafenib (a BRAF inhibitor), and pembrolizumab (a PD-1 inhibitor), as well as talimogene laherparepvec (TVEC).^84,^ ^86,^ ^87^

## Current Clinical Practice

The majority of melanomas (67%–75%) are initially detected by patients or their spouses (i.e., lesion-directed examination), not clinician exam.^88,^ ^89^ Current practice for persons who are not under surveillance for skin cancer typically involves lesion-directed examination. In lesion-directed examination, a clinician examines a lesion identified incidentally or by a patient. Persons with known elevated skin cancer risk (e.g., personal history of melanoma, multiple nevi) may be under routine surveillance and receive more frequent skin examinations.

Dermatologists are more likely to report more skin examinations performed than family practice clinicians or internists (552 [81.3%] dermatologists versus 333 [59.6%] family practice clinicians versus 243 [56.4%] internists).^90^ It is unclear how many of these screenings are performed in persons with elevated risk for skin cancer versus how many were in persons with an average risk for skin cancer.

Primary care clinicians in two counties in Connecticut and Florida indicate that only 31 percent perform skin cancer screening on their adult patients; the primary barrier was clinician lack of confidence in identifying a suspicious lesion.^91,^ ^92^ While there are several educational interventions to improve knowledge of and confidence in skin cancer screening in primary care, few tools have been rigorously tested for measured changes in clinical practice.^93,^ ^94^

The use of virtual care (e.g., telehealth, telemedicine) has rapidly increased since the beginning of 2020 as a response to the COVID-19 pandemic.^95^ Evidence suggests that telehealth may improve access to care, improve patient and provider satisfaction, and reduce costs for both health systems and some patients, with the promise of delivering clinical outcomes similar to those from in-person care for some conditions and health needs.^96^ Telehealth in primary care and teledermatology (i.e., dermatology services over distance, or distance and time) is being used to evaluate patients’ individual risk for skin cancer, facilitate skin cancer screening and early diagnosis, and provide behavioral counseling.^96–98^

## Current Screening Recommendations

Currently, no professional organizations in the United States recommend clinician-performed population-based skin cancer screening (Appendix B). The American Academy of Family Physicians cites the 2016 USPSTF recommendation^99^ as the basis for its conclusion that there is insufficient evidence to evaluate the balance of benefits and harms of screening. The American College of Physicians, however, does not have current guidance on whether or not to screen. The American Cancer Society (ACS) has no specific recommendation for skin cancer screening, but highlights the importance of knowing one’s own skin and provides instructions on performing skin self-examination.^100,^ ^101^ The American Academy of Dermatology (AAD) similarly encourages regular skin self-examination in asymptomatic persons with no history of skin cancer. Also, AAD states that persons should seek advice from their health provider on the frequency of self-exam.^102^ The AAD has offered free skin cancer screening clinics since 1985, similar to its contemporary SPOTMe^®^ screening campaign.^103^

A nationwide skin cancer screening program was implemented in Germany in 2008, following the results of the Skin Cancer Research to Provide Evidence for Effectiveness of Screening in Northern Germany (SCREEN) study.^104^ Other than Germany, routine screening is not recommended by professional organizations in other countries, including the United Kingdom, The Netherlands, and Australia.

## Previous USPSTF Recommendation

In 2016, the USPSTF concluded that the current evidence was insufficient to assess the balance of benefits and harms of visual skin examination by a clinician to screen for skin cancer in adults (I statement).^99^ This statement applied to asymptomatic adults who did not have a history of premalignant or malignant skin lesions. Patients with suspicious skin lesions or those already under surveillance because of a high risk of skin cancer, such as those with a familial syndrome, were outside the scope of the recommendation statement. The 2016 recommendation does not mention immunosuppressed patients or other groups at high-risk of developing skin cancer.

The USPSTF addressed counseling for skin cancer prevention, including skin self-examination, in the evidence review supporting its 2018 recommendation statement.^48^ In 2018, the USPSTF recommended skin cancer prevention counseling for young adults, adolescents, children, and parents of young children (B recommendation) and for adults older than 24 years with fair skin types (C recommendation). The USPSTF concluded the current evidence was insufficient to assess the balance of benefits and harms of counseling adults about skin self-examination for skin cancer prevention (I statement).^105^