# Appendix F Ongoing Studies

According to ClinicalTrials.gov there are 6 trials on skin cancer screening in adults that are either: recruiting, not yet recruiting, active, or complete with no results available. They are described in the table below by expected completion date.

Identifier | Study Name | Location | Sponsor | Planned N | Study design | Intervention | Relevant Outcomes | Estimated completion | 2022 Status
NCT02902822 (https://clinicaltrials.gov/ct2/show/NCT02902822) | Tele-dermatology of Skin Cancer in a Cohort of Local Health Authority Employees in the Province of Bergamo | Italy | Centro Studi Gised, Italy | 461 patients | Randomized clinical trial | Web-based / smartphone app allowing patients to send photos of suspicious lesions | Skin cancer incidence | May 2019 | Complete; no results available
NCT02352428 (https://clinicaltrials.gov/ct2/show/NCT02352428) | Skin Cancer Screening Education Study (SCSES) | Canada | Association of Dermatological Prevention, Germany | 200 physicians (40,000–80,000 patients) | Population-based nonrandomized trial | Skin cancer screening training for family physicians and dermatologists | Diagnostic accuracy, harms, skin cancer incidence | September 2019 | Active, not recruiting
NCT04534868 (https://clinicaltrials.gov/ct2/show/NCT04534868) | Patient Acceptance And Satisfaction of Teledermoscopy In General Practice In a Belgian Rural Area | Belgium | Cliniques universitaires Saint-Luc-Université Catholique de Louvain, Belgium | 100 patients | Interventional clinical trial, single group assignment | Taking macroscopic and dermoscopic pictures of suspicious skin lesions | Patient acceptability of and satisfaction with teledermoscopy | March 2021 | Not yet recruiting
NCT05148455 (https://clinicaltrials.gov/ct2/show/NCT05148455) | Pregnancy-related Changes in Melanocytic Nevi | Switzerland | University Hospital, Basel, Switzerland | 50 females (pregnant and non-pregnant) | Observational cohort | Standard-of-care clinical skin examination | Change in psychological impact of skin cancer screening | February 2022 | Active, not recruiting
NCT05246163 (https://clinicaltrials.gov/ct2/show/NCT05246163) | ARTIficial Intelligence-based Smartphone Application for Skin Cancer Detection (ARTIS) | Belgium | University Hospital, Ghent, Belgium | 1500 patients | Observational cross-sectional | Skin cancer screening smartphone application (Skinvision App) | Diagnostic performance of skin cancer screening smartphone application | October 2023 | Recruiting
NCT04358276 (https://clinicaltrials.gov/ct2/show/NCT04358276) | Technology-Enabled Activation of Skin Cancer Screening for Stem Cell Transplant Survivors and Their Primary Care Providers | United States | City of Hope Medical Center, National Cancer Institute (NCI) | 720 patients | Randomized clinical trial | Educational intervention and text messages (for patients), dermatoscope and training (for physicians) | Receipt of physician skin exam, time to diagnosis of suspicious lesions | October 2024 | Recruiting

## Appendix References

1 United Nations Human Development Program. Human Development Index (HDI). [2020 October 23]. http://hdr.undp.org/en/content/human-development-index-hdi.
2 Wells G, Shea B, O'Connell D, The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. [2021 July 12]. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp.
3 U.S. Preventive Service Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015.
4 American Cancer Society. Can Melanoma Skin Cancer Be Found Early?: American Cancer Society 2020/10/23]. https://www.cancer.org/cancer/melanoma-skin-cancer/detection-diagnosis-staging/detection.html#references.
5 American Cancer Society. Guidelines for the Early Detection of Cancer. American Cancer Society 2020/10/20]. https://www.cancer.org/healthy/find-cancer-early/cancer-screening-guidelines/american-cancer-society-guidelines-for-the-early-detection-of-cancer.html.
6 American Academy of Dermatology. Skin Cancer: Incidence Rates. American Academy of Dermatology Association 2020/10/20]. https://www.aad.org/media/stats-skin-cancer.
7 Cancer Council Australia's National Skin Cancer Committee. Position Statement - Early Detection of Skin Cancer. Cancer Council of Australia 2020/10/20]. https://wiki.cancer.org.au/policy/Position_statement_-_Screening_and_early_detection_of_skin_cancer#_ga=1.163538552.530426991.1463699610.
8 The Royal Australian College of General Practitioners. Guidelines for Preventive Activities in General Practice. 9th ed. East Melbourne, Vic: RACGP; 2018.
9 Janda M, Cust AE, Neale RE, Early detection of melanoma: a consensus report from the Australian Skin and Skin Cancer Research Centre Melanoma Screening Summit. Australian & New Zealand Journal of Public Health. 2020;44(2):111–5. PMID: 32190955.32190955
10 Katalinic A, Eisemann N, Waldmann A. Skin Cancer Screening in Germany. Documenting Melanoma Incidence and Mortality From 2008 to 2013. Deutsches Arzteblatt international. 2015;112(38):629–34. PMID: 26429634.26429634
11 Dutch Working Group on Melanoma. Melanoma Guideline 2012. [2020 October 23]. http://www.oncoline.nl/uploaded/docs/melanoom/201208_vertaling%20Richtlijn%20melanoom%20def.pdf.
12 Marsden JR, Newton-Bishop JA, Burrows L, Revised U.K. guidelines for the management of cutaneous melanoma 2010. Br J Dermatol. 2010;163(2):238–56. PMID: 20608932.20608932
13 Krensel M, Andrees V, Mohr N, Costs of routine skin cancer screening in Germany - a claims data analysis. Clin Exp Dermatol. 2020;30:30. PMID: 33378094.33378094
14 Hoorens I, Vossaert K, Pil L, Total-body examination vs lesion-directed skin cancer screening. JAMA Dermatol. 2016;152(1):27–34.26466155
15 Trautmann F, Meier F, Seidler A, Effects of the German skin cancer screening programme on melanoma incidence and indicators of disease severity. British Journal of Dermatology. 2016;175(5):912–9. PMID: 27203791.27203791
16 Matsumoto M, Wack S, Weinstock MA, Five-Year Outcomes of a Melanoma Screening Initiative in a Large Health Care System. JAMA Dermatol. 2022. PMID: 35385051.35385051
17 Aitken JF, Elwood M, Baade PD, Clinical whole-body skin examination reduces the incidence of thick melanomas. International journal of cancer. 2010;126(2):450–8. PMID: 19609948.19609948
18 Cristofolini M, Boi S, Cattoni D, A 10-Year Follow-Up Study of Subjects Recruited in a Health Campaign for the Early Diagnosis of Cutaneous Melanoma: Suggestions for the Screening Timetable. Dermatology. 2015;231(4):345–52. PMID: 26278413.26278413