# Appendix E Additional Tables

Appendix E Figure 1 Stage or Thickness at KC Detection, Screened vs. No Routine Skin Cancer Screening (KQ2)^13^

This figure is a bar graph summarizing stage at keratinocyte cancer (KC) detection in screened populations vs. those with no routine screening from the Krensel 2020 study (n=10,844 KC cases). These data, which also are reported in Report Table 13, show similar distributions of KC stage in each study group (99.9% of KC cases detected at stage I/II in screened group; 99.8% in unscreened group).

Appendix E Figure 2 Precursor Lesion Detection Rates, Screened vs. Unscreened (KQ2)^14^

This figure is a bar graph summarizing precursor lesion detection rates in screened populations vs. those with no routine screening from the Hoorens 2016 study (n=1,916 individuals) These data, which also are reported in Report Table 12, show rates of actinic keratoses and atypical nevi were similar in both groups. Actinic keratoses was detected in 7.9 percent of the total body exam group and 7.8 percent of the lesion-directed exam group (p = 0.90). Atypical nevi were detected at 15.1 percent of the total body exam group and 17.3 percent of the lesion-directed group (p = 0.33).

Appendix E Figure 3 Stage at Melanoma Detection, Screened vs. No Routine Skin Cancer Screening (KQ2)^13,^ ^15,^ ^16^

This figure is a bar graph summarizing stage at melanoma detection in screened populations vs. those with no routine screening from the Matsumoto 2022, Krensel 2020, and Trautmann 2016 studies. These data, which also are reported in Report Table 13, show inconsistent findings. In the U.S.-based study (Matsumoto 2022, 994 melanoma cases), in situ melanoma made up a larger proportion of cases in the screened group compared to the unscreened group (48.3% total melanomas detected in situ in screened group vs 34.6% in unscreened group, adjusted hazard ratio [95% CI]: 2.6 [2.1-3.1]; p<0.001). In the German Krensel 2020 study (n=1536 melanoma cases), there was no association between screening and detection of in situ melanoma. In the German national program (Trautmann 2016 study), both lymph node metastasis and distant metastasis were observed at similar rates. For example, lymph node metastases at detection were similarly detected in persons with documented whole-body screening (5.9%), and those without such documentation (8.5 percent).

Appendix E Figure 4 Thickness at Melanoma or KC Detection, Screened vs. No Routine Skin Cancer Screening (KQ2)^16-18^

This figure is a bar graph summarizing thickness at melanoma detection in screened populations vs. those with no routine screening from the Aitken 2010, Cristofolini 2015, and Matsumoto 2022 studies. These data, which also are reported in Report Table 13, show inconsistent findings. In the Australian study (Aitken 2010), the proportion of melanoma cases detected decreased as thickness increased, with 54.5% of cases detected at 0.01-0.75mm and 6.7% of cases detected at 3mm or greater. In the Italian study (Cristofolini 2015), 70.4% of melanomas detected in the screened group were <1mm compared to 57.7% in the usual care group but the difference was not statistically significant. The total number of melanomas detected at <2mm thickness was statistically significantly higher for screen-detected melanomas (92.6% of screen-detected melanomas were <2mm compared to 75.9% of melanomas in the usual care group, p = 0.043). And in the U.S. study (Matsumoto 2022), among those who underwent routine screening, 37.1% of melanomas were thin invasive (<1mm) and 14.6% were detected at 1mm or greater. Among those who did not undergo routine screening, 37.3% of melanomas were thin invasive (<1mm) and 28.1% were detected at 1mm or greater.

Appendix E Table 1 Age-Standardized Melanoma Incidence per 100,000, SCREEN Study Region and Germany, 1998-2013, Total and by Sex (KQ1, KQ1a)^10^

| Schleswig-Holstein^*^ | Schleswig-Holstein^*^ | Germany^†^ | Germany^†^ | Schleswig-Holstein^*^ | Schleswig-Holstein^*^ | Germany^†^ | Germany^†^ | Schleswig-Holstein^*^ | Schleswig-Holstein^*^ | Germany^†^ | Germany^†^
| Age-standardized incidence rate per 100,000 | Incidence | Age-standardized incidence rate per 100,000 | Incidence | Age-standardized incidence rate per 100,000 | Incidence | Age-standardized incidence rate per 100,000 | Incidence | Age-standardized incidence rate per 100,000 | Incidence | Age-standardized incidence rate per 100,000 | Incidence
Year | Total | Total | Total | Total | Female | Female | Female | Female | Male | Male | Male | Male
1998 | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
1999 | 17.8 | 590 | NR | NR | 19.1 | 334 | NR | NR | 16.5 | 256 | NR | NR
2000 | 19.7 | 657 | NR | NR | 18.8 | 333 | NR | NR | 20.6 | 324 | NR | NR
2001 | 20.5 | 695 | NR | NR | 22 | 388 | NR | NR | 18.9 | 307 | NR | NR
2002 | 17.9 | 609 | NR | NR | 18.8 | 334 | NR | NR | 17 | 275 | NR | NR
2003 | 21.1^‡^ | 718^‡^ | 14 | 13,992 | 24^‡^ | 409^‡^ | 14.3 | 7,483 | 18.3^‡^ | 309^‡^ | 13.6 | 6,508
2004 | 21.3 ^‡^ | 736^‡^ | 14.2 | 14,428 | 22.1^‡^ | 394^‡^ | 13.9 | 7,418 | 20.4^‡^ | 342^‡^ | 14.4 | 7,010
2005 | 17.2 | 632 | 14.5 | 14,966 | 17.2 | 332 | 14.4 | 7,727 | 17.3 | 300 | 14.6 | 7,240
2006 | 15.9 | 591 | 14.3 | 14,987 | 15.7 | 303 | 14.2 | 7,702 | 16.2 | 288 | 14.4 | 7,285
2007 | 15.7 | 590 | 14.9 | 15,740 | 16.2 | 314 | 14.9 | 8,068 | 15.3 | 276 | 14.9 | 7,673
2008 | 17.4^§^ | 661^§^ | 17.7^§^ | 18,852^§^ | 19^§^ | 367^§^ | 17^§^ | 8,068^§^ | 15.9^§^ | 294^§^ | 18.3^§^ | 9,547^§^
2009 | 18.3^§^ | 683^§^ | 17.9^§^ | 19,253^§^ | 18.5^§^ | 339^§^ | 17.2^§^ | 9,305^§^ | 18.1^§^ | 344^§^ | 18.6^§^ | 9,882^§^
2010 | 17.7^§^ | 682^§^ | 18.2^§^ | 19,605^§^ | 18.3^§^ | 349^§^ | 18^§^ | 9,371^§^ | 17.1^§^ | 333^§^ | 18.4^§^ | 9,852^§^
2011 | 17.8^§^ | 701^§^ | 17.9^§^ | 19,646^§^ | 18.7^§^ | 365^§^ | 17.6^§^ | 9,753^§^ | 16.9^§^ | 336^§^ | 18.2^§^ | 9,875^§^
2012^§^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR
2013^§^ | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR | NR

* SCREEN study region.

† Germany data includes Schleswig-Holstein.

‡ Years of SCREEN skin cancer screening program (2003–2004).

§ Years of German national skin cancer screening (2008–2013).