# Appendix D Excluded Studies

E Codes
E1. Not relevant
E2. Not English
E3. Not original research
E4. Publication date (published 2014 or earlier – doesn’t apply to studies carried forward from prior review)
Ineligible SETTING
E5a. Exclusively specialty care setting (dermatology, plastic surgery, etc.)
E5b. Not “very high HDI” country
E5c. Other ineligible setting
Ineligible POPULATION
E6a. Younger than age 15
E6b. (KQ1–3): Already under surveillance for skin cancer (due to previous skin cancer, genetic syndrome, immunosuppression, etc.)
E6c. Other ineligible population
E6d. Overlapping population; contains duplicative data
Ineligible SCREENING
E7a. Lesion-directed diagnostic skin exam (in response to patient concern)
E7b. Other ineligible screening (e.g., skin self-exam, behavioral counseling by clinician for self-exam, biomarkers, consumer smartphone apps)
Ineligible OUTCOMES
E8a. Incomplete study / protocol only
E8b. Other ineligible outcomes
Ineligible STUDY DESIGN
E9a. (KQ 1, 2, 4): No comparison group
E9b. Other ineligible design
E10. Irretrievable
E11. Poor QUALITY

1 2-cm versus 4-cm surgical excision margin for thick (>2 mm) primary malignant melanoma: long-term follow-up of a multicenter randomized trial. European journal of surgical oncology. 2020;462:e15–e16. PMID: CN-02137007. E6c, E8b, E6c, E6c.
2 Abdel-Rahman O Evaluation of the eighth American Joint Committee on Cancer staging system for malignant melanoma of the skin. Future Oncology. 2018;145:471–481. PMID: 29322826. E1, E9b, E1, E1.29322826
3 Afshar N, Dashti S G, Thursfield V, Farrugia H, Giles G G, Milne R L, English D R Do age at diagnosis, tumour thickness and tumour site explain sex differences in melanoma survival? a sequential causal mediation analysis using cancer registry data. Journal of Global Oncology. 2018;4:33s. E1, E3, E1, E1.
4 Aitken J F, Janda M, Elwood M, Youl P H, Ring I T, Lowe J B Clinical outcomes from skin screening clinics within a community-based melanoma screening program. J Am Acad Dermatol. 2006;541:105–14. PMID: 16384764. E8b, E6c, E8b, E8b.16384764
5 Aitken J F, Youlden D R, Baade P D, Soyer H P, Green A C, Smithers B M Generational shift in melanoma incidence and mortality in Queensland, Australia, 1995–2014. International Journal of Cancer. 2018;1428:1528–1535. PMID: 29105744. E1, E8b, E1, E1.29105744
6 20109 ∼ Ajmal S, Comissiong D, Barsky M, Vezeridis M P, Miner T J Surgical treatment of melanoma in elderly: Do we follow NCCN guidelines?. Annals of Surgical Oncology. 2015;221:S123. E6b, E8b, E6b, E6b.
7 Akufo-Tetteh E, Wong C, Black L, Harris A Stripping down to the bare facts: The importance of full-skin examination in the diagnosis of malignant melanoma. British Journal of Dermatology. 2015;173:35. E8b, E8b, E9a, E8b.
8 Al-Himdani S, Naderi N, Whitaker I S, Jones N W An 18-year Study of Malignant Melanoma in Childhood and Adolescence. Plastic and Reconstructive Surgery - Global Open. 2019;78:e2338. PMID: 31592003. E6c, E8b, E6c, E6c.31592003
9 Ali Z, Todd P M Total body skin examination increases squamous cell carcinoma detection: a retrospective cohort study. Clinical & Experimental Dermatology. 2020;451:86–88. PMID: 31120587. E5a, E5a, E5a, E5a.31120587
10 Allais B S, Beatson M, Wang H, Shahbazi S, Bijelic L, Jang S, Venna S Five-Year Survival in Patients with Nodular and Superficial Spreading Melanomas in the US Population. Journal of the American Academy of Dermatology. 2020;:. E6b, E8b, E6b, E6b.
11 Al-Qurayshi Z, Sullivan C B, Schwalje A, Walsh J, Bayon R, Tufano R, Kandil E Presentation and Outcomes of Elderly Patients Undergoing Head and Neck Surgeries: A National Perspective. Otolaryngology - Head and Neck Surgery (United States). 2020;1632:335–343. E6c, E6c, E6c, E6c.
12 Amber K T, Ledon J A, Savas J A, Dusseault S K, Nouri K Visual identification of skin cancer in beachgoers: A need for improved education on non-melanoma skin cancer in the general population and melanoma in the African-American population. International Journal of Dermatology. 2015;543:e85–e87. E1, E1, E1, E1.
13 Amit M, Liu C, Netto Gleber F O, Kini S, Tam S, Benov A, Aashiq M, El-Naggar A K, Moreno A C, Rosenthal D I, Glisson B S, Ferrarotto R, Wong M K, Migden M R, Li G, Khanna A, Goepfert R P, Nagarajan P, Weber R S, Myers J N, Gr Integrating depth of invasion in T classification improves the prognostic performance of the American Joint Committee on Cancer primary tumor staging system for cutaneous squamous cell carcinoma of the head and neck. European Journal of Cancer. 2021;144:169–177. E1, E9b, E1, E1.33352413
14 Anastasiadou Z, Schafer I, Siebert J, Gunther W, Reusch M, Augustin M Participation and health care provision of statutory skin cancer screening in Germany - a secondary data analysis. Journal of the European Academy of Dermatology & Venereology. 2016;303:424–7. PMID: 26856813. E8b, E8a, E8b, E8b.26856813
15 Anders M P, Fengler S, Volkmer B, Greinert R, Breitbart E W Nationwide skin cancer screening in Germany: Evaluation of the training program. International Journal of Dermatology. 2017;5610:1046–1051. PMID: 28832980. E6c, E6c, E6c, E6c.28832980
16 Anderson A J, Kirkwood J M, Ferris L K A pragmatic approach to melanoma screening in collaboration with primary care providers. Cutis. 2016;976:382–3. PMID: 27416080. E3, E3, E3, E3.27416080
17 Anderson A M, Matsumoto M, Saul M I, Secrest A M, Ferris L K Accuracy of Skin Cancer Diagnosis by Physician Assistants Compared With Dermatologists in a Large Health Care System. JAMA Dermatology. 2018;1545:569–573. PMID: 29710082. E8b, E6c, E9b, E8b.29710082
18 Anwar S L, Cahyono R, Budiman H Y, Avanti W S, Harahap W A, Aryandono T Regional lymph node infiltration and thick lesions are associated with poor prognosis in high-risk resected melanomas: A retrospective cohort study. Annals of Medicine and Surgery. 2021;61:132–138. E5b, E5b, E5b, E5b.33456772
19 18313 ∼ Arber N, Leshno A, Shapira S Liberman E, Gur E, Elran H, Kraus S, Sror M, Harlap-Gat A, Galazan L, Jean M, Av G, Kessler A, Blachar A, Golan O, Benjamin S, Geva R, Moshkowitz M One stop screening for multiple cancer types: 10 year experience of an integrated cancer prevention center. Journal of Clinical Oncology. 2016;34:. E7b, E8b, E7b, E7b.
20 Arnold-Bruning F S, Blaschke T, Kramer K, Lademann J, Thiede G, Fluhr J W, Patzelt A, Meinke M C Application of parelectric spectroscopy to detect skin cancer-A pilot study. Skin Research & Technology. 2020;262:234–240. PMID: 31549768. E7a, E8b, E7a, E7a.31549768
21 Asdahl K R, Stolle L B A single-center study on 118 re-excisions and 136 sentinel node biopsies for malignant melanoma. Melanoma Research. 2016;26:e16–e17. E6c, E8b, E6c, E6c.
22 Atique U, Mushtaq S, Rana I A, Hassan U Clinicopathologic Features of Cutaneous Malignant Melanoma and Their Impact on Prognosis. Cureus. 2020;129:e10450. PMID: 33072458. E5b, E5b, E5b, E5b.33072458
23 Augustin J, Sorbe C, Augustin M, Zander N, Kis A Regional variations in the use of statutory skin cancer screenings in Germany: population-based spatial multisource analysis. Journal of the European Academy of Dermatology & Venereology. 2020;348:1736–1743. PMID: 31981431. E8b, E6c, E8b, E8b.31981431
24 Aung P, Milton D, Ivan D, Pradhan D, Nagarajan P, Tetzlaff M, Curry J, Prieto V, Torres-Cabala C Acral lentiginous subtype is an indicator of worse survival in early stage (T1) melanoma. Modern Pathology. 2019;323:. E6c, E8b, E6c, E6c.
25 Autier P, Boniol M, Boniol M, Aegerter P, Saiag P Non-tumour risk factors for cutaneous melanoma relapse. European Journal of Cancer. 2015;51:S153. E6c, E8b, E6c, E6c.
26 Avilés-Izquierdo J A, Molina-López I, Rodríguez-Lomba E, Marquez-Rodas I, Suarez-Fernandez R, Lazaro-Ochaita P Who detects melanoma? Impact of detection patterns on characteristics and prognosis of patients with melanoma. Journal of the American Academy of Dermatology. 2016;755:967–974. E6c, E8b, E6c, E6c.
27 Aviles-Izquierdo J A, Nieto-Benito L M, Lazaro-Ochaita P, Escat-Cortes J L, Marquez-Rodas I, Mercader-Cidoncha E Prognostic significance of sentinel node biopsy status in cutaneous melanoma: a 21-years prospective study from a single institution. Clinical & Translational Oncology: Official Publication of the Federation of Spanish Oncology Societes & of the National Cancer Institute of Mexico. 2020;229:1611–1618. PMID: 32065344. E6c, E8b, E6c, E6c.32065344
28 Bachar G, Tzelnick S, Amiti N, Gutman H Patterns of failure in patients with cutaneous head and neck melanoma. European Journal of Surgical Oncology. 2020;465:914–917. PMID: 31952929. E1, E9b, E1, E1.31952929
29 Bagnoni G D 'Erme A M, Fidanzi C, Viacava P, Strambi S, Spinelli C Melanoma in children, adolescents and young adults: Clinical-pathology, surgery and outcome. Journal of the Dermatology Nurses' Association. 2020;122:. E3, E3, E3, E3.
30 Bajaj S, Collado A, Moran U, Donnelly D M A, Johannet P, Shapiro R L, Berman R S, Weber J S, Zhong J, Osman I The solved and unresolved issues of melanoma staging: A comparison of American Joint Committee on Cancer (AJCC) 7th versus 8th edition. Journal of Clinical Oncology. 2019;37:. E1, E8b, E1, E1.
31 Bajaj S, Donnelly D, Call M, Johannet P, Moran U, Polsky D, Shapiro R, Berman R, Pavlick A, Weber J, Zhong J, Osman I Melanoma prognosis: Accuracy of the american joint committee on cancer staging manual eighth edition. Journal of the National Cancer Institute. 2020;1129:921–928. E1, E9b, E1, E1.
32 4473 ∼ Banting S, Milne D, Thorpe T, Na L, Spillane J, Speakman D, Henderson M A, Gyorki D E Negative Sentinel Lymph Node Biopsy in Patients with Melanoma: The Patienťs Perspective. Annals of Surgical Oncology. 2019;267:2263–2267. PMID: 31011899. E6c, E8b, E6c, E6c.31011899
33 Barclay M E, Abel G A, Elliss-Brookes L, Greenberg D C, Lyratzopoulos G The influence of patient case mix on public health area statistics for cancer stage at diagnosis: a cross-sectional study. European journal of public health. 2019;296:1103–1107. E6c, E8b, E6c, E6c.
34 Barreiro-Capurro A, Andrés-Lencina J J, Podlipnik S, Carrera C, Requena C, Manrique-Silva E, Quaglino P, Tonella L, Jaka A, Richarz N, Rodríguez-Peralto J L, Ortiz P, Boada A, Ribero S, Nagore E, Malvehy J, Puig S Differences in cutaneous melanoma survival between the 7th and 8th edition of the American Joint Committee on Cancer (AJCC). A multicentric population-based study. European Journal of Cancer. 2021;145:29–37. E1, E9b, E1, E1.33418234
35 Bassino S, Ribero S, Miniotti M, Picardi A, Caliendo V, Castelli L, Torta R, Macripò G, Leombruni P Emotional distress and health-related quality of life among cutaneous melanoma follow-up outpatients: The role of selfperception of body image and surgical scarring. European Journal of Dermatology. 2017;274:435–438. E6c, E8b, E6c, E6c.
36 Bay C, Kejs A M, Storm H H, Engholm G Incidence and survival in patients with cutaneous melanoma by morphology, anatomical site and TNM stage: a Danish Population-based Register Study 1989–2011. Cancer Epidemiology. 2015;391:1–7. PMID: 25468643. E1, E9b, E1, E1.25468643
37 Bayers S, Orseth M, Prasad S, Hynan L S, Berry E, Argenbright K, Jacobe H, Savory S Community-based melanoma screening: A pilot study for the development of an educational curriculum for nonphysician providers. Journal of the American Academy of Dermatology. 2021;29:29. E6c, E6c, E6c, E6c.
38 Beal B T, White E K, Behera A K, Zavell A E, McGuinness A E, Blangger H, Armbrecht E S, Maher I A Patients' Body Image Improves After Mohs Micrographic Surgery for Nonmelanoma Head and Neck Skin Cancer. Dermatologic Surgery. 2018;4411:1380–1388. PMID: 29846341. E6c, E8b, E6c, E6c.29846341
39 Beaulieu D, Tsao H, Michaud D S, Okhovat J P, Halpern A C, Geller A C Factors associated with suspected nonmelanoma skin cancers, dysplastic nevus, and cutaneous melanoma among first-time SPOTme screening program participants (2009–2010). Journal of the American Academy of Dermatology. 2018;10:10. PMID: 30543833. E8b, E6c, E8b, E8b.30543833
40 Beaulieu D, Tsao H, Michaud D S, Okhovat J P, Halpern A C, Geller A C Number needed to screen for presumptive screening diagnoses among first-time SPOTme screening participants (1992–2010). Journal of the American Academy of Dermatology. 2020;821:233–234. PMID: 31228527. E8b, E6c, E8b, E8a.31228527
41 Beaulieu D, Tsao H, Michaud D S, Okhovat J P, Halpern A C, Lundberg M, Geller A C A Geographically-Based Cross-Sectional Analysis of SPOT me R Skin Cancer Screening Data. Journal of the American Academy of Dermatology. 2020;10:10. PMID: 32534079. E8a, E8b, E8a, E8a.32534079
42 Behbahani S, Karanfilian K M, Lambert W C Cutaneous melanoma in women: Demographic differences in genders, prognostic factors, and survival outcomes. International Journal of Women's Dermatology. 2020;63:218–219. E6c, E8b, E6c, E6c.
43 Belgrano V, Katsarelias D, Mattsson J, Olofsson Bagge R Sentinel node for malignant melanoma: An observational study of a consecutive single centre experience. European Journal of Surgical Oncology. 2019;452:225–230. PMID: 30391091. E1, E9b, E1, E1.30391091
44 Berger A C, Ollila D W, Christopher A, Kairys J C, Mastrangelo M J, Feeney K, Dabbish N, Leiby B, Frank J A, Stitzenberg K B, Meyers M O Patient Symptoms Are the Most Frequent Indicators of Recurrence in Patients with American Joint Committee on Cancer Stage II Melanoma. Journal of the American College of Surgeons. 2017;2244:652–659. PMID: 28189663. E1, E9b, E1, E1.28189663
45 16298 ∼ Berk-Krauss J, Polsky D, Stein J, Geller A Accelerated melanoma mortality rates among middle-aged white males with tumors of all thicknesses. Journal of Clinical Oncology. 2017;3515:. E6c, E8b, E6c, E6c.
46 Bhardwaj A, Donnellan P Overall survival of unresectable melanoma at Galway university hospital between 2005 and 2017: A retrospective review. Irish Journal of Medical Science. 2018;187:S166–S167. E1, E3, E1, E1.
47 Bianconi F, Crocetti E, Grisci C, Primieri C, Stracci F What has changed in the epidemiology of skin melanoma in central Italy during the past 20 years?. Melanoma Research. 2020;304:396–401. PMID: 30480621. E6c, E9b, E6c, E6c.30480621
48 Blakely A, Fallon E A, Comissiong D S, Vezeridis M P, Miner T J Disease recurrence patterns of head and neck melanoma. Annals of Surgical Oncology. 2016;231:S130. E6b, E8b, E6b, E6b.
49 Blank N R, Giordano C N, Dusza S, Nehal K, Lee E H Patient Expectations Influence Postoperative Facial Satisfaction Measured by the FACE-Q Skin Cancer Module: A Pilot Study. Dermatologic Surgery. 2020;468:1113–1115. PMID: 31306272. E1, E1, E1, E1.31306272
50 Borkowska A M, Szumera-Cieckiewicz A, Spalek M J, Teterycz P, Czarnecka A M, Rutkowski P L Clinicopathological Features and Prognostic Factors of Primary Acral Melanomas in Caucasians. Journal of Clinical Medicine. 2020;99:16. PMID: 32948014. E1, E9b, E1, E1.32948014
51 Bouchard Lj Prevention and early detection of melanoma. Pigment cell & melanoma research. 2017;301:87-. PMID: CN-01333968. E3, E3, E3, E3.
52 Braun R P, Ulrich K, Hunger R, Gaide O, Arnold A, Merat R, Dummer R, Hafner J, French L E, Cozzio A Evaluation of the National Swiss Skin Cancer Screening Campaign 2013: Do We Do the Right Thing. Dermatology. 2017;2335:404–409. PMID: 29237168. E8b, E6c, E9a, E8b.29237168
53 Brecht I B, De Paoli A, Bisogno G, Orbach D, Schneider D T, Leiter U, Offenmueller S, Cecchetto G, Godzinski J, Bien E, Stachowicz-Stencel T, Ben-Ami T, Chiaravalli S, Maurichi A, De Salvo G L, Sorbara S, Bodemer C, Garbe C, Reguerre, Pediatric patients with cutaneous melanoma: A European study. Pediatric Blood & Cancer. 2018;656:e26974. PMID: 29350487. E6a, E6a, E6a, E6a.29350487
54 Brecht I B, Garbe C, Gefeller O, Pfahlberg A, Bauer J, Eigentler T K, Offenmueller S, Schneider D T, Leiter U 443 paediatric cases of malignant melanoma registered with the German Central Malignant Melanoma Registry between 1983 and 2011. European Journal of Cancer. 2015;517:861–8. PMID: 25794606. E1, E8b, E1, E1.25794606
55 Brenner H Mortality From Malignant Melanoma in an Era of Nationwide Skin Cancer Screening. Deutsches Arzteblatt International. 2015;11238:627–8. PMID: 26429633. E1, E1, E1, E1.26429633
56 Brinkman J N, Hajder E, van der Holt B, Den Bakker M A, Hovius S E, Mureau M A The Effect of Differentiation Grade of Cutaneous Squamous Cell Carcinoma on Excision Margins, Local Recurrence, Metastasis, and Patient Survival: A Retrospective Follow-Up Study. Annals of Plastic Surgery. 2015;753:323–6. PMID: 24401812. E6c, E8b, E6c, E6c.24401812
57 Brunßen A, Hübner J, Schadendorf D, Terheyden P, Katalinic A Impact of skin cancer screening on the incidence of advanced melanoma and melanoma mortality - A pilot project for a case-control study in the setting of the German nationwide skin cancer screening (PiKoM). Oncology Research and Treatment. 2018;41:159. E1, E1, E1, E1.
58 17968 ∼ Brunssen A, Jansen L, Eisemann N, Waldmann A, Kraywinkel K, Eberle A, Holleczek B, Zeißig S, Brenner H, Katalinic A Relative survival from melanoma stratified by tumor stage and histological subtype. European Journal of Epidemiology. 2016;31:S31–S32. E6c, E8a, E6c, E6c.
59 Brunssen A, Jansen L, Eisemann N, Waldmann A, Weberpals J, Kraywinkel K, Eberle A, Holleczek B, Zeissig S R, Brenner H, Katalinic A Long-term relative survival from melanoma in Germany 1997–2013. Melanoma Research. 2020;:386–395. E6c, E8b, E6c, E6c.30020195
60 Brunssen A, Jansen L, Eisemann N, Waldmann A, Weberpals J, Kraywinkel K, Eberle A, Holleczek B, Zeissig S R, Brenner H, Katalinic A, Gekid Cancer Survival Working Group A population-based registry study on relative survival from melanoma in Germany stratified by tumor thickness for each histologic subtype. Journal of the American Academy of Dermatology. 2019;804:938–946. PMID: 30244061. E1, E9b, E1, E1.30244061
61 Burki T K Total body exam or lesion detection screening for skin cancer?. Lancet Oncology. 2015;1616:e590. PMID: 26511646. E3, E3, E3, E3.26511646
62 Cavanaugh-Hussey M W, Mu E W, Kang S, Balch C M, Wang T Older Age is Associated with a Higher Incidence of Melanoma Death but a Lower Incidence of Sentinel Lymph Node Metastasis in the SEER Databases (2003–2011). Annals of Surgical Oncology. 2015;227:2120–6. PMID: 25940571. E1, E8b, E1, E1.25940571
63 Chae J K, Kim J H, Kim E J, Park K Values of a Patient and Observer Scar Assessment Scale to Evaluate the Facial Skin Graft Scar. Annals of Dermatology. 2016;285:615–623. PMID: 27746642. E6c, E6c, E6c, E8b.27746642
64 Chan K K, Chan R C, Ho R S, Chan J Y Clinical Patterns of Melanoma in Asians: 11-- Year Experience in a Tertiary Referral Center. Annals of Plastic Surgery. 2016;77 Suppl 1:S6–S11. PMID: 26808749. E6c, E8b, E6c, E6c.26808749
65 Chang K L, Brown L Screening for hereditary cancer syndromes. American Family Physician. 2015;912:130–1. PMID: 25591216. E1, E1, E1, E1.
66 Chang Y C, Anolik R B, Cabral H, Bhawan J Frequency of squamous cell carcinoma in situ (SCCIS) and SCC in re-excisions of biopsy-proven cutaneous SCCIS. British Journal of Dermatology. 2017;1776:1747–1748. PMID: 27943251. E3, E3, E3, E3.27943251
67 Chapman B, Paniccia A, Merkow J, Jones E L, Jones T S, Hodges M, Kounalakis N, Gajdos C, McCarter M D Increased size of sentinel lymph node is associated with disease-specific survival for cutaneous melanoma. Journal of the American College of Surgeons. 2015;2214:e130. E6c, E6c, E6c, E6c.
68 Chayangsu C Clinicopathological characteristics and prognostic factors of malignant melanoma: A retrospective analysis of a 12-year study. Annals of Oncology. 2017;28:x115–x116. E5b, E5b, E5b, E5b.
69 Chen J, Xu Y, Zhou Y, Wang Y, Zhu H, Shi Y Prognostic role of sentinel lymph node biopsy for patients with cutaneous melanoma: A retrospective study of surveillance, epidemiology, and end-result population-based data. Oncotarget. 2016;729:45671–45677. PMID: 27344178. E6c, E8b, E6c, E6c.27344178
70 Chen Y F, Ma H, Perng C K, Feng C J Prognostic Factors and Clinical Outcomes of Clinical Node-Negative Cutaneous Malignant Melanoma Patients: An Asian Single Institute Study. Annals of Plastic Surgery. 2020;841S Suppl 1:S48–S53. PMID: 31833887. E1, E9b, E1, E1.31833887
71 16398 ∼ Ciurea A, Pacheco D, Rivera Y, Benson D, Tripp M Project DERM: Skin cancer health education, screening services and outcomes in an underserved population in Harris County, TX. Journal of the American Academy of Dermatology. 2017;766:AB205. E7b, E8b, E7b, E8b.28917460
72 Claeson M, Gillstedt M, Whiteman D C, Paoli J Lethal Melanomas: A Population-based Registry Study in Western Sweden from 1990 to 2014. Acta Dermato-Venereologica. 2017;9710:1206–1211. PMID: 28761961. E1, E9b, E1, E1.28761961
73 Coco V, Farnetani F, Cesinaro A M, Ciardo S, Argenziano G, Peris K, Pellacani G, Longo C False-Negative Cases on Confocal Microscopy Examination: A Retrospective Evaluation and Critical Reappraisal. Dermatology. 2016;2322:189–197. E6b, E8b, E6b, E6b.
74 Conde-Ferreirós A, Corchete L A, Puebla-Tornero L, Corchado-Cobos R, García-Sancha N, Román-Curto C, Cañueto J Definition of prognostic subgroups in the T3 stage of the eighth edition of the American Joint Committee on Cancer staging system for cutaneous squamous cell carcinoma: Tentative T3 stage subclassification. Journal of the American Academy of Dermatology. 2020;:. E6c, E9b, E6c, E6c.
75 Conic R, Cabrera C, Gastman B Does time to treatment matter in melanoma?. Journal of the American Academy of Dermatology. 2017;766:AB103. E6c, E8b, E6c, E6c.
76 Connolly K L, Nehal K S, Dusza S W, Rossi A M, Lee E H Assessment of intraoperative pain during Mohs micrographic surgery (MMS): An opportunity for improved patient care. Journal of the American Academy of Dermatology. 2016;753:590–594. PMID: 27125530. E1, E1, E1, E1.27125530
77 Crocetti E, Fancelli L, Manneschi G, Caldarella A, Pimpinelli N, Chiarugi A, Nardini P, Buzzoni C Melanoma survival: Sex does matter, but we do not know how. European Journal of Cancer Prevention. 2016;255:404–409. E6c, E9b, E6c, E6c.
78 Crocetti E, Mallone S, Robsahm T E, Gavin A, Agius D, Ardanaz E, Lopez M C, Innos K, Minicozzi P, Borgognoni L, Pierannunzio D, Eisemann N, Eurocare- Working Group Survival of patients with skin melanoma in Europe increases further: Results of the EUROCARE-5 study. European Journal of Cancer. 2015;5115:2179–2190. PMID: 26421821. E6c, E8b, E6c, E6c.26421821
79 Crocetti E, Stanganelli I, Mancini S, Vattiato R, Giuliani O, Ravaioli A, Balducci C, Falcini F, Pimpinelli N Evaluation of the agreement between TNM 7th and 8th in a population-based series of cutaneous melanoma. Journal of the European Academy of Dermatology & Venereology. 2019;333:521–524. PMID: 30317667. E1, E9b, E1, E1.30317667
80 Curiel-Lewandrowski C, Swetter S M Lack of harms from community-based melanoma screening by primary care providers. Cancer. 2016;12220:3102–3105. PMID: 27392136. E1, E1, E1, E1.27392136
81 D'Acunto C, Raone B, Neri I, Passarini B, Patrizi A Outpatient pediatric dermatologic surgery: Experience in 296 patients. Pediatric Dermatology. 2015;323:424–426. E6a, E6a, E6a, E6a.
82 de Freitas C A F, Santos A N, Bittner G C, Sanabria B D, Levenhagen Mmmd, Hans-Filho G Nonmelanoma Skin Cancer at Critical Facial Sites: Results and Strategies of the Surgical Treatment of 102 Patients. Journal of Skin Cancer. 2019;2019:4798510. PMID: 31346477. E6c, E7b, E6c, E6c.31346477
83 De Giorgi V, Grazzini M, Savarese I, Gori A, Papi F, D'Errico A, Scarfi F, Gandini S The impact of body area in melanoma self-detection: a retrospective study. European Journal of Cancer Prevention. 2015;244:343–6. PMID: 25325306. E7b, E7b, E7b, E7b.25325306
84 9325 ∼ De Giorgi V, Scarfì F, Gori A, Silvestri F, Trane L, Maida P, Venturi F, Covarelli P Short-term teledermoscopic monitoring of atypical melanocytic lesions in the early diagnosis of melanoma: utility more apparent than real. Journal of the European Academy of Dermatology and Venereology. 2020;348:e398–e399. E3, E3, E3, E3.
85 Deep N L, Glasgow A E, Habermann E B, Kasperbauer J L, Carlson M L Melanoma of the external ear: A population-based study. American Journal of Otolaryngology. 2017;383:309–315. PMID: 28258767. E1, E9b, E1, E1.28258767
86 Deinlein T, Michor C, Hofmann-Wellenhof R, Schmid-Zalaudek K, Fink-Puches R The importance of total-body photography and sequential digital dermatoscopy for monitoring patients at increased melanoma risk. Journal der Deutschen Dermatologischen Gesellschaft. 2020;187:692–697. PMID: 32597015. E5a, E8b, E5a, E6b.32597015
87 Del Fiore P, Russo I, Ferrazzi B, Monico A D, Cavallin F, Filoni A, Tropea S, Russano F, Di Prata C, Buja A, Collodetto A, Spina R, Carraro S, Cappellesso R, Nicolè L, Chiarion-Sileni V, Pigozzo J, Dall’Olmo L, Rastrelli M, Vecchiato Melanoma in Adolescents and Young Adults: Evaluation of the Characteristics, Treatment Strategies, and Prognostic Factors in a Monocentric Retrospective Study. Frontiers in Oncology. 2021;11:. E6c, E8b, E6c, E6c.
88 DeMarco S S, Vos P, Green H, Defazio J, Davis N, Fiz L, Phillips C A 10-year review of outpatient skin biopsy results and skin cancer subtypes. Dermatology Online Journal. 2016;221:15. PMID: 26990466. E5a, E8b, E5a, E5a.26990466
89 Dessinioti C, Geller A C, Stergiopoulou A, Swetter S M, Baltas E, Mayer J E, Johnson T M, Talaganis J, Trakatelli M, Tsoutsos D, Tsourouflis G, Stratigos A J Association of Skin Examination Behaviors and Thinner Nodular vs Superficial Spreading Melanoma at Diagnosis. JAMA Dermatology. 2018;1545:544–553. PMID: 29710122. E6c, E6c, E6c, E6c.29710122
90 Di Carlo V, Esteve J, Johnson C, Girardi F, Weir H K, Wilson R J, Minicozzi P, Cress R D, Lynch C F, Pawlish K S, Rees J R, Coleman M P, Allemani C, Us Concord Working Group Trends in short-term survival from distant-stage cutaneous melanoma in the United States, 2001–2013 (CONCORD-3). JNCI Cancer Spectrum. 2020;46:pkaa078. PMID: 33409455. E1, E9b, E1, E1.33409455
91 Dika E, Chessa M A, Veronesi G, Ravaioli G M, Fanti P A, Ribero S, Tripepi G, Gurioli C, Gradassi A T, Lambertini M, Patrizi A A single institute's experience on melanoma prognosis: A long-term follow-up. Giornale Italiano di Dermatologia e Venereologia. 2018;1533:326–332. E1, E9b, E1, E1.
92 Dinnes J, Deeks J J, Chuchu N, Saleh D, Bayliss S E, Takwoingi Y, Davenport C, Patel L, Matin R N, O'Sullivan C, Patalay R, Williams H C, Cochrane Skin Cancer Diagnostic Test Accuracy Group Reflectance confocal microscopy for diagnosing keratinocyte skin cancers in adults. Cochrane Database of Systematic Reviews. 2018;12:CD013191. PMID: 30521687. E6c, E8b, E6c, E6c.30521687
93 Dinnes J, Deeks J J, Grainge M J, Chuchu N, Ferrante di Ruffano L, Matin R N, Thomson D R, Wong K Y, Aldridge R B, Abbott R, Fawzy M, Bayliss S E, Takwoingi Y, Davenport C, Godfrey K, Walter F M, Williams H C, Cochrane Skin Cance Visual inspection for diagnosing cutaneous melanoma in adults. Cochrane Database of Systematic Reviews. 2018;12:CD013194. PMID: 30521684. E9b, E1, E9b, E9b.30521684
94 Dominguez M L, Suarez J P, Fernandez P, Rayo J I, Rodriguez O D, Gonzalez F M Prognostic significance of the effect of delay time between primary melanoma biopsy and sentinel lymph node biopsy. European Journal of Nuclear Medicine and Molecular Imaging. 2017;442:S753. E6c, E8b, E6c, E6c.
95 Donigan J M, Millican E A Cosmetic and Functional Outcomes of Second Intention Healing for Mohs Defects of the Lips. Dermatologic Surgery. 2019;451:26–35. PMID: 29994950. E6c, E8b, E6c, E6c.29994950
96 Duarte C A, Florez J P, Lopez H G, Meneses M X, de Vries E Survival of acral lentiginous melanoma in the National Cancer Institute of Colombia. Journal of the European Academy of Dermatology & Venereology. 2017;313:438–442. PMID: 27518480. E5b, E5b, E5b, E5b.27518480
97 7587 ∼ Dubal P M, Bhojwani A, Patel T D, Zuckerman O, Baredes S, Liu J K, J A Squamous cell carcinoma of the maxillary sinus: A population-based analysis. Laryngoscope. 2016;1262:399–404. PMID: 26393540. E6c, E6c, E6c, E6c.26393540
98 Dumitra S, Raoof M, Marcinkowski E, Schoellhammer H F, Barkun J S, Fong Y, Melstrom L Sentinel lymph node biopsy in octogenarians with very thick melanomas does not impact survival. Annals of Surgical Oncology. 2016;231:S130. E6c, E8b, E6c, E6c.
99 Duquette S P, Wooden W, Coleman J, Tholpady S Melanoma Extirpation with Immediate Reconstruction: The Oncologic Safety and Cost Savings of Single-Stage Treatment. Plastic & Reconstructive Surgery. 2017;1393:796e-797e. PMID: 28234869. E1, E1, E1, E1.28234869
100 Duran J, Morgan F C, Karia P S, Schmults C D An evaluation of high-stage cutaneous squamous cell carcinoma outcomes by sex. British Journal of Dermatology. 2017;1774:1131–1133. E6c, E8b, E6c, E6c.
101 Durmus Ucar A N, Durmus Kocaaslan F N, Salman A, Demirkesen C, Erdem Bayram F, Bayramicli M Margin-Controlled, Staged Surgical Excision in the Treatment of High-Risk Basal Cell Carcinomas of the Head and Neck Region. Journal of Cutaneous Medicine & Surgery. 2019;233:258–264. PMID: 30556424. E6b, E8b, E6b, E6b.30556424
102 Earp E, Mackie L, Todd P Hidden so seek: Incidental melanoma found on full-skin examination. British Journal of Dermatology. 2019;181:63. E5a, E5a, E5a, E5a.
103 Echanique K, Ghazizadeh S, Moon A, Kwan K, St John M Rate of regional recurrence in head and neck melanoma after negative sentinel lymph node biopsy. Otolaryngology - Head and Neck Surgery. 2019;1612:P82. E6c, E6c, E6c, E6c.
104 Eisemann N Routine health data in skin cancer screening evaluation. British Journal of Dermatology. 2016;1755:862. PMID: 27790681. E3, E3, E3, E3.27790681
105 Eisemann N, Jansen L, Castro F A, Chen T, Eberle A, Nennecke A, Zeissig S R, Brenner H, Katalinic A, Gekid Cancer Survival Working Group Survival with nonmelanoma skin cancer in Germany. British Journal of Dermatology. 2016;1744:778–85. PMID: 26676514. E6c, E8b, E6c, E6c.26676514
106 Eisemann N, Waldmann A, Geller A C, Weinstock M A, Volkmer B, Greinert R, Breitbart E W, Katalinic A Non-Melanoma Skin Cancer Incidence and Impact of Skin Cancer Screening on Incidence. J Invest Dermatol. 2014;1341:43–50. PMID: 23877569. E8b, E8b, E8b, E8b.23877569
107 El Sharouni M A, Aivazian K, Witkamp A J, Sigurdsson V, Van Gils C H, Scolyer R A, Thompson J F, Van Diest P J, Lo S N Association of Histologic Regression with a Favorable Outcome in Patients with Stage 1 and Stage 2 Cutaneous Melanoma. JAMA Dermatology. 2020;:. E1, E9b, E1, E1.
108 El Sharouni M A, van Diest P J, Witkamp A J, Sigurdsson V, van Gils C H Subtyping Cutaneous Melanoma Matters. JNCI Cancer Spectrum. 2020;46:pkaa097. PMID: 33409460. E1, E8b, E1, E1.33409460
109 el Sharouni M A, Witkamp A J, Sigurdsson V, van Diest P J, Louwman M W J, Kukutsch N A Sex matters: men with melanoma have a worse prognosis than women. Journal of the European Academy of Dermatology and Venereology. 2019;3311:2062–2067. E1, E9b, E1, E1.
110 3658 ∼ El Sharouni M A, Witkamp A J, Sigurdsson V, van Diest P J, Suijkerbuijk K P M Thick melanomas without lymph node metastases: A forgotten group with poor prognosis. European Journal of Surgical Oncology. 2020;465:918–923. PMID: 31901365. E6b, E6b, E6b, E6b.31901365
111 Elder D E Melanoma Screening and Mortality. Journal of the National Cancer Institute. 2018;11010:1135–1136. PMID: 29618115. E3, E3, E3, E3.29618115
112 Ellison H B, Allard-Picou A, Dove J T, Arora T K, Shabahang M M, Blansfield J A Melanoma outcomes based on histologic subtype: A review of the National Cancer Database. Annals of Surgical Oncology. 2015;221:S111. E1, E3, E1, E1.
113 Enamandram M, Duncan L M, Kimball A B Delivering value in dermatology: insights from skin cancer detection in routine clinical visits. Journal of the American Academy of Dermatology. 2015;722:310–3. PMID: 25484266. E5a, E5a, E5a, E5a.25484266
114 Eriksson H, Lyth J, Andersson T M The proportion cured of patients diagnosed with Stage III-IV cutaneous malignant melanoma in Sweden 1990–2007: A population-based study. International Journal of Cancer. 2016;13812:2829–36. PMID: 26815934. E1, E9b, E1, E1.26815934
115 Ernst D S, Petrella T, Joshua A M, Hamou A, Thabane M, Vantyghem S, Gwadry-Sridhar F Burden of illness for metastatic melanoma in Canada, 2011–2013. Current Oncology. 2016;236:e563–e570. PMID: 28050145. E1, E9b, E1, E1.28050145
116 Evrard D, Routier E, Mateus C, Tomasic G, Lombroso J, Kolb F, Robert C, Moya-Plana A Sentinel lymph node biopsy in cutaneous head and neck melanoma. European Archives of Oto-Rhino-Laryngology. 2018;2755:1271–1279. E6b, E8b, E6b, E6b.
117 Fayne R, Forouzandeh M, De Bedout V, Zarei M, Fox J D, Aigen A R, Solle N, Caban-Martinez A, Koru-Sengul T, Kirsner R S, Jaimes N 18466 Skin cancer screening using total body photography and digital dermoscopy: A pilot study among firefighters. Journal of the American Academy of Dermatology. 2020;836:AB212. E8b, E8b, E8b, E8b.
118 Fayyaz F, Shellenberger R A Does the initial biopsy type affect clinically important outcomes in malignant melanoma? A meta-analysis. Journal of Clinical Oncology. 2019;37:. E3, E3, E3, E3.
119 Feichtenschlager V, Weihsengruber F, Richter L, Vujic I, Rappersberger K, Posch C Clinical melanoma characteristics and survival—a single-center retrospective study between 2000 and 2010. Wiener Medizinische Wochenschrift. 2019;16913–14:323–330. E1, E9b, E1, E1.
120 Feigelson H S, Powers J D, Kumar M, Carroll N M, Pathy A, Ritzwoller D P Melanoma incidence, recurrence, and mortality in an integrated healthcare system: A retrospective cohort study. Cancer Medicine. 2019;89:4508–4516. PMID: 31215776. E1, E9b, E1, E1.31215776
121 Fernández-de-Misa Cabrera R, González Delgado B, Gambra Michel L E, Casale C, Lopez Figueroa A, Uña Gorospe J, Martínez Cedrés J C, Cabrera Suárez M A, Garrido Ríos S, Hernández Hernández N, Tébar Díaz A, Sánchez Barrios A, Allende Riera A Clinicopathological characteristics of cutaneous malignant melanoma in patients at a tertiary hospital in Macaronesia. Survival as a function of locoregional prognostic factors per the American Joint Committee on Cancer. International Journal of Dermatology. 2018;572:193–201. E1, E5b, E1, E1.
122 Fernandez-de-Misa Cabrera, Gambra L E Michel, Una J Gorospe, Lopez A L Figueroa, Nogales Mullor R, Martinez J C Cedres, Cabrera Suarez M A, Garrido Rios S, Hernandez N Hernandez, Suarez J Hernandez, Allende Riera A Disease-Free Survival for Patients with Thin Melanomas according to the American Joint Committee on Cancer 8th Edition. Dermatology. 2019;2354:334–339. PMID: 31112971. E1, E8b, E1, E1.31112971
123 1758 ∼ Ferrandiz L, Ojeda-Vila T, Corrales A, Martin-Gutierrez Fj, Ruiz-de-Casas A, Galdeano R, Alvarez-Torralba I, Sanchez-Ibanez F, Dominguez-Toro Jm, Encina F, Impact of dermoscopy on an internet-based skin cancer triage system: interim results of a randomized study. Journal of the american academy of dermatology. 2017;762:342–343. PMID: CN-01374653. E8b, E8b, E8b, E8b.
124 Ferrante di Ruffano L, Takwoingi Y, Dinnes J, Chuchu N, Bayliss S E, Davenport C, Matin R N, Godfrey K, O'Sullivan C, Gulati A, Chan S A, Durack A, O'Connell S, Gardiner M D, Bamber J, Deeks J J, Williams H C, Cochrane Skin Cancer D Computer-assisted diagnosis techniques (dermoscopy and spectroscopy-based) for diagnosing skin cancer in adults. Cochrane Database of Systematic Reviews. 2018;12:CD013186. PMID: 30521691. E3, E3, E3, E3.30521691
125 Ferris L, Saul M, Lin Y, Weinstock M A, Geller A, Solano F, Neuren E B, Kirkwood J M Preliminary outcomes of a primary care-based skin cancer screening program. Journal of Clinical Oncology. 2016;34:. E3, E3, E3, E3.
126 Fink C, Jaeger C, Jaeger K, Haenssle H A Diagnostic performance of the MelaFind device in a real-life clinical setting. Journal der Deutschen Dermatologischen Gesellschaft. 2017;154:414–419. PMID: 28332777. E5b, E8b, E5a, E5a.28332777
127 Finnegan L A, Mc Namara A T, Buckley C E, Joyce K M, Jones D M, Kelly J L, Regan P J, Hussey A J, Mc Inerney N M Accuracy and prognostic value of sentinel lymph node biopsy in head and neck melanoma. Irish Journal of Medical Science. 2019;188:S180–S181. E6c, E8b, E6c, E6c.
128 Fix W C, Miller C, Etzkorn J, Shin T, Howe N, Zhang J, Sobanko J F Patient scar assessment correlates with quality of life (QOL) after mohs micrographic surgery (MMS). Journal of Investigative Dermatology. 2018;1385:S89. E6c, E8b, E6c, E6c.
129 Fleming P, Fung K, Chan A 194 Dermatologic assessment is associated with improved melanoma outcomes: population-based cohort study. Journal of Investigative Dermatology. 2019;1395:S34. E6c, E8b, E6c, E6c.
130 Forbes B, Secrest A, Hand M Q, Eliason M J Process of standardized postoperative telephone follow-up implementation for Mohs micrographic surgery. Journal of the American Academy of Dermatology. 2018;793:AB230. E6c, E8b, E6c, E6c.
131 Forschner A, Eichner F, Amaral T, Keim U, Garbe C, Eigentler T K Improvement of overall survival in stage IV melanoma patients during 2011–2014: analysis of real-world data in 441 patients of the German Central Malignant Melanoma Registry (CMMR). Journal of Cancer Research & Clinical Oncology. 2017;1433:533–540. PMID: 27878363. E6c, E8b, E6c, E6c.27878363
132 Forschner A, Keim U, Hofmann M, Spankuch I, Lomberg D, Weide B, Tampouri I, Eigentler T, Fink C, Garbe C, Haenssle H A Diagnostic accuracy of dermatofluoroscopy in cutaneous melanoma detection: results of a prospective multicentre clinical study in 476 pigmented lesions. British Journal of Dermatology. 2018;1792:478–485. PMID: 29569229. E5a, E6c, E5a, E5a.29569229
133 Fortes C, Mastroeni S, Caggiati A, Passarelli F, Zappala A, Capuano M, Bono R, Nudo M, Marino C, Michelozzi P The effect of time to sentinel lymph node biopsy on cutaneous melanoma survival. American Journal of Surgery. 2016;2125:935–940. PMID: 27266393. E1, E9b, E1, E1.27266393
134 Fortes C, Mastroeni S, Mannooranparampil T J, Passarelli F, Zappala A, Annessi G, Marino C, Caggiati A, Russo N, Michelozzi P Tumor-infiltrating lymphocytes predict cutaneous melanoma survival. Melanoma Research. 2015;254:306–11. PMID: 25933208. E6c, E6c, E6c, E6c.25933208
135 Franklin M M, Nash S Melanoma histology and stage at presentation in American Indian and Alaska native people. Journal of Investigative Medicine. 2018;661:254. E6c, E8b, E6c, E6c.
136 14914 ∼ Friedrich S, Arndt V, Becker N, Haug U Are there adequate data for a population-based evaluation of innovative therapies in the treatment of malignant melanoma in Germany?. Oncology Research and Treatment. 2018;41:51. E6b, E8b, E6b, E6b.
137 Fritschi L, Dye S A, Katris P Validity of melanoma diagnosis in a community-based screening program. Am J Epidemiol. 2006;1644:385–90. PMID: 16760225. E8b, E6c, E8b, E8b.16760225
138 Frohlich S M, Cazzaniga S, Kaufmann L S, Hunger R E, Seyed Jafari S M A Retrospective Cohort Study on Patients with Lentigo Maligna Melanoma. Dermatology. 2019;2354:340–345. PMID: 31112945. E1, E9b, E1, E1.31112945
139 Fujisawa Y, Yoshikawa S, Minagawa A, Takenouchi T, Yokota K, Uchi H, Kamo R, Nakamura Y, Kato J, Asai J Epidemiology of malignant melanoma in Japan: Analysis of 4239 patient data. Journal of Investigative Dermatology. 2017;13710:S288. E1, E1, E1, E1.
140 Fujisawa Y, Yoshikawa S, Minagawa A, Takenouchi T, Yokota K, Uchi H, Noma N, Nakamura Y, Asai J, Kato J, Fujiwara S, Fukushima S, Uehara J, Hoashi T, Kaji T, Fujimura T, Namikawa K, Yoshioka M, Murata N, Ogata D, Matsuyama K, Hatta N Classification of 3097 patients from the Japanese melanoma study database using the American joint committee on cancer eighth edition cancer staging system. Journal of Dermatological Science. 2019;942:284–289. PMID: 31023613. E1, E9b, E1, E1.31023613
141 Furtner J, Berghoff A S, Schöpf V, Reumann R, Pascher B, Woitek R, Asenbaum U, Pelster S, Leitner J, Widhalm G, Gatterbauer B, Dieckmann K, Höller C, Prayer D, Preusser M Temporal muscle thickness is an independent prognostic marker in melanoma patients with newly diagnosed brain metastases. Journal of Neuro-Oncology. 2018;1401:173–178. E6b, E8b, E6b, E6b.
142 G Lben K, Berberoglu U, Altinyollar H, Kinas V, Turanli S Sentinel lymph node status affects long-term survival in patients with intermediate-thickness melanoma. Journal of Cancer Research & Therapeutics. 2016;122:840–4. PMID: 27461661. E6c, E8b, E6c, E6c.27461661
143 Gao J M, Adams L, Ismail F Full-skin examinations in the National Health Service: Life-saving or time-wasting?. British Journal of Dermatology. 2020;183 SUPPL 1:23. E3, E3, E3, E3.
144 Geller A C, Swetter S M, Weinstock M A Focus on early detection to reduce melanoma deaths. Journal of Investigative Dermatology. 2015;1354:947–949. PMID: 25785949. E3, E3, E3, E3.25785949
145 Gershenwald J E, Scolyer R A, Hess K R, Sondak V K, Long G V, Ross M I, Lazar A J, Faries M B, Kirkwood J M, McArthur G A, Haydu L E, Eggermont A M M, Flaherty K T, Balch C M, Thompson J F, for members of the American Joint Melanoma staging: Evidence-based changes in the American Joint Committee on Cancer eighth edition cancer staging manual. CA: a Cancer Journal for Clinicians. 2017;676:472–492. PMID: 29028110. E1, E8b, E1, E1.29028110
146 Gil_Quijano A M, Hernández J Vargas, Ramirez P Barbosa, A M Valbuena Garcia, Acuña Merchan L PCN219 Incidence and Distribution of Tumor STAGE of Melanoma in Adults By Sex. Colombia, 2019. Value in Health. 2020;23:S461–S462. E5b, E5b, E5b, E5b.
147 Giordano C N, Mori S, Navarrete-Dechent C, Dusza S W, Rossi A M, Nehal K S, Lee E H Patient Concerns in the Immediate Postoperative Period After Mohs Micrographic Surgery. Dermatologic Surgery. 2020;464:514–518. PMID: 31592922. E6c, E8b, E6c, E6c.31592922
148 Gjorup C, Grønvold M, Dahlstrøm K, Drzewiecki K T, Christensen K B, Hendel H W, Hölmich L R Lymphoedema following sentinel lymph node biopsy and/or complete lymph node dissection: Impact on health-related quality of life. Melanoma Research. 2016;26:e119–e120. E6c, E8b, E6c, E6c.
149 Gkini M A, Leeman H, Sahota A Healing by secondary intention on the nose: An evaluation of patient satisfaction after Mohs micrographic surgery for basal cell carcinomas. British Journal of Dermatology. 2018;179:121. E6c, E8b, E6c, E6c.
150 5294 ∼ Gonzalez A B, Baum C L, Brewer J D, Arpey C J, Harmsen W S, Suman V J, Markovic S N, Jakub J W Patterns of failure following the excision of in-transit lesions in melanoma and the influence of excisional margins. Journal of Surgical Oncology. 2018;1184:606–613. PMID: 30114337. E1, E1, E1, E1.30114337
151 Gorig T, Schneider S, Schilling L, Diehl K Barriers to Using a Nationwide Skin Cancer Screening Program: Findings from Germany. Oncology Research and Treatment. 2018;4112:774–779. PMID: 30458453. E8b, E8b, E8b, E8b.30458453
152 Green A C, Baade P, Coory M, Aitken J F, Smithers M Population-based 20-year survival among people diagnosed with thin melanomas in Queensland, Australia. J Clin Oncol. 2012;3013:1462–7. PMID: 22412152. E6b, E8b, E6b, E6b.22412152
153 Grogan J, Cooper C L, Dodds T J, Guitera P, Menzies S W, Scolyer R A Punch 'scoring': a technique that facilitates melanoma diagnosis of clinically suspicious pigmented lesions. Histopathology. 2018;722:294–304. PMID: 28796900. E6c, E8b, E6c, E6c.28796900
154 Guevara M, Rodríguez-Barranco M, Puigdemont M, Minicozzi P, Yanguas-Bayona I, Porras-Povedano M, Rubió-Casadevall J, Sánchez Pérez M J, Marcos-Gragera R, Ardanaz E Disparities in the management of cutaneous malignant melanoma. A population-based high-resolution study. European journal of cancer care. 2019;284:e13043. E6c, E8b, E6c, E6c.
155 Guo W, Yin Gf, Chen Xh, Huang Zg Analysis of distant metastasis and related factors of head and neck mucosal melanoma. Lin chuang er bi yan hou tou jing wai ke za zhi [Journal of clinical otorhinolaryngology, head, and neck surgery]. 2018;3214:1078–1081. PMID: CN-02138144. E2, E2, E2, E2.
156 Haeberle M Skin cancer screening at the workplace in a large trading company. British Journal of Dermatology. 2016;175:63. E5a, E8b, E5a, E8b.
157 Haenssle H A, Hoffmann S, Holzkamp R, Samhaber K, Lockmann A, Fliesser M, Emmert S, Schon M P, Rosenberger A, Buhl T Melanoma thickness: the role of patients' characteristics, risk indicators and patterns of diagnosis. Journal of the European Academy of Dermatology & Venereology. 2015;291:102–8. PMID: 24646029. E8b, E8b, E8b, E8b.24646029
158 Hafstrom A, Romell A, Ingvar C, Wahlberg P, Greiff L Sentinel lymph node biopsy staging for cutaneous malignant melanoma of the head and neck. Acta Oto-Laryngologica. 2016;1363:312–8. PMID: 26767628. E6c, E8b, E6c, E6c.26767628
159 Han A Y, Kuan E C, Mallen-St Clair J, Alonso J E, Arshi A, St John M A Epidemiology of Squamous Cell Carcinoma of the Lip in the United States: A Population-Based Cohort Analysis. JAMA Otolaryngology-- Head & Neck Surgery. 2016;14212:1216–1223. PMID: 27832256. E1, E9b, E1, E1.27832256
160 Han D, Han G, Morrison S, Leong S P, Kashani-Sabet M, Vetto J, White R, Schneebaum S, Pockaj B, Mozzillo N, Sondak V K, Zager J S Factors predicting survival in thick melanoma: Do all thick melanomas have the same prognosis?. Surgery. 2020;1683:518–526. PMID: 32669204. E1, E8b, E1, E1.32669204
161 Han D, Han G, Zhao X, Rao N G, Messina J L, Marzban S S, Sarnaik A A, Cruse C W, Sondak V K, Zager J S Clinicopathologic predictors of survival in patients with desmoplastic melanoma. PLoS ONE [Electronic Resource]. 2015;103:e0119716. PMID: 25811671. E6c, E8b, E6c, E6c.25811671
162 Han S S, Moon I J, Kim S H, Na J I, Kim M S, Park G H, Park I, Kim K, Lim W, Lee J H, Chang S E Assessment of deep neural networks for the diagnosis of benign and malignant skin neoplasms in comparison with dermatologists: A retrospective validation study. PLoS Medicine / Public Library of Science. 2020;1711:e1003381. PMID: 33237903. E6b, E8b, E6b, E6b.33237903
163 Hanson J L, Kingsley-Loso J L, Grey K R, Raju S I, Parks P R, Bershow A L, Warshaw E M Incidental melanomas detected in veterans referred to dermatology. Journal of the American Academy of Dermatology. 2016;743:462–9. PMID: 26612677. E5a, E5a, E5a, E5a.26612677
164 14995 ∼ Harrison C, Drury P, Cassell O Sentinel lymph node biopsy for thin melanomas under the American Joint Committee on Cancer 8th edition cancer staging system. Journal of Plastic, Reconstructive and Aesthetic Surgery. 2018;711:120–121. E6b, E9b, E6b, E6b.
165 Harrison C, Mikhail M, Potter M, Gore S, Cassell O Sentinel lymph node biopsy for external ear melanoma: A 17 year experience with long term survival data. Journal of Plastic, Reconstructive & Aesthetic Surgery: JPRAS. 2017;709:1301–1303. PMID: 28711605. E6c, E8b, E6c, E6c.28711605
166 Hashmi O, Waller J, Turrentine J Melanoma follow-up and mortality: A large-scale study of Medicare patients. Journal of the American Academy of Dermatology. 2018;793:AB190. E6b, E8a, E6b, E6b.
167 Hawkins M L, Rioth M J, Eguchi M M, Cockburn M Poor prognosis for thin ulcerated melanomas and implications for a more aggressive approach to treatment. Journal of the American Academy of Dermatology. 2019;806:1640–1649. PMID: 30654077. E1, E9b, E1, E1.30654077
168 Aj Hayes, Maynard L, Coombes G, Newton-Bishop J, Timmons M, Cook M, Theaker J, Bliss Jm, Thomas Jm Wide versus narrow excision margins for high-risk, primary cutaneous melanomas: long-term follow-up of survival in a randomised trial. The lancet. Oncology. 2016;172:184‐192. PMID: CN-01137469. E6b, E8b, E6b, E6b.
169 Heath M, Woody M, Leitenberger J, Latour E, Bar A Invasive Melanoma and Melanoma in Situ Treated With Modified Mohs Micrographic Surgery With En Face Permanent Sectioning: A 10-Year Retrospective Review. Dermatologic Surgery. 2020;468:1004–1013. PMID: 31714384. E6b, E8b, E6b, E6b.31714384
170 Heino P J, Mylläri P H, Jahkola T A, Sintonen H, Luoma M L, Räsänen P, Roine R P Long-term quality of life of melanoma survivors is comparable to that of the general population. Anticancer Research. 2019;395:2633–2640. E6c, E8b, E6b, E6c.
171 Helsing P, Robsahm T E, Vos L, Rizvi S M, Akslen L A, Veierod M B Cutaneous head and neck melanoma (CHNM): A population-based study of the prognostic impact of tumor location. Journal of the American Academy of Dermatology. 2016;755:975–982.e2. PMID: 27546291. E6c, E9b, E6c, E6c.27546291
172 Helvind N M, Holmich L R, Smith S, Glud M, Andersen K K, Dalton S O, Drzewiecki K T Incidence of In Situ and Invasive Melanoma in Denmark From 1985 Through 2012: A National Database Study of 24,059 Melanoma Cases. JAMA Dermatology. 2015;15110:1087–95. PMID: 26061591. E6b, E8b, E6b, E6b.26061591
173 Henton J, Callear J, Dearden A, Rannan-Eliya S Are cutaneous melanoma treatment guidelines keeping pace with rapidly evolving melanoma treatment options? A review of metastatic melanoma at a supra-regional service. European Journal of Cancer. 2017;72:S124–S125. E6c, E8b, E6c, E6c.
174 Herb J, Stitzenberg K B, Meyers M O Sentinel Node Biopsy in Non-Ulcerated T1b Melanoma: Analysis of Incidence and Cost Using a Population-Based Registry. Journal of the American College of Surgeons. 2020;2314:S279–S280. E6c, E8b, E6c, E6c.
175 Hernandez R S, Lino-Silva L S, Najar C Z, García-Pérez L Exhaustive pathologic work-up in sentinel lymph node biopsy for melanoma: Is it necessary?. Annals of Surgical Oncology. 2017;241:S149. E6c, E8b, E6c, E6c.
176 Hieken T J, Glasgow A E, Enninga E A L, Kottschade L A, Dronca R S, Markovic S N, Block M S, Habermann E B Sex-Based Differences in Melanoma Survival in a Contemporary Patient Cohort. Journal of Women's Health. 2020;299:1160–1167. PMID: 32105561. E6c, E8b, E6c, E6c.32105561
177 12109 ∼ Hopkins Z H, Carlisle R P, Curtis J A, Secrest A M 187 Characterizing amelanotic melanoma and factors associated with survival. Journal of Investigative Dermatology. 2019;1395:S32. E1, E3, E1, E1.
178 Houston N A, Secrest A M, Harris R J, Mori W S, Eliason M J, Phillips C M, Ferris L K Patient Preferences During Skin Cancer Screening Examination. JAMA Dermatology. 2016;1529:1052–4. PMID: 27166873. E6c, E8b, E6c, E6c.27166873
179 Huang K, Xu Y, Gabriel E M, Misra S, Chen Y, Bagaria S P Comparative Analysis of Acral Melanoma in Chinese and Caucasian Patients. Journal of Skin Cancer. 2020;2020:. E1, E9b, E1, E1.
180 Huayllani M T, Sisti A, Restrepo D J, Boczar D, Cochuyt J J, Spaulding A C, Bagaria S P, Rinker B D, Forte A J Desmoplastic Melanoma: Clinical Characteristics and Survival in the US Population. Cureus. 2019;116:e4931. PMID: 31431837. E1, E9b, E1, E1.31431837
181 Hubner J, Eisemann N, Brunssen A, Katalinic A Skin cancer screening in Germany: review after ten years. Bundesgesundheitsblatt, gesundheitsforschung, gesundheitsschutz. 2018;6112:1536–1543. PMID: CN-01667431. E2, E2, E2, E2.
182 Hubner J, Waldmann A, Eisemann N, Noftz M, Geller A C, Weinstock M A, Volkmer B, Greinert R, Breitbart E W, Katalinic A Association between risk factors and detection of cutaneous melanoma in the setting of a population-based skin cancer screening. European Journal of Cancer Prevention. 2018;276:563–569. PMID: 28692584. E8b, E6c, E8b, E8b.28692584
183 Hubner J, Waldmann A, Geller A C, Weinstock M A, Eisemann N, Noftz M, Bertram S, Nolte S, Volkmer B, Greinert R, Breitbart E, Katalinic A Interval cancers after skin cancer screening: incidence, tumour characteristics and risk factors for cutaneous melanoma. British Journal of Cancer. 2017;1162:253–259. PMID: 27898656. E8b, E6c, E9a, E8b.27898656
184 Hunger R E, Angermeier S, Seyed Jafari S M, Ochsenbein A, Shafighi M A retrospective study of 1- versus 2-cm excision margins for cutaneous malignant melanomas thicker than 2 mm. Journal of the American Academy of Dermatology. 2015;726:1054–9. PMID: 25877659. E6c, E8a, E6c, E6c.25877659
185 Huyser M, Chang A L, Yang K, Chang C Melanoma incidence among ethnic minority populations. Annals of Surgical Oncology. 2018;251:S174. E6c, E8b, E6c, E6c.
186 Ingkaninanda P, Visessiri Y, Rutnin S Clinicopathological Features and Prognostic Factors of Malignant Melanoma: A Retrospective Analysis of Thai Patients in Ramathibodi Hospital. Journal of the Medical Association of Thailand. 2015;988:820–7. PMID: 26437541. E5b, E5b, E5b, E5b.26437541
187 Isaacs K E, Pasquali S, Thompson J F Outcomes following observation of melanoma patients with a positive sentinel lymph node biopsy: A large, single institution experience. Annals of Surgical Oncology. 2018;251:S66. E6b, E8b, E6b, E6b.
188 Isaksson K, Katsarelias D, Mikiver R, Carneiro A, Ny L, Olofsson Bagge R A Population-Based Comparison of the AJCC 7th and AJCC 8th Editions for Patients Diagnosed with Stage III Cutaneous Malignant Melanoma in Sweden. Annals of Surgical Oncology. 2019;269:2839–2845. PMID: 31111349. E1, E9b, E1, E1.31111349
189 Islami F, Ward E M, Sung H, Cronin K A, Tangka F K L, Sherman R L, Zhao J, Anderson R N, Henley S J, Yabroff K R, Jemal A, Benard V B Annual Report to the Nation on the Status of Cancer, Part 1: National Cancer Statistics. Journal of the National Cancer Institute. 2021;:. E3, E8b, E3, E3.
190 19658 ∼ Ismail N, Wynne B, Barry R, Ormond P The benefit of full-skin examination by dermatologists as a part of strategy to diagnose melanoma early. British Journal of Dermatology. 2015;173:109. E5a, E5a, E5a, E5a.
191 Ito T, Wada M, Nagae K, Nakano-Nakamura M, Nakahara T, Hagihara A, Furue M, Uchi H Acral lentiginous melanoma: who benefits from sentinel lymph node biopsy?. Journal of the American Academy of Dermatology. 2015;721:71–7. PMID: 25455840. E6c, E8b, E6c, E6c.25455840
192 Ivars M, Moreno-Artero E, Idoate M A, Redondo P Pseudoaneurysms as a possible complication of facial dermatologic surgery. Journal der Deutschen Dermatologischen Gesellschaft. 2018;168:1036–1038. PMID: 30058776. E3, E3, E3, E3.30058776
193 Jain S, Li Y, Kuan E C, Tajudeen B A, Batra P S Prognostic Factors in Paranasal Sinus Squamous Cell Carcinoma and Adenocarcinoma: A SEER Database Analysis. Journal of Neurological Surgery Part B Skull Base. 2019;803:258–263. PMID: 31143568. E1, E1, E1, E1.31143568
194 Jakub J W, Terando A M, Sarnaik A, Ariyan C E, Faries M B, Neuman H, Wasif N, Zani S Jr, Wayne J D, Farma J M, Averbook B J, Grotz T E, Allred J B, Suman V J, Tyler D, Brady M S, Bilimoria K Y, Nelson H Safety and feasibility of minimally invasive inguinal lymph node dissection in patients with melanoma (SAFE-MILND). Annals of Surgical Oncology. 2015;221:S22. E6c, E8b, E6c, E6c.
195 Janda M, Finnane A, Soyer H P Redefining Dermatologists' Role in Skin Cancer Early Detection and Follow-up Care. JAMA Dermatology. 2015;1515:483–4. PMID: 25629217. E3, E3, E3, E3.25629217
196 Jaukovic L, Rajović M, Radulovic M, Kandolf-Sekulovic L Lymphoscintigraphy and sentinel lymph node biopsy in cutaneous melanoma: Analysis of 201 patients from a single institution. European Journal of Nuclear Medicine and Molecular Imaging. 2015;421:S155–S156. E6c, E8b, E6c, E6c.
197 Jayasekera P, Dodds J, Kai A, Oliphant T, Langtry J, Lawrence C Preoperative blood pressure does not predict bleeding risk in Mohs surgery patients. British Journal of Dermatology. 2017;177:112–113. E6c, E8b, E6c, E6c.
198 Jayasekera P, Dodds J, Oliphant T, Langtry J, Lawrence C Dermoscopic examination of basal cell carcinoma margins before Mohs surgery does not reduce the number of Mohs stages. British journal of dermatology. 2017;177:107-. PMID: CN-01745984. E8b, E8b, E8b, E8b.28117875
199 Psa Jayasekera, Dodd J, Oliphant T, Langtry Jaa, Lawrence Cm Dermoscopy prior to Mohs micrographic surgery does not improve tumour margin assessment and leads to fewer Mohs stages. British journal of dermatology. 2018;1782:565–566. PMID: CN-01461162. E8b, E8b, E8b, E8b.
200 Jokic S, Markovic I, Bukumiric Z, Jokic V, Rakovic M, Tripkovic J, Stojiljkovic D, Spurnic I, Jevric M, Matic M, Dobrosavljevic D Predictors of sentinel lymph node status of cutaneous melanoma in Serbian patients. Journal of B.U.ON.. 2018;232:468–474. E1, E9b, E1, E1.
201 Jorgensen K J Melanoma Screening. Dermatology. 2017;2335:410–411. PMID: 29241216. E3, E3, E3, E3.29241216
202 Joyce K M, McInerney N M, Piggott R P, Martin F, Jones D M, Hussey A J, Kerin M J, Kelly J L, Regan P J Analysis of sentinel node positivity in primary cutaneous melanoma: an 8-year single institution experience. Irish Journal of Medical Science. 2017;1864:847–853. PMID: 28132159. E6c, E8b, E6c, E6c.28132159
203 7926 ∼ Kai Y, Ishikawa K, Goto M, Sakai T, Ito A, Shono T, Shimada H, Shimizu F, Goto M, Hatano Y, Okamoto O, Katagiri K, Aono H, Eshima N, Fujiwara S Results of second-stage screening for skin cancers in Oita Prefecture, Japan. Journal of Dermatology. 2015;4212:1160–4. PMID: 26177589. E8b, E6c, E9a, E8b.26177589
204 Kanaki T, Stang A, Gutzmer R, Zimmer L, Chorti E, Sucker A, Ugurel S, Hadaschik E, Grager N S, Satzger I, Schadendorf D, Livingstone E Impact of American Joint Committee on Cancer 8th edition classification on staging and survival of patients with melanoma. European Journal of Cancer. 2019;119:18–29. PMID: 31401470. E1, E8b, E1, E1.31401470
205 Kapasi F, Vallejo C, Ameerally P Postoperative aesthetic outcomes in non-melanoma skin cancer of the head and neck: A comparison of patient and clinician perspectives. Journal of the European Academy of Dermatology and Venereology. 2017;31:84. E6c, E8b, E6c, E6c.
206 Karakousis G C, Gimotty P A, Leong S P, Pockaj B A, White R L, O'Donoghue C, Sinnamon A J, Bartlett E K, Dueck A C, Gould Rothberg B E, Messina J L, Vetto J T, Sondak V K, Schneebaum S, Kashani-Sabet M, Han D, Faries M B, Zag Microsatellitosis in Patients with Melanoma. Annals of Surgical Oncology. 2019;261:33–41. PMID: 30421045. E1, E9b, E1, E1.30421045
207 Karanfilian K M, Behbahani S, Alhatem A, Karanfilian T, Lambert W C 15639 Balloon cell melanoma: A National Cancer Institute database analysis of patient characteristics and survival. Journal of the American Academy of Dermatology. 2020;836:AB44. E1, E1, E1, E1.
208 Karia P S, Morgan F C, Califano J A, Schmults C D Comparison of Tumor Classifications for Cutaneous Squamous Cell Carcinoma of the Head and Neck in the 7th vs 8th Edition of the AJCC Cancer Staging Manual. JAMA Dermatology. 2018;1542:175–181. PMID: 29261835. E1, E9b, E1, E1.29261835
209 Keith D, De Berker D, Bray A, Brain A, Mohd-Mustapa M F British Association of Dermatologists national audit on nonmelanoma skin cancer excision 2016. British Journal of Dermatology. 2017;177:104. E6c, E8b, E6c, E6c.
210 Kelly K M, Dhumal T, Scott V G, Mbous Y P V, Chotiner M, Powers R, Whetsel T, Safarudin F, Cornelius P, Garofoli G SCAN! A pharmacy-based, sun safety feasibility study. Journal of the American Pharmacists Association. 2020;:. E7b, E6c, E7b, E7b.
211 Kerivan L, Reintgen M, Reintgen E, Swaminathan S, Reintgen D S Conditional survival of melanoma in the sentinel lymph node era: Meaningful prognostic information for patients and physicians. Annals of Surgical Oncology. 2017;241:S132. E1, E3, E1, E1.
212 Khan K, Mykula R, Kerstein R, Rabey N, Bragg T, Crick A, Heppell S, Budny P, Potter M A 5-year follow-up study of 633 cutaneous SCC excisions: Rates of local recurrence and lymph node metastasis. Journal of Plastic, Reconstructive & Aesthetic Surgery: JPRAS. 2018;718:1153–1158. PMID: 29803777. E6b, E8b, E6b, E6b.29803777
213 Kim B, Sgarioto M, Hewitt D, Paver R, Norman J, Fernandez-Penas P Scar outcomes in dermatological surgery. Australasian Journal of Dermatology. 2018;591:48–51. PMID: 28244587. E1, E1, E1, E8b.28244587
214 Kim C C, Najita J S, Tan S Y M, Varada S, Tong L X, Dunbar H, Lee M Y, Seery V J, Buchbinder E I, Tawa N E, Fuller J, Frankenthaler R A, McDermott D F, Lee S J, Atkins M B Factors associated with worse outcome for patients with AJCC stage IIC relative to stage IIIA melanoma. Journal of Clinical Oncology. 2015;3315:. E1, E3, E1, E1.
215 Kim C, Economou S, Amatruda T T, Martin J C, Dudek A Z Prognostic significance of microscopic tumor burden in sentinel lymph node in patients with cutaneous melanoma. Anticancer Research. 2015;351:301–9. PMID: 25550564. E6c, E8b, E6c, E6c.25550564
216 9049 ∼ Kim D, Chu S, Khan A, Compres E, Gerami P, David Wayne J Risk Factors and Patterns of Recurrence after Sentinel Lymph Node Biopsy for Thin Melanoma. Journal of the American College of Surgeons. 2020;2314:e212. E6c, E8b, E6c, E6c.
217 Kinnier C V, Paruch J L, Dahlke A R, Wayne J D, Benson A B 3rd, Winchester D P, Bilimoria K Y Adjusted Hospital Sentinel Lymph Node Positivity Rates in Melanoma: A Novel Potential Measure of Quality. Annals of Surgery. 2016;2632:392–8. PMID: 26488806. E6b, E8b, E6b, E6b.26488806
218 Dd Kirchoff, Gb Deutsch, Sl Stern, Lavotshkin S Lee Dj, Lj Foshag, Faries Mb Impact of obesity in melanoma outcomes: analysis of data from a multinational randomized controlled sentinel lymph node trial. Cancer research. 2015;7515:. PMID: CN-01139572. E1, E8b, E1, E1.
219 Kjerkegaard U, Eldon M, Sjøgren P, Stolle L B A single-center retrospective study on 659 re-excisions of melanoma and 769 sentinel node biopsies in 2008–2012. European Journal of Plastic Surgery. 2015;386:471–478. E1, E9b, E1, E1.
220 Kjome R L S, Wright D J, Bjaaen A B, Garstad K W, Valeur M Dermatological cancer screening: Evaluation of a new community pharmacy service. Research In Social & Administrative Pharmacy. 2017;136:1214–1217. PMID: 27964893. E6b, E6c, E8b, E8b.27964893
221 Ko D, Lipner S R Comment on: "The first 30 years of the American Academy of Dermatology skin cancer screening program: 1985–2014". Journal of the American Academy of Dermatology. 2019;801:e23. PMID: 30244068. E3, E3, E3, E3.30244068
222 Koskivuo I, Vihinen P, Maki M, Talve L, Vahlberg T, Suominen E Improved Survival in Male Melanoma Patients in the Era of Sentinel Node Biopsy. Scandinavian Journal of Surgery: SJS. 2017;1061:80–86. PMID: 26929285. E6c, E8b, E6c, E6c.26929285
223 Kraywinkel K, Dahm S Impact of skin cancer screening on the incidence of skin melanoma in Germany-a trend analysis by tumor stage and histological subtype. Oncology Research and Treatment. 2016;39:40. E8b, E6c, E9a, E8b.
224 Kuiper E M, van den Berge B A, Spoo J R, Kuiper J, Terra J B Low recurrence rate of head and neck basal cell carcinoma treated with Mohs micrographic surgery: A retrospective study of 1021 cases. Clinical Otolaryngology. 2018;435:1321–1327. PMID: 29953746. E1, E9b, E1, E1.29953746
225 Kurn H A, Sivesind T E, Dellavalle R P From the Cochrane Library: Screening for reducing morbidity and mortality in malignant melanoma. Journal of the American Academy of Dermatology. 2021;26:26. E3, E3, E3, E3.
226 Kyrgidis A, Tzellos T, Mocellin S, Apalla Z, Lallas A, Pilati P, Stratigos A Sentinel lymph node biopsy followed by lymph node dissection for localised primary cutaneous melanoma. Cochrane Database of Systematic Reviews. 2015;5:CD010307. PMID: 25978975. E9b, E8b, E8b, E8b.25978975
227 Lam P H, Obirieze A C, Ortega G, Li B S, Purnell S D, Weeks C B, Ehanire I D, Oyetunji T A, Wilson L L An Age-Based Analysis of Pediatric Melanoma: Staging, Surgery, and Mortality in the Surveillance, Epidemiology, and End Results Database. American Surgeon. 2018;845:739–745. PMID: 29966577. E6c, E8b, E6c, E6c.29966577
228 Lam P H, Obirieze A C, Ortega G, Purnell S D, Li B S, Ehanire I D, Oyetunji T A, Wilson L L Pediatric melanoma: Staging, surgery and mortality in the surveillance, epidemiology and end results (SEER) database. Annals of Surgical Oncology. 2015;221:S124. E6c, E8b, E6c, E6c.
229 16946 ∼ Lamb C, Kairys J, Mastrangelo M, Dabbish N, Feeney K, Leiby B, Sato T, Berger A Survival and factors associated with false negative (FN) sentinel lymph node biopsy (SLNB) for melanoma. Annals of Surgical Oncology. 2017;241:S148. E6c, E8b, E6c, E6c.
230 Landow S M, Gjelsvik A, Weinstock M A Mortality burden and prognosis of thin melanomas overall and by subcategory of thickness, SEER registry data, 1992–2013. Journal of the American Academy of Dermatology. 2017;762:258–263. PMID: 27887797. E6b, E8b, E6b, E6b.27887797
231 Lee A H, Grose E, Li H, Brandts-Longtin O, Wang H, Boulva K, Johnson-Obaseki S, Nessim C Impact of Positive Biopsy Margins and Residual Disease in Wide Local Excision (WLE) on Melanoma Survival: Implications for Management. Journal of the American College of Surgeons. 2020;2314:e208. E6c, E8b, E6c, E6c.
232 Lee A Y, Friedman E, Sun J, Potdar A, Daou H, Farrow N E, Farley C, Vetto J, Han D, Tariq M, Shapiro R, Beasley G, Contreras C, Osman I, Lowe M, Zager J, Berman R Substage-specific survival in acral lentiginous melanoma. Annals of Surgical Oncology. 2019;26:S158. E1, E3, E1, E1.
233 Lee D Y, Huynh K T, Teng A, Lau B J, Vitug S, Lee J H, Stern S L, Foshag L J, Faries M B Predictors and Survival Impact of False-Negative Sentinel Nodes in Melanoma. Annals of Surgical Oncology. 2016;233:1012–8. PMID: 26586498. E1, E9b, E1, E1.26586498
234 Lee L Y W, Hill T, Topping O, Tilby M, Baker M, Greig J, Isherwood L, Miller R, Petrenko Y, Desai R, Field A, Kennedy B, Khan S, Kountourou A, Ndlovu S, Starkey T, Storey F, Turner L, Vaughan-Williams W, Moyler S, Preston H, Latty Utility of COVID-19 Screening in Cancer Patients. Cancer Cell. 2020;383:306–307. E1, E1, E1, E1.
235 Lee Mitsis D K, Groman A, Beaupin L M, Salerno K E, Francescutti V, Skitzki J J, Kane J M, Khushalani N I Trends in demographics, incidence, and survival in children, adolescents and young adults (AYA) with melanoma: A Surveillance, Epidemiology and End Results (SEER) population-based analysis. Journal of Clinical Oncology. 2015;3315:. E6c, E8b, E6c, E6c.
236 Leeneman B, Blommestein H, de Groot S, Holleman M S, Kuppen M, Luyendijk M, Westgeest H M, Uyl - de Groot C A, Franken M REPORTING FOLLOW-UP IN SURVIVAL ANALYSES: INFORMATIVE OR NOT?. Value in Health. 2018;21:S358–S359. E1, E3, E1, E1.
237 Leeneman B, Franken M G, Coupé V M H, Hendriks M P, Kruit W, Plaisier P W, van Ruth S, Verstijnen J A M C, Wouters M W J M, Blommestein H M, Uyl – de Groot C A Stage-specific disease recurrence and survival in localized and regionally advanced cutaneous melanoma. European Journal of Surgical Oncology. 2019;455:825–831. E1, E8b, E1, E1.
238 Leitch C S, Sinclair C G, Aguilar-Duran S, Panthagani A P, Ray R, Kavanagh G M Comment on: “Risk of subsequent melanoma after melanoma in situ and invasive melanoma: A population-based study from 1973 to 2011”. Journal of the American Academy of Dermatology. 2016;754:e163–e164. E3, E3, E3, E3.
239 Leiter U, Buettner P G, Eigentler T K, Garbe C Prognostic factors of thin cutaneous melanoma: an analysis of the central malignant melanoma registry of the german dermatological society. J Clin Oncol. 2004;2218:3660–7. PMID: 15302905. E6b, E8b, E6b, E6b.15302905
240 Leow M Q, Cao T Dermatologic Screening in an Elderly Community with Low Socioeconomic Status in Singapore. Annals of the Academy of Medicine, Singapore. 2016;455:219–20. PMID: 27383723. E6b, E8b, E6b, E6b.27383723
241 Lewis D J, Shin D, Ming M E 425 Characteristics associated with physician-identified melanomas vs personally-identified melanomas. Journal of Investigative Dermatology. 2020;1407:S56. E8b, E8b, E8b, E8b.
242 Li A B, Jiang B J, Wang H H, Yang Y S, Zhang X B, Lan G H, Shu W B Prognostic factors for survival in patients with clear cell sarcoma: An analysis of the Surveillance, Epidemiology, and End Results (SEER) database. Medical Science Monitor. 2019;25:6939–6945. E1, E1, E1, E1.
243 9055 ∼ Li H, Brandts-Longtin O, Grose E, Lee A, Boulva K, Johnson-Obaseki S, Nessim C The Association Between Socio-Economic Status and Survival Outcomes for Melanoma in Canada. Journal of the American College of Surgeons. 2020;2314:S282–S283. E6c, E8b, E6c, E6c.
244 Lideikaite A, Mozuraitiene J, Letautiene S Analysis of prognostic factors for melanoma patients. Acta Medica Lituanica. 2017;241:25–34. PMID: 28630590. E1, E9b, E1, E1.28630590
245 Lin M J, Cicchiello M, Kelly J W Comparison of pathways to diagnosis of nodular melanoma and superficial spreading melanoma. British Journal of Dermatology. 2015;173:60–61. E6c, E8b, E6c, E6c.
246 Lindqvist E K, Laine E, Kamali A, Sars C, Gillgren P, Schultz I Risk factors for post-operative complications after sentinel lymph node biopsy for cutaneous melanoma: Results from a large cohort study. Journal of Plastic, Reconstructive & Aesthetic Surgery: JPRAS. 2019;7212:1956–1962. PMID: 31607594. E1, E1, E1, E6b.31607594
247 Lino-Silva L S, Zepeda-Najar C, Salcedo-Hernandez R A, Martinez-Said H Acral Lentiginous Melanoma: Survival Analysis of 715 Cases. Journal of Cutaneous Medicine & Surgery. 2019;231:38–43. PMID: 30221995. E1, E5b, E1, E1.30221995
248 Liu J, Ebrahimi A, Low T H H, Gao K, Palme C E, Sydney C, Ashford B G, Iyer N G, Clark J R, Gupta R Predictive value of the 8th edition American Joint Commission Cancer (AJCC) nodal staging system for patients with cutaneous squamous cell carcinoma of the head and neck. Journal of Surgical Oncology. 2018;1174:765–772. E1, E9b, E1, E1.
249 Liu R, Ferris L K, Pugliano-Mauro M, Patton T, Wang L, Siripong N 13155 Reevaluating the ABCD criteria using a consecutive series of melanomas. Journal of the American Academy of Dermatology. 2020;836:AB6. E6c, E8b, E6c, E6c.
250 Lo S N, Scolyer R A, Thompson J F Long-Term Survival of Patients with Thin (T1) Cutaneous Melanomas: A Breslow Thickness Cut Point of 0.8 mm Separates Higher-Risk and Lower-Risk Tumors. Annals of Surgical Oncology. 2018;254:894–902. PMID: 29330716. E1, E8b, E1, E1.29330716
251 Lo S, Scolyer R, Thompson J Long-term survival outcome of patients with thin (T1) cutaneous melanomas: A naturally-occurring, biologically-relevant Breslow thickness cutpoint of 0.8 mm separates higher risk from lower risk tumors. Pigment Cell and Melanoma Research. 2018;311:181. E1, E3, E1, E1.
252 Loh T, Hau J, Jiang S B Removal of incidental skin cancer during Mohs micrographic surgery indicated for a different primary tumor. Journal of the American Academy of Dermatology. 2018;793:AB244. E5a, E8b, E5a, E5a.
253 Look Hong N J, Cheng S, Baxter N, Wright F Treatment matters: Examining the relationship between treatment adequacy and survival in Melanoma. Annals of Surgical Oncology. 2019;26:S39. E6c, E8b, E6c, E6c.
254 Lorimer P D, Hill J S, Carpenter K W, Salo J C, Han Y, Forster M R, Sarantou T, White Jr R L Pediatric melanoma: An age-based analysis of the National Cancer Database. Annals of Surgical Oncology. 2015;221:S117. E6a, E8b, E6a, E6a.
255 Losty P, Poirier V, Verne J Malignant melanoma in children and adolescents-a nationwide outcome report. Pediatric Blood and Cancer. 2015;62:S187. E6c, E8b, E6c, E6c.
256 5988 ∼ Luen S, Wong S W, Mar V, Kelly J W, McLean C, McArthur G A, Haydon A Primary Tumor Thickness is a Prognostic Factor in Stage IV Melanoma: A Retrospective Study of Primary Tumor Characteristics. American Journal of Clinical Oncology. 2018;411:90–94. PMID: 26325493. E1, E9b, E1, E1.26325493
257 Luk P P, Ebrahimi A, Veness M J, McDowell L, Magarey M, Gao K, Palme C E, Clark J R, Gupta R Prognostic value of the 8th edition American Joint Commission Cancer nodal staging system for patients with head and neck cutaneous squamous cell carcinoma: A multi-institutional study. Head and Neck. 2020;:. E1, E9b, E1, E1.
258 Luke C G, Coventry B J, Foster-Smith E J, Roder D M A critical analysis of reasons for improved survival from invasive cutaneous melanoma. Cancer Causes Control. 2003;149:871–8. PMID: 14682444. E6b, E8b, E6b, E6b.14682444
259 Luo S, Lobo A Z, Tanabe K K, Muzikansky A, Durazzo T, Sober A, Tsao H, Cosimi A B, Lawrence D P, Duncan L M Clinical significance of microscopic melanoma metastases in the nonhottest sentinel lymph nodes. JAMA Surgery. 2015;1505:465–72. PMID: 25831227. E6b, E8b, E6b, E6b.25831227
260 Lynch M, Tierney E, Roche L, Quigley J, Farsi M, Ramsay B, Hackett C, Ahmad K The effect of a pigmented lesion clinic in the Mid-West of Ireland on melanoma diagnosis and management. British Journal of Dermatology. 2016;175:130–131. E8b, E8b, E9a, E8b.
261 Lynch M, Tierney E, Roche L, Quigley J, Farsi M, Ramsay B, Hackett C, Ahmad K Melanoma diagnosis and management after the introduction of a pigmented lesion clinic in the Mid-West of Ireland. Irish Journal of Medical Science. 2017;1863:671–675. E8b, E8b, E9b, E8b.
262 Lyth J, Eriksson H, Hansson J, Ingvar C, Jansson M, Lapins J, Naredi P, Stierner U, Ullenhag G, Carstensen J, Lindholm C Trends in cutaneous malignant melanoma in Sweden 1997–2011: Thinner tumours and improved survival among men. British Journal of Dermatology. 2015;1723:700–706. E6c, E8b, E6c, E6c.
263 Lyth J, Falk M, Maroti M, Eriksson H, Ingvar C Prognostic risk factors of first recurrence in patients with primary stages I–II cutaneous malignant melanoma – from the population-based Swedish melanoma register. Journal of the European Academy of Dermatology and Venereology. 2017;319:1468–1474. E1, E9b, E1, E1.
264 Lyth J, Mikiver R, Nielsen K, Isaksson K, Ingvar C Prognostic instrument for survival outcome in melanoma patients: based on data from the population-based Swedish Melanoma Register. European Journal of Cancer. 2016;59:171–178. PMID: 27046697. E1, E8b, E1, E1.27046697
265 Ma Q, Suo H, Zhu L, Qian Y, Sun X, Xie J, Li Q, Fu Y, Li J, Tao J Prognostic significance of tumor size for primary invasive cutaneous melanoma: A population-based study, 2004–2016. Cancer Medicine. 2020;913:4561–4571. E1, E9b, E1, E1.
266 MacNeil S D, Patel K, Liu K, Shariff S, Yoo J, Nichols A, Fung K, Garg A X Survival of patients with subglottic squamous cell carcinoma. Current Oncology. 2018;256:e569–e575. PMID: 30607125. E1, E1, E1, E1.30607125
267 Madeja J, Kelsberg G, Safranek S Does screening by primary care providers effectively detect melanoma and other skin cancers?. Journal of Family Practice. 2020;692:E10–E12. PMID: 32182298. E3, E3, E3, E3.32182298
268 Madu M F, Franke V, Van de Wiel B A, Klop W M C, Jozwiak K, van Houdt W J, Wouters Mwjm, van Akkooi A C J External validation of the American Joint Committee on Cancer 8th edition melanoma staging system: who needs adjuvant treatment?. Melanoma Research. 2020;302:185–192. PMID: 31651715. E1, E9b, E1, E1.31651715
269 Madu M F, Franke V, Van De Wiel B, Klop W M C, Józwiak K, Wouters M W J M, Van Akkooi A C J External validation of the 8th Edition Melanoma Staging System of the American Joint Committee on Cancer (AJCC): Effect of adding EORTC sentinel node (SN) tumor burden criteria on prognostic accuracy in stage III. Journal of Clinical Oncology. 2018;3615:. E6b, E8b, E6b, E6b.
270 10954 ∼ Malik A, Alassadi Z, Srinivasan B, Brennan P, Anand R ‘Donť worry, iťs only a local’ - Morbidity and Mortality in Elderly Patients Undergoing Local Anaesthetic Management of Facial Skin Cancers. British Journal of Oral and Maxillofacial Surgery. 2019;5710:e81. E6c, E8b, E6c, E6c.
271 Marashi-Pour S, Morrell S, Cooke-Yarborough C, Arcorace M, Baker D Competing risk analysis of mortality from invasive cutaneous melanoma in New South Wales: a population-based study, 1988–2007. Aust N Z J Public Health. 2012;365:441–5. PMID: 23025365. E6c, E9b, E6c, E6c.23025365
272 Marcadis A R, Marti J L, Ehdaie B, Hakimi A A, Davies L, Morris L G T Characterizing Relative and Disease-Specific Survival in Early-Stage Cancers. JAMA Internal Medicine. 2020;1803:461–463. E6c, E6c, E6c, E6c.
273 Marchetti M A, Chung E, Halpern A C Screening for Acral Lentiginous Melanoma in Dark-Skinned Individuals. JAMA Dermatology. 2015;15110:1055–6. PMID: 26083954. E3, E3, E3, E3.26083954
274 Marchetti M A, Yu A, Nanda J, Tschandl P, Kittler H, Marghoob A A, Halpern A C, Dusza S W Number needed to biopsy ratio and diagnostic accuracy for melanoma detection. Journal of the American Academy of Dermatology. 2020;833:780–787. E9b, E9b, E9b, E9b.
275 Aj Marek, Ey Chu, Me Ming, Za Khan, Kovarik Cl Piloting the Use of Smartphones, Reminders, and Accountability Partners to Promote Skin Self-Examinations in Patients with Total Body Photography: a Randomized Controlled Trial. American journal of clinical dermatology. 2018;195:779‐785. PMID: CN-01644759. E7b, E1, E7b, E8b.
276 Matthews N H, Risica P M, Dionne L, Mello J, Ferris L K, Saul M, Geller A, Solano F, Kirkwood J M, Weinstock M A Potential adverse psychosocial impacts of skin biopsies in the context of melanoma screening. Journal of Investigative Dermatology. 2017;1375:S27. E3, E3, E3, E3.
277 May M M, Lohse C M, Moore E J, Price D L, Van Abel K M, Brewer J D, Janus J R Wide local excision prior to sentinel lymph node biopsy for primary melanoma of the head and neck. International Journal of Dermatology. 2019;5810:1184–1190. PMID: 30968948. E6c, E8b, E6c, E8b.30968948
278 McDermott J D, Eguchi M, Morgan R, Amini A, Goddard J A, Borrayo E A, Karam S D Elderly Black Non-Hispanic Patients With Head and Neck Squamous Cell Cancer Have the Worst Survival Outcomes. Journal of the National Comprehensive Cancer Network. 2020;:1–11. PMID: 32987364. E6c, E6c, E6c, E6c.32987364
279 McFarland S L, Schram S E Physician skin examinations for melanoma screening. Cutis. 2015;963:175–82. PMID: 26562268. E1, E1, E1, E1.26562268
280 Mejbel H, Mori T, Torres-Cabala C, Milton D, Muto Y, Nakama K, Yamazaki N, Nagarajan P, Tetzlaff M, Ivan D, Curry J, Hwu W J, Prieto V, Namikawa K, Aung P Comparative study of acral lentiginous melanoma in patients from usa and japan. Modern Pathology. 2020;333:481–483. E6c, E8b, E6c, E6c.
281 Merrill R M, Bateman S Conditional Melanoma Cancer Survival in the United States. Cancers. 2016;82:02. PMID: 26848688. E6c, E8b, E6c, E6c.26848688
282 Mesquita A, Reis R, Senra F, Carvalho Martins P, Peyroteu M, Ribeiro C, Sousa A, Ferreira A, Ribeiro M, Abreu De Sousa J Melanoma: Prognostic factors in 5 years of follow up. European Journal of Surgical Oncology. 2016;429:S172–S173. E6c, E8b, E6c, E6c.
283 Miller K A, Wojcik K Y, Cockburn M G, In G K, Hamilton A S, Milam J E Prevalence and correlates of adherence to skin examination among adolescent and young adult survivors of melanoma from the Project Forward Study. Pediatric Blood and Cancer. 2020;673:. E6b, E8b, E6b, E6b.
284 5926 ∼ Miller M Q, David A P, McLean J E, Park S S, Christophel J Association of Mohs Reconstructive Surgery Timing With Postoperative Complications. JAMA Facial Plastic Surgery. 2018;202:122–127. PMID: 28880987. E6b, E8b, E6b, E6b.28880987
285 Miller R, Walker S, Shui I, Brandtmüller A, Cadwell K, Scherrer E Epidemiology and survival outcomes in stages II and III cutaneous melanoma: A systematic review. Melanoma Management. 2020;71:39–51. E1, E3, E1, E1.
286 Minicozzi P, Walsh P M, Sánchez M J, Trama A, Innos K, Marcos-Gragera R, Dimitrova N, Botta L, Johannesen T B, Rossi S, Sant M Is low survival for cancer in Eastern Europe due principally to late stage at diagnosis?. European Journal of Cancer. 2018;93:127–137. E1, E8b, E1, E1.29518726
287 Mirza F N, Tuggle C T, Zogg C K, Mirza H N, Narayan D Epidemiology of cutaneous adenosquamous carcinoma: A United States population-based cohort analysis using the Surveillance, Epidemiology, and End Results Database. Journal of the American Academy of Dermatology. 2019;814:AB57. E6c, E9b, E6c, E6c.
288 Mo R, Chen C, Jiang Y, Ma Z, Meng X, Tan Q Sex-specific survival benefit in early skin melanoma based on 8th AJCC edition: an analysis of data from the Surveillance, Epidemiology, and End Results (SEER) database. Annals of Translational Medicine. 2021;91:53. E6b, E8b, E6b, E6c.
289 Mo R, Chen C, Mi L, Ma Z, Tan Q Skin melanoma survival is not superior in females in the new stage IIID of the 8th edition of the staging system: an analysis of data from the Surveillance, Epidemiology, and End Results (SEER) database. Annals of Translational Medicine. 2020;821:. E1, E9b, E1, E1.32793666
290 Moncrieff M D O Ľeary F M, Beadsmoore C J, Pawaroo D, Heaton M J, Isaksson K, Olofsson Bagge R Effect of delay between nuclear medicine scanning and sentinel node biopsy on outcome in patients with cutaneous melanoma. British Journal of Surgery. 2020;1076:669–676. PMID: 32077090. E6c, E8b, E6c, E6c.32077090
291 Moody J A, Ali R F, Carbone A C, Singh S, Hardwicke J T Complications of sentinel lymph node biopsy for melanoma - A systematic review of the literature. European Journal of Surgical Oncology. 2017;432:270–277. PMID: 27423448. E6c, E8b, E6c, E6c.27423448
292 Fc Morgan, Es Ruiz, Ps Karia, Rj Besaw, Va Neel, Schmults Cd Factors predictive of recurrence, metastasis, and death from primary basal cell carcinoma 2 cm or larger in diameter. Journal of the American Academy of Dermatology. 2020;833:832–838. PMID: CN-02142274. E6c, E6c, E6b, E6c.
293 Morgese F, Sampaolesi C, Torniai M, Conti A, Ranallo N, Giacchetti A, Serresi S, Onofri A, Burattini M, Ricotti G, Berardi R Gender Differences and Outcomes in Melanoma Patients. Oncology and Therapy. 2020;81:103–114. E6c, E8b, E6c, E6c.
294 Moye M S, King S M, Rice Z P, DeLong L K, Seidler A M, Veledar E, Curiel-Lewandrowski C, Chen S C Effects of total-body digital photography on cancer worry in patients with atypical mole syndrome. JAMA Dermatol. 2015;1512:137–43. PMID: 25389923. E5a, E6b, E5a, E5a.25389923
295 Murchie P, Amalraj Raja E, Brewster D H, Iversen L, Lee A J Is initial excision of cutaneous melanoma by General Practitioners (GPs) dangerous? Comparing patient outcomes following excision of melanoma by GPs or in hospital using national datasets and meta-analysis. European Journal of Cancer. 2017;86:373–384. PMID: 29100192. E1, E9b, E1, E1.29100192
296 Murray D, Topfer J, Decilveo A P, Wittig J C Benefits Associated With Early Diagnosis and Treatment of Soft Tissue Sarcomas of the Foot and Ankle. Journal of Foot and Ankle Surgery. 2016;555:980–984. E6c, E6c, E6c, E6c.
297 5712 ∼ Murtha T D, Han G, Han D Predictors for Use of Sentinel Node Biopsy and the Association with Improved Survival in Melanoma Patients Who Have Nodal Staging. Annals of Surgical Oncology. 2018;254:903–911. PMID: 29368153. E6b, E8b, E6b, E6b.29368153
298 Mylle S, Verhaeghe E, Van Coile L, Van de Maele B, Hoorens I, Brochez L Lesion-directed screening to optimize skin cancer detection in dermatology practice: an observational study. Journal of the European Academy of Dermatology & Venereology. 2021;356:1309–1314. E5a, E6c, E5a, E5a.
299 Nahar V K, Mayer J E, Grant-Kels J M The Case for Skin Cancer Screening With Total-Body Skin Examinations. JAMA Oncology. 2016;28:999–1001. PMID: 27459540. E3, E2, E3, E3.27459540
300 Nam K W, Bae Y C, Bae S H, Song K H, Kim H S, Choi Y J Analysis of the clinical and histopathological patterns of 100 consecutive cases of primary cutaneous melanoma and correlation with staging. Archives of Plastic Surgery. 2015;426:746–752. E1, E9b, E1, E1.
301 Namikawa K, Aung P P, Milton D R, Tetzlaff M T, Torres-Cabala C A, Curry J L, Nagarajan P, Ivan D, Ross M, Gershenwald J E, Prieto V G Correlation of Tumor Burden in Sentinel Lymph Nodes with Tumor Burden in Nonsentinel Lymph Nodes and Survival in Cutaneous Melanoma. Clinical Cancer Research. 2019;2524:7585–7593. PMID: 31570567. E1, E9b, E1, E1.31570567
302 Namin A W, Zitsch R P Impact of Biopsy Modality on the Management of Cutaneous Melanoma of the Head and Neck. Otolaryngology - Head and Neck Surgery (United States). 2018;1583:473–478. E8b, E6b, E8b, E8b.
303 Neuwirth M, Bello D, Brady M S, Ariyan C E, Coit D G, Bartlett E K Disease presentation is highly prognostic in melanoma patients with occult nodal disease following sentinel lymph node biopsy. Annals of Surgical Oncology. 2020;27:S156. E6b, E8b, E6b, E6b.
304 Ngo P, Ko J, Sussman T A, Li H, Hobbs B, Gastman B, Funchain P Survival and recurrence patterns of stage II and III cutaneous melanoma by AJCC 8th edition staging. Pigment Cell and Melanoma Research. 2020;331:213. E1, E9b, E1, E1.
305 Nguyen B, Karia P S, Hills V M, Besaw R J, Schmults C D Impact of National Comprehensive Cancer Network Guidelines on Case Selection and Outcomes for Sentinel Lymph Node Biopsy in Thin Melanoma. Dermatologic Surgery. 2018;444:493–501. PMID: 29059142. E6c, E8b, E6c, E6c.29059142
306 Nijhuis A, De Santos D A O, Holtkamp L, Uren R, Thompson J, Nieweg O Sentinel node biopsy in melanoma patients with a local recurrence or in-transit metastasis. Annals of Surgical Oncology. 2019;26:S44. E6c, E6c, E6c, E6c.
307 Nikolic D V, Nikolic A T, Stanimirovic V V, Nikolic M D Melanoma campaign CAN/NOT improve revealing of THIN/THICK malignant melanomas. Pigment Cell and Melanoma Research. 2017;305:e107. E8b, E8b, E9a, E8b.
308 Nutalapati S, Chen Q, Huang B, Myint Z Survival disparities in top five cancers in the United States: A population based study. Journal of Clinical Oncology. 2021;3915 SUPPL:. E3, E3, E3, E3.
309 O'Bryan C J, Gao D X, Kentosh J B 26485 Effectiveness of free screenings in detecting skin cancers: A 4-year comparison to a dermatology clinic. Journal of the American Academy of Dermatology. 2021;853:AB19. E3, E3, E3, E3.
310 26937 ∼ O'Bryan C, Gao D X, Kentosh J B Impact of free skin screenings on number of biopsy-confirmed skin cancers and analysis of popular advertising methods: a 4-year retrospective study at a single dermatology practice. International Journal of Dermatology. 2021;17:17. E7a, E6c, E7a, E7a.
311 Oconnor C, Gallagher C, Oconnell M, Bourke J, Murphy M, Bennett M Bare necessities? The utility of full skin examination in the COVID-19 era. Clinical and experimental dermatology. 2021;464:720–722. PMID: CN-02265728. E5a, E6c, E5a, E5a.
312 Ogata D, Uhara H, Tsutsumida A, Yamazaki N, Mochida K, Amano M, Yoshikawa S, Kiyohara Y, Tsuchida T Nail apparatus melanoma in a Japanese population: a comparative study of surgical procedures and prognoses in a large series of 151 cases. European Journal of Dermatology. 2017;276:620–626. PMID: 29165298. E1, E9b, E1, E1.29165298
313 Olazagasti Lourido J M, Ma J E, Lohse C M, Brewer J D Increasing Incidence of Melanoma in the Elderly: An Epidemiological Study in Olmsted County, Minnesota. Mayo Clinic Proceedings. 2016;9111:1555–1562. E6b, E8b, E6b, E6b.
314 OĽeary F M, Beadsmoore C J, Pawaroo D, Skrypniuk J, Heaton M J, Moncrieff M D Survival outcomes and interval between lymphoscintigraphy and SLNB in cutaneous melanoma- findings of a large prospective cohort study. European Journal of Surgical Oncology. 2018;4411:1768–1772. PMID: 30343702. E6c, E6c, E6c, E6c.30343702
315 OĽeary F, Beadsmoore C J, Pawaroo D, Skrypniuk J, Heaton M, Moncrieff M Survival outcomes and interval between lymphoscintigraphy and sentinel node biopsy in cutaneous melanoma: Findings of a large prospective cohort study. Annals of Surgical Oncology. 2017;241:S134. E6c, E8b, E6c, E6c.
316 Olsen C M, Pandeya N, Thompson B S, Dusingize J C, Green A C, Neale R E, Whiteman D C, Q Skin Study Physician Skin Checks before the Diagnosis of Melanoma Correlate with Tumor Characteristics. Journal of Investigative Dermatology. 2018;13810:2288–2291. PMID: 29733814. E6c, E8b, E6c, E6c.29733814
317 Olsen C M, Thompson B S, Green A C, Neale R E, Whiteman D C, Q Skin Sun, Health Study Group Sun Protection and Skin Examination Practices in a Setting of High Ambient Solar Radiation: A Population-Based Cohort Study. JAMA Dermatology. 2015;1519:982–90. PMID: 26039788. E8b, E8b, E8b, E8b.26039788
318 Omara S, Wen D, Ng B, Anand R, Matin R N, Taghipour K, Esdaile B Identification of Incidental Skin Cancers Among Adults Referred to Dermatologists for Suspicious Skin Lesions. JAMA Network Open. 2020;312:e2030107. PMID: 33326027. E5a, E5a, E5a, E5a.33326027
319 Otsuka M, Yamasaki O, Kaji T, Iwatsuki K, Asagoe K Sentinel lymph node biopsy for 102 patients with primary cutaneous melanoma at a single Japanese institute. Journal of Dermatology. 2015;4210:954–61. PMID: 26074328. E6c, E8b, E6c, E6c.26074328
320 Oude Ophuis C M, Louwman M W, Grunhagen D J, Verhoef K, van Akkooi A C Implementation of the 7th edition AJCC staging system: Effects on staging and survival for pT1 melanoma. A Dutch population based study. International Journal of Cancer. 2017;1408:1802–1808. PMID: 28109000. E1, E9b, E1, E1.28109000
321 Oude Ophuis C M, van Akkooi A C, Rutkowski P, Powell W E, Robert C, Testori A, van Leeuwen B L, Siegel P, Eggermont A M, Verhoef C, Grunhagen D J Timing of completion lymphadenectomy after positive sentinel node biopsy in patients with melanoma. British Journal of Surgery. 2017;1046:726–733. PMID: 28218385. E6c, E8b, E6c, E6c.28218385
322 Oude Ophuis C M, van Akkooi A C, Rutkowski P, Voit C A, Stepniak J, Erler N S, Eggermont A M, Wouters M W, Grunhagen D J, Verhoef C K Effects of time interval between primary melanoma excision and sentinel node biopsy on positivity rate and survival. European Journal of Cancer. 2016;67:164–173. PMID: 27669503. E6b, E8b, E6b, E6b.27669503
323 Owen S A, Sanders L L, Edwards L J, Seigler H F, Tyler D S, Grichnik J M Identification of higher risk thin melanomas should be based on Breslow depth not Clark level IV. Cancer. 2001;915:983–91. PMID: 11251950. E6c, E8b, E6c, E6c.11251950
324 6315 ~ Ozao-Choy J, Nelson D W, Hiles J, Stern S, Yoon J L, Sim M S, Faries M B The prognostic importance of scalp location in primary head and neck melanoma. Journal of Surgical Oncology. 2017;1163:337–343. PMID: 28543136. E1, E9b, E1, E1.28543136
325 Padrik P, Valter A, Valter E, Baburin A, Innos K Trends in incidence and survival of cutaneous malignant melanoma in Estonia: a population-based study. Acta Oncologica. 2017;561:52–58. PMID: 27796149. E1, E8b, E1, E1.27796149
326 Palkina N, Sergeeva O, Ruksha T, Artyukhov I Melanoma Screening Day in Krasnoyarsk Krai of the Russian Federation: Results from 2015–2016. Asian Pacific Journal of Cancer Prevention: Apjcp. 2018;192:503–507. PMID: 29480992. E8b, E8b, E8b, E8b.29480992
327 Pan Y, Haydon A M, McLean C A, McDonald P B B, Kelly J W Prognosis associated with cutaneous melanoma metastases. Australasian Journal of Dermatology. 2015;561:25–28. E6b, E9b, E6c, E6c.
328 Paolino G Detection of False Negative Sentinel Lymph Node in Cutaneous Oncology: A General Reappraisal. Journal of Investigative Surgery. 2020;338:748–749. PMID: 32772780. E3, E3, E3, E3.32772780
329 Parikh P P, Tashiro J, Rubio G A, Sola J E, Neville H L, Hogan A R, Perez E A Incidence and outcomes of pediatric extremity melanoma: A propensity score matched SEER study. Journal of Pediatric Surgery. 2018;539:1753–1760. PMID: 29602554. E1, E6d, E1, E1.29602554
330 Parsons B G, Gren L H, Simonsen S E, Harding G, Grossman D, Wu Y P Opportunities for Skin Cancer Prevention Education among Individuals Attending a Community Skin Cancer Screening in a High-Risk Catchment Area. Journal of Community Health. 2018;432:212–219. PMID: 28752269. E8b, E6c, E8b, E8b.28752269
331 Passmore-Webb B, Gurney B, Johns S, Sundram F, Newlands C, Sharma S Sentinel lymph node biopsy for head and neck melanoma - A multi-centre study examining efficacy and safety. British Journal of Oral and Maxillofacial Surgery. 2016;5410:e163. E6c, E8b, E6c, E6c.
332 Passmore-Webb B, Gurney B, Yuen H M, Sloane J, Lee J, Proctor M, Sundram F, Newlands C, Sharma S Sentinel lymph node biopsy for melanoma of the head and neck: a multicentre study to examine safety, efficacy, and prognostic value. British Journal of Oral & Maxillofacial Surgery. 2019;579:891–897. PMID: 31466802. E6c, E8b, E6c, E6c.31466802
333 Patel S H, Ahmad S A Screening high risk populations for cancer. Journal of Surgical Oncology. 2019;1205:819. E3, E3, E3, E3.
334 Pavri S N, Han G, Khan S, Han D Does sentinel lymph node status have prognostic significance in patients with acral lentiginous melanoma?. Journal of Surgical Oncology. 2019;1198:1060–1069. PMID: 30883783. E1, E9b, E1, E1.30883783
335 Pearl R L, Shao K, Shin T M, Miller C J, Sobanko J F Acute Appearance Concerns in Patients Undergoing Mohs Surgery: A Single-Institution Cross-Sectional Study. Dermatologic Surgery. 2018;4410:1349–1351. PMID: 30256237. E1, E1, E1, E1.30256237
336 Pelster M W, Yoo S Use of an Abdominal Binder to Minimize Postprocedural Complications After Cutaneous Surgery on the Trunk. Dermatologic Surgery. 2016;4211:1299–1300. PMID: 27355572. E6c, E6c, E6c, E6c.27355572
337 16438 ∼ Peric B, Milicevic S, Zgajnar J, Hocevar M Survival of melanoma patients after false negative sentinel lymph node biopsy. Journal of the European Academy of Dermatology and Venereology. 2017;31:68. E6c, E8b, E6c, E6c.
338 Peris K Commentary to Shetty A, Janda M, Fry K Clinical utility of skin cancer and melanoma risk scores for population screening: TRoPICS study. Journal of the European Academy of Dermatology & Venereology. 2021;356:1244–1245. E3, E3, E3, E3.
339 Persa O D, Knuever J, Rose A, Mauch C, Schlaak M Predicting risk for seroma development after axillary or inguinal sentinel lymph node biopsy in melanoma patients. International Journal of Dermatology. 2019;582:185–189. PMID: 30229888. E6c, E8b, E6c, E6c.30229888
340 Pignone M P, Adamson A S Keratinocyte Carcinomas: Should We Screen for Them?. American Family Physician. 2020;1026:330–331. PMID: 32931219. E3, E3, E3, E3.32931219
341 Pinto A, El-Basyuni S, Boyle M Involved excision margins in cutaneous head and neck basal cell carcinomas and the outcomes of re-excisions. British Journal of Oral and Maxillofacial Surgery. 2015;5310:e51. E6c, E6c, E6c, E6c.
342 Pitre L D, Linford G, Pond G R, McWhirter E, Seow H Is Access to Care Associated With Stage at Presentation and Survival for Melanoma Patients?. Journal of Cutaneous Medicine & Surgery. 2019;236:586–594. PMID: 31462069. E1, E9b, E1, E1.31462069
343 Pizarro A, Arranz D, Villeta M, Valencia J L Absence of thick, nodular melanomas during long-term surveillance with total body photography and digital dermatoscopy. Journal of the European Academy of Dermatology and Venereology. 2019;339:e341–e342. E3, E3, E3, E3.
344 Pizarro A, Santiago J L, Santiago D I Dermoscopy in the prevention and early diagnosis of melanoma: a biological perspective. Actas Dermo-Sifiliograficas. 2015;1061:3–6. PMID: 25109768. E3, E3, E3, E3.25109768
345 Posch C, Feichtenschlager V, Weihsengruber F, Rappersberger K Eleven years of melanoma patient management-observations and trends from a single-center study in Austria. Pigment Cell and Melanoma Research. 2017;301:132. E6c, E8b, E6c, E6c.
346 Prado G, D'Amore P, Tagliero A, Florez-White M, Acuna J Melanoma incidence from 2001–2011 and predictors of stage at diagnosis. Journal of the American Academy of Dermatology. 2016;745:AB120. E6c, E8b, E6c, E6c.
347 Privalle A, Havighurst T, Kim K, Bennett D D, Xu Y G Number of skin biopsies needed per malignancy: Comparing the use of skin biopsies among dermatologists and nondermatologist clinicians. Journal of the American Academy of Dermatology. 2020;821:110–116. E8b, E6c, E8b, E8b.
348 Quan H, Yan L, Zhang H, Zou L, Yuan W, Wang S Development and validation of a nomogram for prognosis of sinonasal squamous cell carcinoma. International Forum of Allergy & Rhinology. 2019;99:1030–1040. PMID: 31318493. E1, E1, E1, E1.31318493
349 Quinn P L, Oliver J B, Mahmoud O M, Chokshi R J Cost-Effectiveness of Sentinel Lymph Node Biopsy for Head and Neck Cutaneous Squamous Cell Carcinoma. Journal of Surgical Research. 2019;241:15–23. PMID: 31004868. E6c, E8b, E6c, E6c.31004868
350 16464 ∼ Radevic T, Rajovic M, Kremic Z, Ilijin I, Jevremovic L, Mijuskovic Z, Kandolf-Sekulovic L Clinicopathologic characteristics and prognostic factors for thin cutaneous melanoma: Retrospective single-institution analysis. Journal of the European Academy of Dermatology and Venereology. 2017;31:77. E6c, E8b, E6c, E6c.
351 Rahimi-Nedjat R K, Al-Nawas B, Tuettenberg A, Sagheb K, Grabbe S, Walter C Sentinel lymph node biopsy in malignant melanoma of the head and neck. Journal of Cranio-Maxillo-Facial Surgery. 2018;466:1027–1031. PMID: 29735384. E6c, E8b, E6c, E6c.29735384
352 Rahman A, Rahman A K, Rao B Early detection of skin cancer via terahertz spectral profiling and 3D imaging. Biosensors and Bioelectronics. 2016;82:64–70. E1, E1, E1, E1.27040943
353 Rambhia P H, Somach S, Conic R Z, Funovits A, Crowe D, Li B, Joseph N, Sharpe S M, Averbook B J Ratio of tumor thickness to adjacent dermal thickness: A novel prognostic factor for cutaneous melanoma. Annals of Surgical Oncology. 2018;251:S179. E6c, E8b, E6c, E6c.
354 Ramond A, Carroll R, Vekeria S, Nordstrom B PCN114 Investigating Secular Trends in the Survival of Melanoma Patients in England. Value in Health. 2021;24:S40. E3, E3, E3, E3.
355 Ramos-Font C, Triviño-Ibañez E, González-Jiménez A, Sánchez-Sánchez R, Rashki M, García-Redondo J, Masegosa-Sánchez A, López-Ruiz J, Llamas-Elvira J Sentinel lymph node biopsy in melanoma: Results of survival. European Journal of Nuclear Medicine and Molecular Imaging. 2018;45:S437. E6c, E6c, E6c, E6c.
356 Rashed H, Flatman K, Bamford M, Teo K W, Saldanha G Breslow density is a novel prognostic feature in cutaneous malignant melanoma. Histopathology. 2017;702:264–272. PMID: 27502743. E6c, E7b, E6c, E6c.27502743
357 Rat C, Grimault C, Quereux G, Dagorne M, Gaultier A, Khammari A, Dreno B, Nguyen J M Proposal for an annual skin examination by a general practitioner for patients at high risk for melanoma: a French cohort study. BMJ Open. 2015;57:e007471. PMID: 26224016. E8b, E8b, E9a, E8b.26224016
358 Rat C, Hild S, Gaultier A, Khammari A, Bonnaud-Antignac A, Quereux G, Dreno B, Nguyen J M Anxiety, locus of control and sociodemographic factors associated with adherence to an annual clinical skin monitoring: a cross-sectional survey among 1000 high-risk French patients involved in a pilot-targeted screening programme for melanoma. BMJ Open. 2017;710:e016071. PMID: 28982813. E8b, E6c, E8b, E6b.28982813
359 Rat C, Quereux G, Grimault C, Fernandez J, Poiraud M, Gaultier A, Chaslerie A, Pivette J, Khammari A, Dreno B, Nguyen J M Inclusion of populations at risk of advanced melanoma in an opportunistic targeted screening project involving general practitioners. Scandinavian Journal of Primary Health Care. 2016;343:286–94. PMID: 27467203. E8b, E6c, E8b, E8b.27467203
360 Rees M J, Liao H, Spillane J, Speakman D, McCormack C, Donahoe S, Pohl M, Webb A, Gyorki D, Henderson M A Localized melanoma in older patients, the impact of increasing age and comorbid medical conditions. European Journal of Surgical Oncology. 2016;429:1359–66. PMID: 26899940. E1, E9b, E1, E1.26899940
361 Remer J, Fonseca A, Weinstock M A 469 Evaluating melanoma incidence and survival in the US veterans population. Journal of Investigative Dermatology. 2020;1407:S62. E6c, E8b, E6c, E6c.
362 Ribero S, Galli F, Osella-Abate S, Bertero L, Cattaneo L, Merelli B, Tondini C, Ghilardi L, De Giorgi V, Occelli M, Quaglino P, Cassoni P, Palmieri G, Massi D, Mandala M, Italian Melanoma Intergroup Prognostic impact of regression in patients with primary cutaneous melanoma >1 mm in thickness. Journal of the American Academy of Dermatology. 2019;801:99–105.e5. PMID: 30447951. E6c, E8b, E6c, E6c.30447951
363 6758 ∼ Richards M K, Czechowicz J, Goldin A B, Gow K W, Doski J, Goldfarb M, Nuchtern J, Langer M, Beierle E A, Vasudevan S, Gupta D, Parikh S R Survival and Surgical Outcomes for Pediatric Head and Neck Melanoma. JAMA Otolaryngology-- Head & Neck Surgery. 2017;1431:34–40. PMID: 27607058. E1, E6d, E1, E1.
364 Rivard J, Kostaras X, Shea-Budgell M, Chin-Lenn L, Quan M L, McKinnon J G A population-based assessment of melanoma: Does treatment in a regional cancer center make a difference?. Journal of Surgical Oncology. 2015;1122:173–8. PMID: 26445222. E6c, E8b, E6c, E6c.26445222
365 Robinson J K, Jain N, Marghoob A A, McGaghie W, MacLean M, Gerami P, Hultgren B, Turrisi R, Mallett K, Martin G J A Randomized Trial on the Efficacy of Mastery Learning for Primary Care Provider Melanoma Opportunistic Screening Skills and Practice. J Gen Intern Med. 2018;336:855–862. PMID: 29404948. E7b, E8b, E7b, E7b.29404948
366 Robinson J K, MacLean M, Reavy R, Turrisi R, Mallett K, Martin G J Dermoscopy of Concerning Pigmented Lesions and Primary Care Providers' Referrals at Intervals After Randomized Trial of Mastery Learning. J Gen Intern Med. 2018;336:799–800. PMID: 29637481. E8b, E8b, E8b, E8b.29637481
367 Rockberg J, Amelio J M, Taylor A, Jörgensen L, Ragnhammar P, Hansson J Epidemiology of cutaneous melanoma in Sweden—Stage-specific survival and rate of recurrence. International Journal of Cancer. 2016;13912:2722–2729. E6c, E9b, E6c, E6c.
368 Rodríguez-Lomba E, Marquez-Rodas I, Mercader-Cidoncha E, Suárez-Fernández R, Avilés-Izquierdo J A Why do patients with thick melanoma have different outcomes? A retrospective epidemiological and survival analysis. Clinical and Translational Oncology. 2017;198:1055–1057. E6b, E8b, E6b, E6b.
369 Rosenbaum B E, Schafer C N, Han S W, Osman I, Zhong H, Brinster N Computer-assisted measurement of primary tumor area is prognostic of recurrence-free survival in stage IB melanoma patients. Modern Pathology. 2017;3010:1402–1410. E6c, E6c, E6c, E6c.
370 Rosendahl C O, Drugge E D, Volpicelli E R, Drugge R J Diagnosis of a Minute Melanoma Assisted by Automated Multi-Camera-Array Total Body Photography. Australasian Journal of Dermatology. 2016;573:242–3. PMID: 27469484. E3, E3, E3, E3.27469484
371 Rosskamp M, Verbeeck J, Gadeyne S, Verdoodt F, De Schutter H Socio-Economic Position, Cancer Incidence and Stage at Diagnosis: A Nationwide Cohort Study in Belgium. Cancers. 2021;135:24. E6b, E8b, E6b, E6b.
372 Rubin R Melanoma Diagnoses Rise While Mortality Stays Fairly Flat, Raising Concerns About Overdiagnosis. JAMA. 2020;32315:1429–1430. PMID: 32236494. E3, E3, E3, E3.32236494
373 Ručigaj T P, Janežič K, Lipozenčić J Basal cell carcinoma at the university dermatovenerological clinic of Ljubljana, Slovenia. Acta Dermatovenerologica Croatica. 2015;231:66–69. E6c, E8b, E6c, E6c.
374 Ruiz E S, Karia P S, Besaw R, Schmults C D Performance of the American Joint Committee on Cancer Staging Manual, 8th Edition vs the Brigham and Women's Hospital Tumor Classification System for Cutaneous Squamous Cell Carcinoma. JAMA Dermatology. 2019;1557:819–825. E1, E9b, E1, E1.
375 Rutherford M J, Ironmonger L, Ormiston-Smith N, Abel G A, Greenberg D C, Lyratzopoulos G, Lambert P C Estimating the potential survival gains by eliminating socioeconomic and sex inequalities in stage at diagnosis of melanoma. British Journal of Cancer. 2015;112 Suppl 1:S116–23. PMID: 25734390. E6c, E8b, E6c, E6c.25734390
376 10244 ∼ Rutkowski P, Lugowska I, Kosela-Paterczyk H, Zdzienicki M, Goryn T, Teterycz P The Comparison of 8th and 7th Edition of AJCC Staging System in Melanomas at Locoregional Stage. European Journal of Surgical Oncology. 2020;462:e3. E6c, E8b, E6c, E6c.
377 Rutkowski P, Spalek M, Stepniak J, Dziewirski W, Kozak K, Kosela-Paterczyk H, Szumera-Cieckiewicz A, Pienkowski A, Kowalik A, Goryn T, The analysis of outcomes of primary cutaneous melanoma located on hand or foot undergoing sentinel lymph node biopsy. European journal of surgical oncology. Conference: 36th congress of the european society of surgical oncology in partnership with the polish society of surgical oncology, ESSO 36. Poland. 2016;429:S111. PMID: CN-01361635. E1, E1, E1, E1.
378 Rutkowski P, Szydlowski K, Nowecki Z I, Salamacha M, Goryn T, Mitrega-Korab B, Pienkowski A, Dziewirski W, Zdzienicki M The long-term results and prognostic significance of cutaneous melanoma surgery using sentinel node biopsy with triple technique. World Journal of Surgical Oncology. 2015;13:299. PMID: 26462471. E6c, E6c, E6c, E6c.26462471
379 Saldanha G, Flatman K, Teo K W, Bamford M A Novel Numerical Scoring System for Melanoma Tumor-infiltrating Lymphocytes Has Better Prognostic Value Than Standard Scoring. The American journal of surgical pathology. 2017;417:906–914. E6b, E8b, E6b, E6b.
380 Saldanha G, Yarrow J, Pancholi J, Flatman K, Teo K W, Elsheik S, Harrison R, O'Riordan M, Bamford M Breslow Density Is a Novel Prognostic Feature That Adds Value to Melanoma Staging. American Journal of Surgical Pathology. 2018;426:715–725. PMID: 29462090. E6c, E8b, E6c, E6c.29462090
381 Sanders M G H, Pardo L M, Verkouteren J A C, Hamann S A S, Hamer M A, Nijsten T Dermatological screening of a middle-aged and elderly population: the Rotterdam Study. British Journal of Dermatology. 2017;1774:e98–e100. E3, E3, E3, E3.
382 Sanniec K, Harirah M, Thornton J F Ear Reconstruction after Mohs Cancer Excision: Lessons Learned from 327 Consecutive Cases. Plastic & Reconstructive Surgery. 2019;1443:719–729. PMID: 31461038. E6c, E8b, E6c, E6c.
383 Sarac R, Hobbs D Time-lapse total body photography followed by dermoscopy improves melanoma outcomes in a private practice setting. Journal of the American Academy of Dermatology. 2017;766:AB260. E8b, E8b, E9a, E8b.
384 Sargen MR Pfeiffer RM Elder DE Yang XR Goldstein AM Tucker MA The Impact of Longitudinal Surveillance on Tumor Thickness for Melanoma-Prone Families with and without Pathogenic Germline Variants of CDKN2A and CDK4. Cancer epidemiology, biomarkers & prevention. 2021;304:676–681. PMID: 33811164. E6b, E6b, E6b, E6b.33811164
385 Sars C, Gillgren P, Schultz I, Lindqvist E K Risk Factors for Complications and Long-Term Outcomes Following Completion Lymph Node Dissection for Cutaneous Melanoma: A Retrospective Cohort Study. Journal of Plastic, Reconstructive & Aesthetic Surgery: JPRAS. 2020;738:1540–1546. PMID: 32467082. E6c, E8b, E6c, E6c.32467082
386 Schneider JS, Moore DH 2nd, Mendelsohn ML. Screening program reduced melanoma mortality at the Lawrence Livermore National Laboratory, 1984 to 1996. J Am Acad Dermatol. 2008 May;58(5):741–9. PMID: 18068264. E7a, E7a, E7a, E8b18068264
387 Schoffer O, Schulein S, Arand G, Arnholdt H, Baaske D, Bargou R C, Becker N, Beckmann M W, Bodack Y, Bohme B, Bozkurt T, Breitsprecher R, Buchali A, Burger E, Burger U, Dommisch K, Elsner G, Fernschild K, Flintzer U, Funke U, Gerken, Tumour stage distribution and survival of malignant melanoma in Germany 2002–2011. BMC Cancer. 2016;161:936. PMID: 27919243. E1, E9b, E1, E1.27919243
388 Schuitevoerder D, Fortino J, Vetto J T Sentinel node biopsy for T1 melanoma in patients 75 years of age or older does not change clinical outcomes. Annals of Surgical Oncology. 2016;231:S123. E6b, E8b, E6b, E6b.
389 Secker L J, Buis P A, Bergman W, Kukutsch N A Effect of a Dermoscopy Training Course on the Accuracy of Primary Care Physicians in Diagnosing Pigmented Lesions. Acta Derm Venereol. 2017;972:263–265. PMID: 27572816. E8b, E8b, E8b, E8b.27572816
390 3895 ∼ Serte S, Demirel H Gabor wavelet-based deep learning for skin lesion classification. Computers in Biology & Medicine. 2019;113:103423. PMID: 31499395. E1, E1, E1, E1.31499395
391 Severson K, Ederaine S A, Montoya J, Butterfield R, Zhang N, Besch-Stokes J, Hughes A, Ochoa S, Nelson S, DiCaudo D J, Sekulic A, Pittelkow M R, Mangold A 462 Examination of current staging systems in cutaneous squamous cell carcinoma. Journal of Investigative Dermatology. 2020;1407:S61. E6c, E3, E6c, E6c.
392 Shah P, Bajaj S, Polsky D 646 Late-stage melanoma diagnosis in New York State (NYS). Journal of Investigative Dermatology. 2020;1407:S88. E6c, E8b, E6c, E6c.
393 Shan Y, Xu Y, Lu Y, Chen M, Cao J, Wang Y, Lin X, Ye J Epidemiology and Survival Outcomes for Eyelid Primary Malignant Melanoma: An Analysis of 1397 Cases in the SEER Database. Journal of Ophthalmology. 2020;2020:. E1, E9b, E1, E1.
394 Shaub A R, Lewis E T, Swetter S M Patient Perceptions of Primary Care-Based Skin Cancer Screening. JAMA Dermatology. 2017;15311:1192–1193. PMID: 28768305. E8b, E8b, E8b, E8b.28768305
395 Shellenberger R A, Fayyaz F, Sako Z, Schaeffer M, Tawagi K, Scheidel C, Nabhan M Impact of Biopsy Technique on Clinically Important Outcomes for Cutaneous Melanoma: A Systematic Review and Meta-analysis. Mayo Clinic Proceedings: Innovations, Quality and Outcomes. 2020;44:373–383. E3, E3, E3, E3.
396 Shelly S Early Detection of Melanoma by Using Whole Body Screening During Routine Health Visit. Dissertation/ thesis. 2016;:1–1. PMID: CN-02112816. E8b, E8b, E8b, E8b.
397 Shen W, Sakamoto N, Yang L Cancer-specific mortality and competing mortality in patients with head and neck squamous cell carcinoma: a competing risk analysis. Annals of Surgical Oncology. 2015;221:264–71. PMID: 25074664. E6c, E6c, E6c, E6c.25074664
398 Shi P, Xu Z, Lei X, Yibulayin F, Wushou A Desmoplastic melanoma: Demographic and clinicopathological features and disease-specific prognostic factors. Oncology Letters. 2019;176:5619–5627. E6c, E9b, E6c, E6c.
399 Simberg-Danell C, Lyth J, Mansson-Brahme E, Frohm-Nilsson M, Carstensen J, Hansson J, Eriksson H Prognostic factors and disease-specific survival among immigrants diagnosed with cutaneous malignant melanoma in Sweden. International Journal of Cancer. 2016;1393:543–53. PMID: 27004457. E6b, E8b, E6b, E6b.27004457
400 Singh P, Kim H J, Schwartz R A Superficial spreading melanoma: An analysis of 97 702 cases using the SEER database. Melanoma Research. 2016;264:395–400. E1, E9b, E1, E1.
401 Sinnamon A J, Gimotty P A, Karakousis G C, Yang Y X Survival Outcomes Following Lymph Node Biopsy in Thin Melanoma—A Propensity-Matched Analysis. Annals of Surgical Oncology. 2020;:. E6c, E8b, E6c, E6c.
402 Sitenga J, Aird G, Ahmed A, Silberstein P, Walters R Socioeconomic status and survival in patients with melanoma. Journal of the American Academy of Dermatology. 2018;793:AB265. E1, E9b, E1, E1.29037993
403 8638 ∼ Skaggs R, Coldiron B Skin biopsy and skin cancer treatment use in the Medicare population, 1993 to 2016. Journal of the American Academy of Dermatology. 2021;841:53–59. E8b, E8b, E8b, E8b.
404 Smith A J, Lambert P C, Rutherford M J Understanding the impact of sex and stage differences on melanoma cancer patient survival: a SEER-based study. British Journal of Cancer. 2020;04:04. PMID: 33144697. E1, E9b, E1, E1.33144697
405 Smith J R, Wilson A D Complication rates in sentinel lymph node biopsy for melanoma. Journal of Plastic, Reconstructive & Aesthetic Surgery: JPRAS. 2016;693:442. PMID: 26715555. E6b, E8b, E6b, E6b.26715555
406 Sobarun P, Chen A, Lamb S Incidental skin cancer detection on first specialist appointment at greenlane clinical centre. Australasian Journal of Dermatology. 2015;564:a1–a2. E8b, E8b, E9a, E8b.
407 Sober A J Skin cancer screening in the United States. Journal of the European Academy of Dermatology and Venereology. 2017;31:32. E3, E3, E3, E3.
408 Soh B W, Kim Y C, Choi J W Epidemiology of cutaneous melanoma and melanoma in situ: a 10-year nationwide retrospective cohort study in South Korea. Melanoma Research. 2020;303:297–302. PMID: 32356958. E6c, E8b, E7a, E6c.32356958
409 Solari N, Bertoglio S, Boscaneanu A, Minuto M, Reina S, Palombo D, Bruzzi P, Cafiero F Sentinel lymph node biopsy in patients with malignant melanoma: analysis of post-operative complications. ANZ Journal of Surgery. 2019;899:1041–1044. PMID: 31368164. E6c, E8b, E6c, E6c.31368164
410 Sondak V K, Glass L F, Geller A C Risk-stratified screening for detection of melanoma. JAMA. 2015;3136:616–7. PMID: 25668265. E3, E3, E3, E3.25668265
411 Sondermann W, Zimmer L, Schadendorf D, Roesch A, Klode J, Dissemond J Initial misdiagnosis of melanoma located on the foot is associated with poorer prognosis. Medicine. 2016;9529:e4332. PMID: 27442685. E6c, E8b, E6c, E9b.27442685
412 Song X, Zhao Z, Barber B, Farr A M, Ivanov B, Novich M Overall survival in patients with metastatic melanoma. Current Medical Research & Opinion. 2015;315:987–91. PMID: 25708472. E1, E9b, E1, E1.25708472
413 Stanelle E J, Busam K J, Rich B S, Christison-Lagay E R, Dunkel I J, Marghoob A A, Halpern A, Coit D G, La Quaglia M P Early-stage non-Spitzoid cutaneous melanoma in patients younger than 22 years of age at diagnosis: long-term follow-up and survival analysis. Journal of Pediatric Surgery. 2015;506:1019–23. PMID: 25819019. E6c, E8b, E6c, E6c.25819019
414 Stang A, Garbe C, Autier P, Jockel K H The many unanswered questions related to the German skin cancer screening programme. European Journal of Cancer. 2016;64:83–8. PMID: 27371911. E3, E3, E3, E3.27371911
415 Stang A, Jockel K H, Heidinger O Skin cancer rates in North Rhine-Westphalia, Germany before and after the introduction of the nationwide skin cancer screening program (2000–2015). Eur J Epidemiol. 2018;333:303–312. PMID: 29294207. E9a, E6c, E9a, E8b.29294207
416 11046 ∼ Steding-Jessen M, Engberg H, Øster I, Jensen J W, Hölmich L R, Møller H Regional and socioeconomic variation in survival of melanoma patients in Denmark. Danish Medical Journal. 2019;6611:. E1, E9b, E1, E1.
417 Stöckle N, Hauschild A, Kähler K, TNM classification for stage III melanoma patients in a single German referral center. Oncology Research and Treatment. 2020;43:177–178. E1, E9b, E1, E1.
418 Stromberg U, Holmen A, Peterson S Spatial disparities in melanoma incidence and prognosis with consideration to stage at diagnosis, gender and marital status. Spatial and Spatio-Temporal Epidemiology. 2016;19:21–27. PMID: 27839577. E6b, E8b, E6b, E6b.27839577
419 Strunck J L, Smart T C, Boucher K M, Secrest A M, Grossman D Improved melanoma outcomes and survival in patients monitored by total body photography: A natural experiment. Journal of Dermatology. 2020;474:342–347. PMID: 31953873. E8b, E6c, E7b, E8b.31953873
420 Strunck J L, Smart T, Boucher K, Secrest A M, Grossman D 832 Total body photography facilitates early melanoma detection and improves survival. Journal of Investigative Dermatology. 2019;1395:S143. E6b, E8b, E6b, E6b.
421 Sundararajan S, Acharya U, Kumar A, Kanaan M, Cui H, Jeter J M Effect of histological subtype on overall survival in cutaneous melanoma: A Surveillance, Epidemiology, and End Result program (SEER) database review. Journal of Clinical Oncology. 2016;34:. E1, E3, E1, E1.
422 Svedman F C, Pillas D, Taylor A, Kaur M, Linder R, Hansson J Stage-specific survival and recurrence in patients with cutaneous malignant melanoma in Europe – A systematic review of the literature. Clinical Epidemiology. 2016;8:109–122. E3, E3, E3, E3.27307765
423 Swetter S M, Chang J, Shaub A R, Weinstock M A, Lewis E T, Asch S M Primary Care-Based Skin Cancer Screening in a Veterans Affairs Health Care System. JAMA Dermatol. 2017;1538:797–801. PMID: 28593242. E8b, E8b, E8b, E8b.28593242
424 Swetter SM, Pollitt RA, Johnson TM, Brooks DR, Geller AC. Behavioral determinants of successful early melanoma detection: role of self and physician skin examination. Cancer. 2012 Aug 1;118(15):3725–34. PMID: 22179848. E9b, E9b, E9b, E9b.22179848
425 Swords D S, Andtbacka R H I, Bowles T L, Hyngstrom J R Incidence, predictors and significance of pelvic sentinel lymph nodes in inguinal sentinel lymph node biopsy for melanoma. Annals of Surgical Oncology. 2017;241:S138. E6c, E8b, E6c, E6c.
426 Tarhini A, Ghate S, Ionescu-Ittu R, Shi S, Nakasato A, Ndife B, Laliberte F, Burne R, Duh M S Stage III melanoma incidence and impact of transitioning to the 8th AJCC staging system: a US population-based study. Future Oncology. 2019;154:359–370. PMID: 30317881. E1, E9b, E1, E1.30317881
427 Tas F, Erturk K Number of Excised Lymph Nodes Has No Impact on Relapse and Survival in Patients With Stage III Melanoma. Annals of Plastic Surgery. 2019;834:455–458. PMID: 31524742. E1, E9b, E1, E1.31524742
428 Tegtmeyer K, Atassi G, Zhao J, Lio P 178 Association of melanoma mortality rates and geographic density of dermatology and hematology-oncology specialists. Journal of Investigative Dermatology. 2019;1395:S31. E5a, E6c, E5a, E5a.
429 Teh Y L, Goh W L, Tan S H, Yong G, Sairi A N H, Soo K C, Ong J, Chia C, Tan G, Soeharno H, Tan M H, Chan M, Sathiyamoorthy S, Sittampalam K, Teh J, Chin F, Sethi V, Teo M, Quek R, Farid M Treatment and outcomes of melanoma in Asia: Results from the National Cancer Centre Singapore. Asia-Pacific Journal of Clinical Oncology. 2018;142:e95–e102. E1, E9b, E1, E1.
430 12107 ∼ Tejasvi T, Plaska A, Scharnitz T, Hesseler M, Ellis C 256 Incidental melanoma detection following teledermatology consultation. Journal of Investigative Dermatology. 2019;1395:S44. E5a, E8b, E5a, E5a.
431 Tejera-Vaquerizo A, Descalzo-Gallego M A, Traves V, Requena C, Bolumar I, Pla A, Nagore E The intriguing effect of delay time to sentinel lymph node biopsy on survival: a propensity score matching study on a cohort of melanoma patients. European Journal of Dermatology. 2017;275:487–495. PMID: 28944755. E1, E9b, E1, E1.28944755
432 Tejera-Vaquerizo A, Martín-Cuevas P, Gallego E, Herrera-Acosta E, Traves V, Herrera-Ceballos E, Nagore E Predictors of Sentinel Lymph Node Status in Cutaneous Melanoma: A Classification and Regression Tree Analysis. Actas Dermo-Sifiliograficas. 2015;1063:208–218. E1, E8b, E1, E1.
433 Tejera-Vaquerizo A, Nagore E, Puig S, Robert C, Saiag P, Martin-Cuevas P, Gallego E, Herrera-Acosta E, Aguilera J, Malvehy J, Carrera C, Cavalcanti A, Rull R, Vilalta-Solsona A, Lannoy E, Boutros C, Benannoune N, Tomasic G, Aegerte P, V Effect of time to sentinel-node biopsy on the prognosis of cutaneous melanoma. European Journal of Cancer. 2015;5113:1780–93. PMID: 26072362. E6c, E8b, E6c, E6c.26072362
434 Tejera-Vaquerizo A, Ribero S, Puig S, Boada A, Paradela S, Moreno-Ramirez D, Canueto J, de Unamuno B, Brinca A, Descalzo-Gallego M A, Osella-Abate S, Cassoni P, Carrera C, Vidal-Sicart S, Bennassar A, Rull R, Alos L, Requena C, Bolumar, Survival analysis and sentinel lymph node status in thin cutaneous melanoma: A multicenter observational study. Cancer Medicine. 2019;89:4235–4244. PMID: 31215168. E6c, E8b, E6c, E6c.31215168
435 Tella S H, Kommalapati A, Ganti A K, Marr A S Association Between Hospital Volume, Therapy Types, and Overall Survival in Stage III and IV Cutaneous Malignant Melanoma. Journal of the National Comprehensive Cancer Network. 2019;1711:1334–1342. PMID: 31693989. E6c, E8b, E6c, E6c.31693989
436 Teramoto Y, Keim U, Gesierich A, Schuler G, Fiedler E, Tüting T, Ulrich C, Wollina U, Hassel J C, Gutzmer R, Goerdt S, Zouboulis C, Leiter U, Eigentler T K, Garbe C Acral lentiginous melanoma: a skin cancer with unfavourable prognostic features. A study of the German central malignant melanoma registry (CMMR) in 2050 patients. British Journal of Dermatology. 2018;1782:443–451. E1, E9b, E1, E1.
437 Teterycz P, Lugowska I, Kosela-Paterczyk H, Rutkowski P Comparison of seventh and eighth edition of AJCC staging system in melanomas at locoregional stage. World Journal of Surgical Oncology. 2019;171:129. PMID: 31345228. E1, E9b, E1, E1.31345228
438 Thompson J F, Scolyer R A, Lo S N ASO Author Reflections: Long-Term Survival of Patients with Thin (T1) Cutaneous Melanomas. Annals of Surgical Oncology. 2018;25:918–919. E3, E3, E3, E3.30414034
439 Ch Thomson, Cassell O, Peach H, Holloway S, Garioch J, Moncrieff M Neuropathic pain and quality of life after wide local excision and sentinel lymph node biopsy for melanoma: a multicentre study. Melanoma research. 2017;272:121–125. PMID: CN-01339557. E6b, E9a, E6b, E6b.
440 Thomson D R, Rughani M, Kuo R, Cassell O Sentinel node biopsy status is strongly predictive of survival in cutaneous melanoma: Extended follow-up of 1,527 Oxford patients from 1998–2014. Pigment Cell and Melanoma Research. 2018;311:203. E1, E9b, E1, E1.
441 Trautmann F, Meier F, Seidler A, Schmitt J Utilization of the German skin cancer screening program and effects on melanoma incidence and disease severity-a secondary data-based analysis. European Journal of Epidemiology. 2016;31:S212. E8b, E8b, E6b, E8b.
442 Tromme I, Legrand C, Devleesschauwer B, Leiter U, Suciu S, Eggermont A, Francart J, Calay F, Haagsma J A, Baurain J F, Thomas L, Beutels P, Speybroeck N Melanoma burden by melanoma stage: Assessment through a disease transition model. European Journal of Cancer. 2016;53:33–41. PMID: 26693897. E6c, E8b, E6c, E6c.26693897
443 15609 ∼ Troyano Z, Ezcurra S, Laje M C, Vidal G D C Necessary skin excisions to diagnose melanoma. International Journal of Dermatology. 2017;5611:1233. E6c, E8b, E6c, E6c.
444 Truong A, Strazzulla L, March J, Boucher K M, Nelson K C, Kim C C, Grossman D Reduction in nevus biopsies in patients monitored by total body photography. J Am Acad Dermatol. 2016;751:135–143 e5. PMID: 26947450. E5a, E6c, E5a, E5a.26947450
445 Tsai K C, Hung S J, Wang J H, Huang S J, Wang C H, Lee J T, Lee C Y, Chang C H Cutaneous malignant melanoma in Eastern Taiwan: Clinicopathologic analysis of 56 cases. Dermatologica Sinica. 2019;374:187–193. E1, E9b, E1, E1.
446 Tschetter A J, Campoli M R, Zitelli J A, Brodland D G Long-term clinical outcomes of patients with invasive cutaneous squamous cell carcinoma treated with Mohs micrographic surgery: A 5-year, multicenter, prospective cohort study. Journal of the American Academy of Dermatology. 2020;821:139–148. PMID: 31279037. E1, E9b, E1, E1.31279037
447 Urdang Z D, Rosales D, Li R J, Andersen P E, Gross N D, Clayburgh D R Evidence supporting free head and neck cancer screenings. Otolaryngology - Head and Neck Surgery (United States). 2017;1571:P135. E8b, E8b, E8b, E8b.
448 Utjés D, Lyth J, Lapins J, Eriksson H Reduced disease-specific survival following a diagnosis of multiple primary cutaneous malignant melanomas—a nationwide, population-based study. International Journal of Cancer. 2017;14111:2243–2252. E6b, E8b, E6b, E6b.
449 Utter K, Rosenbaum B E, Han S W, Zhong J, Moran U, Vega-Saenz de Miera E, Darvishian F, Polsky D, Berman R S, Shapiro R L, Osman I, Pavlick A C, Wilson M The impact of clinical stage at primary melanoma diagnosis on post-recurrence survival. Journal of Clinical Oncology. 2016;34:. E1, E3, E1, E1.
450 Vaidya T S, Mori S, Khoshab N, Dusza S W, Bander T, Matros E, Rossi A M, Nehal K S, Lee E H Patient-reported Aesthetic Satisfaction following Facial Skin Cancer Surgery Using the FACE-Q Skin Cancer Module. Plastic and Reconstructive Surgery - Global Open. 2019;79:e2423. PMID: 31942391. E6c, E8b, E6c, E6c.31942391
451 Vaidya T S, Nehal K S, Rossi A M, Lee E H Patient-reported adverse effects after facial skin cancer surgery: Long-term data to inform counseling and expectations. Journal of the American Academy of Dermatology. 2019;816:1423–1425. PMID: 31150707. E6c, E6c, E6c, E6c.31150707
452 Vecchiato A, Mocellin S, Del Fiore P, Tosti G, Ascierto P A, Corradin M T, De Giorgi V, Giudice G, Queirolo P, Ferreli C, Occelli M, Giordano M, Trevisan G, Mascheroni L, Testori A, Spina R, Buja A, Cavallin F, Caraco C, Sommariva A The surgical treatment of non-metastatic melanoma in a Clinical National Melanoma Registry Study Group (CNMR): a retrospective cohort quality improvement study to reduce the morbidity rates. BMC Cancer. 2021;211:8. PMID: 33402122. E6c, E8b, E6c, E6c.33402122
453 Vecchiato A, Zonta E, Campana L, Dal Bello G, Rastrelli M, Rossi C R, Alaibac M Long-term Survival of Patients With Invasive Ultra-thin Cutaneous Melanoma: A Single-center Retrospective Analysis. Medicine. 2016;952:e2452. PMID: 26765437. E1, E9b, E1, E1.26765437
454 Volonteri V, Rinflerch A, Pol M, Roude C, Pagotto V, Galimberti G, Mazzuoccolo L, Garcia-Rivello H Histopathological risk factors in melanoma: A retrospective cohort study in argentinian population. Modern Pathology. 2020;333:506–508. E1, E3, E1, E1.
455 Von Schuckmann L A, Hughes M C B, Ghiasvand R, Malt M, Van Der Pols J C, Beesley V L, Khosrotehrani K, Smithers B M, Green A C Risk of Melanoma Recurrence after Diagnosis of a High-Risk Primary Tumor. JAMA Dermatology. 2019;1556:688–693. E1, E9b, E1, E1.
456 5110 ∼ von Schuckmann L A, Hughes M C B, Lee R, Lorigan P, Khosrotehrani K, Smithers B M, Green A C Survival of patients with early invasive melanoma down-staged under the new eighth edition of the American Joint Committee on Cancer staging system. Journal of the American Academy of Dermatology. 2019;801:272–274. PMID: 29673775. E6c, E8b, E5a, E6c.29673775
457 Waalboer-Spuij R, Hollestein L M, van de Poll-Franse L V, Nijsten T E C Histological diagnosis of basal cell carcinoma is not associated with life expectancy in elderly Dutch people: a population-based cohort study. British Journal of Dermatology. 2017;1774:e88–e89. E3, E3, E3, E3.
458 Waldmann A, Nolte S, Geller A C, Katalinic A, Weinstock M A, Volkmer B, Greinert R, Breitbart E W Frequency of excisions and yields of malignant skin tumors in a population-based screening intervention of 360,288 whole-body examinations. Arch Dermatol. 2012;1488:903–10. PMID: 22911184. E8b, E6c, E8b, E8b.22911184
459 Walia S, Ivanic M G, Jafri Z A, Wu J J Skin cancer screening and prevention during the COVID-19 pandemic. Cutis. 2021;1071:41–42;53. E3, E3, E3, E3.
460 Wang S, Ezaldein H H, Delost G R, Tripathi R, Stamey C, Neudecker M, Scott J F Safety and Efficacy of Mohs Micrographic Surgery in Children and Adolescents: A Systematic Review. Dermatologic Surgery. 2020;467:880–884. PMID: 31834072. E3, E3, E3, E3.31834072
461 Wang Z, Li H, Liu X, Bae J, Huang X, Gao Y, Xu X, Guo J, Lu L, Zan T, Li Q Discordance of pathological thin melanoma thickness and T stage in SEER registry: Impacts on clinical management and research directions. Oncotarget. 2017;858:97727–97735. E1, E9b, E1, E1.
462 Wanis C, Aabed S, McIntosh C, Alwan S, Mizen K, Crank S Can surgical excision match the gold standard of Moh's surgery? A 4-year 2-centre study on head and neck skin cancer. British Journal of Oral and Maxillofacial Surgery. 2019;5710:e99–e100. E6c, E8b, E6c, E6c.
463 Ward C E, MacIsaac J L, Heughan C E, Weatherhead L Metastatic Melanoma in Sentinel Node-Negative Patients: The Ottawa Experience. Journal of Cutaneous Medicine & Surgery. 2018;221:14–21. PMID: 28689448. E6c, E8b, E6c, E6c.28689448
464 Watts C G, Madronio C M, Morton R L, Goumas C, Armstrong B K, Curtin A, Menzies S W, Mann G J, Thompson J F, Cust A E Diagnosis and clinical management of melanoma patients at higher risk of a new primary melanoma: A population-based study in New South Wales, Australia. Australasian Journal of Dermatology. 2017;584:278–285. PMID: 27477217. E8b, E6c, E8b, E8b.27477217
465 Watts CG, McLoughlin K, Goumas C, van Kemenade CH, Aitken JF, Soyer HP, Fernandez Peñas P, Guitera P, Scolyer RA, Morton RL, Menzies SW, Caruana M, Kang YJ, Mann GJ, Chakera AH, Madronio CM, Armstrong BK, Thompson JF, Cust AE. Association Between Melanoma Detected During Routine Skin Checks and Mortality. JAMA Dermatol. 2021 Dec 1;157(12):1425–1436. doi: 10.1001/jamadermatol.2021.3884. PMID: 34730781; PMCID: PMC8567188. E11, E11, E6c, E6c.34730781
466 Weinstock M A, Ferris L K, Saul M I, Geller A C, Risica P M, Siegel J A, Solano F X, Kirkwood J M Downstream consequences of melanoma screening in a community practice setting: First results. Cancer. 2016;12220:3152–3156. PMID: 27391802. E8b, E6c, E8b, E8b.27391802
467 Weinstock M A, Ferris L, Saul M, Geller A, Risica P, Solano F, Lagnese J, Kirkwood J Melanoma screening consequences. Journal of Investigative Dermatology. 2015;135:S55. E3, E3, E3, E3.26269266
468 Weitemeyer M B, Bramsen P, Klausen T W, Holmich L R, Gjorup C A Patient-and observer-reported long-term scar quality of wide local excision scars in melanoma patients. Journal of Plastic Surgery and Hand Surgery. 2018;526:319–324. PMID: 30380964. E6c, E8b, E6c, E6c.30380964
469 Weitman E S, Perez M, Thompson J F, Andtbacka R H I, Dalton J, Martin M L, Miller T, Gwaltney C, Sarson D, Wachter E, Zager J S Quality of life patient-reported outcomes for locally advanced cutaneous melanoma. Melanoma Research. 2018;282:134–142. E1, E1, E1, E2.
470 Welch H G, Kramer B S, Black W C Epidemiologic Signatures in Cancer. N Engl J Med. 2019;38114:1378–1386. PMID: 31577882. E6c, E9b, E6c, E6c.31577882
471 20617 ∼ Whiteman D C, Baade P D, Olsen C M More people die from thin melanomas (1 mm) than from thick melanomas (>4 mm) in Queensland, Australia. J Invest Dermatol. 2015;1354:1190–1193. PMID: 25330295. E6c, E9b, E6c, E6c.25330295
472 Williams Merten J, King J L, Largo-Wight E Total body skin examination adherence among young adults with an increased risk for skin cancer. Dermatology Online Journal. 2017;236:15. PMID: 28633754. E6b, E8b, E6b, E6b.28633754
473 Wilson M A, Zhong J, Rosenbaum B E, Utter K, Moran U, Darvishian F, Polsky D, Berman R S, Shapiro R L, Pavlick A C, Osman I Impact of initial stage on metastatic melanoma survival. Melanoma Research. 2019;293:281–288. PMID: 31026246. E1, E9b, E1, E1.31026246
474 Winge-Main A, Robsahm T E, Nyakas M S, Festervoll G, Torkilseng E, Thybo S, Pati S, Carroll R Long-term outcomes of stage IIB-IV melanoma patients: Nationwide data from Norway. Annals of Oncology. 2020;31:S766–S767. E1, E9b, E1, E1.
475 Wisco O J, Adelson D Basal cell carcinoma screening drives a comprehensive approach to skin cancer. British Journal of Dermatology. 2016;1746:1182–3. PMID: 27317277. E3, E3, E3, E3.27317277
476 Wollina U Reconstruction of Large Facial Defects after Delayed Mohs Surgery for Skin Cancer. Acta Dermatovenerologica Croatica. 2015;234:265–9. PMID: 26724878. E6c, E8b, E6c, E6c.26724878
477 Wollina U, Langner D, Schonlebe J, Tanner C, Fuchs M, Nowak A Sentinel lymph node biopsy in early melanoma-comparison of two techniques for sentinel removal. Wiener Medizinische Wochenschrift. 2017; 1675–6:100–103. PMID: 27577250. E6b, E8b, E6b, E6b.27577250
478 Wong Y F, Yusof M M, Wan Ishak W Z, Alip A, Phua V C Treatment outcome for head and neck squamous cell carcinoma in a developing country: University Malaya Medical Centre, Malaysia from 2003–2010. Asian Pacific Journal of Cancer Prevention: Apjcp. 2015;167:2903–8. PMID: 25854381. E6c, E6c, E6c, E6c.25854381
479 Xavier M H S B, Dmmmond-Lage A P, Baeta C, Rocha L, Almeida A M, Wainstein A J A Delay in cutaneous melanoma diagnosis: Sequence analyses from suspicion to diagnosis in 211 patients. Medicine (United States). 2016;9531:. E5b, E5b, E5b, E5b.
480 Xu Z, Shi P, Yibulayin F, Feng L, Zhang H, Wushou A Spindle cell melanoma: Incidence and survival, 1973–2017. Oncology Letters. 2018;164:5091–5099. E6c, E9b, E6c, E6c.
481 Xu Z, Yibulayin F, Shi P, Feng L Desmoplastic melanoma versus spindle cell melanoma: Incidence and survival, 1973 to 2017. Medicine. 2018;9729:e11563. PMID: 30024556. E6c, E6c, E6c, E6c.30024556
482 Yang C, Liao F, Cao L Web-based nomograms for predicting the prognosis of adolescent and young adult skin melanoma, a large population-based real-world analysis. Translational Cancer Research. 2020;911:7103–7112. E1, E9b, E1, E1.
483 Yang J, Pan Z, Zhao F, Feng X, Liu Q, Li Y, Lyu J A nomogram for predicting survival in patients with nodular melanoma: A population-based study. Medicine. 2019;9824:e16059. PMID: 31192966. E1, E9b, E1, E1.31192966
484 8558 ∼ Yasuta M, Sato S, Kouraba S, lino S, Kiyohara T A statistical study on malignant melanoma over the past 12 years in Fukui University Hospital. International Journal of Clinical Oncology. 2015;201:182–7. PMID: 24633373. E1, E9b, E1, E1.24633373
485 Yun J K, Kim H R, Kim D K, Shim Y M, Kim Y T, Chung K Y, Lee G D, Hwang S K, Choi S, Kim Y H, Park S I, Shin S, Cho J H, Kim H K, Kim J, Zo J I, Park S, Hyun K Y, Hwang Y, Lee H J, Park I K, Kang C H, Lee C Y, Lee, Tumor size as a prognostic factor in limited-stage thymic epithelial tumors: A multicenter analysis. Journal of Thoracic and Cardiovascular Surgery. 2020;:. E1, E1, E1, E1.
486 Zahirsha Z, Barnes J, Simpson M C, Osazuwa-Peters N 25553 Suicide risk among melanoma and nonepithelial skin cancer patients: A Surveillance, Epidemiology, and End Results analysis. Journal of the American Academy of Dermatology. 2021;853:AB8. E7b, E1, E7b, E7b.
487 Zhang D, Wang Z, Shang D, Yu J, Yuan S Incidence and prognosis of brain metastases in cutaneous melanoma patients: A population-based study. Melanoma Research. 2019;291:77–84. E1, E9b, E1, E1.
488 Zhang S, Liu R, Switzer G, Siripong N, Kirkwood J, Holtzman M, Davar D, Najjar Y, Marshall K, Cullison S J, Houston N, Ferris L Patient and tumor characteristics associated with high and lower risk melanoma detection. Journal of the American Academy of Dermatology. 2019;814:AB251. E6c, E8b, E6c, E6c.
489 Znaor A Melanoma burden, healthcare utilization and the potential for overdiagnosis in the elderly U.S. population. British Journal of Dermatology. 2017; 1773:625. E3, E3, E3, E3.
490 Zohar Y, Shreberk-Hassidim R, Elia J, Elia A, Maly A, Margolis A, Hassidim A Clinical description of skin lesions in pathology requisition forms completed by plastic surgeons is lacking: a retrospective study of 499 lesions. European Journal of Plastic Surgery. 2018;412:249–252. E8b, E8b, E8b, E8b.