# Appendix C Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

## Key Question 1

1. Datzmann T, Schoffer O, Meier F, Seidler A, Schmitt, J. Are patients benefiting from participation in the German skin cancer screening programme? A large cohort study based on administrative data. Br J Dermatol. 2022;186(1):69–77. PMID: 34289097.
2. Kaiser M, Schiller J, Schreckenberger C. The effectiveness of a population-based skin cancer screening program: evidence from Germany. European Journal of Health Economics. 2018;193:355–367. PMID: 28353004.
  ○ Boniol M, Autier P, Gandini S. Melanoma mortality following skin cancer screening in Germany. BMJ Open. 2015;59:e008158. PMID: 26373399.
  ○ Geller AC, Greinert R, Sinclair C, Weinstock MA, Aitken J, Boniol M, Capellaro M, Dore JF, Elwood M, Fletcher SW, Gallagher R, Gandini S, Halpern AC, Katalinic A, Lucas R, Marghoob AA, Nolte S, Schuz J, Tucker MA, Volkmer B, Breitbart E. A nationwide population-based skin cancer screening in Germany: proceedings of the first meeting of the International Task Force on Skin Cancer Screening and Prevention (September 24 and 25, 2009). Cancer Epidemiol. 2010;343:355–8. PMID: 20381443.
  ○ Kornek T, Schafer I, Reusch M, Blome C, Herberger K, Beikert FC, Augustin M. Routine skin cancer screening in Germany: four years of experience from the dermatologists' perspective. Dermatology. 2012;225(4):289–93. PMID: 23295723.
3. Katalinic A, Eisemann N, Waldmann A. Skin Cancer Screening in Germany. Documenting Melanoma Incidence and Mortality From 2008 to 2013. Dtsch Arztebl Int. 2015;11238:629–34. PMID: 26429634.
  ○ Breitbart EW, Waldmann A, Nolte S, Capellaro M, Greinert R, Volkmer B, Katalinic A. Systematic skin cancer screening in Northern Germany. J Am Acad Dermatol. 2012;662:201–11. PMID: 22074699.
  ○ Eisemann N, Waldmann A, Holleczek B, Katalinic A. Observed and Expected Mortality in the German Skin Cancer Screening Pilot Project Screen. J Med Screen. 2018;253:166–168.
  ○ Katalinic A, Waldmann A, Weinstock MA, Geller AC, Eisemann N, Greinert R, Volkmer B, Breitbart E. Does skin cancer screening save lives?: an observational study comparing trends in melanoma mortality in regions with and without screening. Cancer. 2012;11821:5395–402. PMID: 22517033.
  ○ Stang A, Jöckel KH. Does Skin Cancer Screening Save Lives? A Detailed Analysis of Mortality Time Trends in Schleswig-Holstein and Germany. Cancer. 2016;1223:432–7. PMID: 26480048.

## Key Question 2

4. Aitken JF, Elwood M, Baade PD, Youl P, English D. Clinical whole-body skin examination reduces the incidence of thick melanomas. Int J Cancer. 2010;1262:450–8. PMID: 19609948.
5. Cristofolini M, Boi S, Cattoni D, Sicher MC, Decarli A, Micciolo RA. 10-Year Follow-Up Study of Subjects Recruited in a Health Campaign for the Early Diagnosis of Cutaneous Melanoma: Suggestions for the Screening Timetable. Dermatology. 2015;2314:345–52. PMID: 26278413.
6. Matsumoto M, Wack S, Weinstock MA, Geller A, Wang H, Solano FX, Kirkwood JM, Ferris LK. Five-Year Outcomes of a Melanoma Screening Initiative in a Large Health Care System. JAMA Dermatol. 2022 Apr 6. doi: 10.1001/jamadermatol.2022.0253. Epub ahead of print. PMID: 35385051.
  ○ Ferris LK, Saul MI, Lin Y, Ding F, Weinstock MA, Geller AC, Yuan JM, Neuren E, Maddukuri S, Solano FX, Kirkwood JMA. Large Skin Cancer Screening Quality Initiative: Description and First-Year Outcomes. JAMA Oncology. 2017;38:1112–1115. PMID: 28241191.
7. Hoorens I, Vossaert K, Pil L, Boone B, De Schepper S, Ongenae K, Annemans L, Chevolet I, Brochez L. Total-body examination vs lesion-directed skin cancer screening. JAMA Dermatol. 2016;1521:27–34.
8. Krensel M, Andrees V, Mohr N, Hischke S. Costs of routine skin cancer screening in Germany - a claims data analysis. Clinical & Experimental Dermatology. 2020;30:30. PMID: 33378094.
9. Trautmann F, Meier F, Seidler A, Schmitt J. Effects of the German skin cancer screening programme on melanoma incidence and indicators of disease severity. British Journal of Dermatology. 2016;1755:912-919. PMID: 27203791.

## Key Question 3

10. Gambichler T, Senger E, Rapp S, Alamouti D, Altmeyer P, Hoffmann K. Deep shave excision of macular melanocytic nevi with the razor blade biopsy technique. Dermatol Surg. 2000;267:662–6. PMID: 10886275.
11. Risica PM, Matthews NH, Dionne L, Mello J, Ferris LK, Saul M, Geller AC, Solano F, Kirkwood JM, Weinstock MA. Psychosocial consequences of skin cancer screening. Preventive Medicine Reports. 2018;10:310–316. PMID: 29868385.
  ○ Matthews NH, Risica PM, Ferris LK, Beatson M, Saul M, Geller AC, Solano F, Kirkwood JM, Weinstock MA. Psychosocial impact of skin biopsies in the setting of melanoma screening: a cross-sectional survey. British Journal of Dermatology. 2019;1803:664–665. PMID: 30183068.

## Key Question 4

12. Dawes SM, Tsai S, Gittleman H, Barnholtz-Sloan JS, Bordeaux JS. Racial disparities in melanoma survival. Journal of the American Academy of Dermatology. 2016;755:983–991. PMID: 27476974.
13. Enninga EAL, Moser JC, Weaver AL, Markovic SN, Brewer JD, Leontovich AA, Hieken J, Shuster L, Kottschade LA, Olariu A, Mansfield AS, Dronca RS. Survival of cutaneous melanoma based on sex, age, and stage in the United States, 1992–2011. Cancer Medicine. 2017;610:2203–2212. PMID: 28879661.
14. Farrow NE, Turner MC, Salama AKS, Beasley GM. Overall Survival Improved for Contemporary Patients with Melanoma: A 2004–2015 National Cancer Database Analysis. Oncology & Therapy. 2020;82:261-275. PMID: 32700043.
15. Khosrotehrani K, Dasgupta P, Byrom L, Youlden DR, Baade PD, Green A. Melanoma survival is superior in females across all tumour stages but is influenced by age. Archives of Dermatological Research. 2015;307(8):731–40. PMID: 26103951.
16. Mahendraraj K, Sidhu K, Lau CS, McRoy GJ, Chamberlain RS, Smith FO. Malignant Melanoma in African-Americans: A Population-Based Clinical Outcomes Study Involving 1106 African-American Patients from the Surveillance, Epidemiology, and End Result (SEER) Database (1988–2011). Medicine. 2017;9615:e6258. PMID: 28403068.
17. Robsahm TE, Helsing P, Nilssen Y, Vos L, Rizvi SMH, Akslen LA, Veierod MB. High mortality due to cutaneous melanoma in Norway: a study of prognostic factors in a nationwide cancer registry. Clinical Epidemiology. 2018;10:537–548. PMID: 29780262.
18. Ward-Peterson M, Acuña JM, Alkhalifah MK, Nasiri AM, Al-Akeel ES, Alkhaldi TM, Dawari SA, Aldaham SA. Association between Race/Ethnicity and Survival of Melanoma Patients in the United States over 3 Decades. Medicine (Baltimore). 2016;95(17):e3315. PMID: 27124020.
19. Zheng G, Chattopadhyay S, Sundquist K, Sundquist J, Forsti A, Hemminki A, Hemminki K. Association between tumor characteristics and second primary cancers with cutaneous melanoma survival: A nationwide cohort study. Pigment Cell & Melanoma Research. 2020;334:625–632. PMID: 32012479.
20. Qian Y, Johannet P, Sawyers A, Yu, J, Osman, I, Zhong, J. The ongoing racial disparities in melanoma: An analysis of the Surveillance, Epidemiology, and End Results database (1975–2016). J Am Acad Dermatol. 2021;84(6):1585–93. PMID: 32861710.