# Appendix B Recommendations of Others

Country | Organization | Year | Recommendation
United States | American Cancer Society (ACS)^4,^ ^5^ | 2020, Accessed | Recommend cancer-related check-ups for persons aged >20 years by having periodic health exams and counseling, including skin cancer.; The ACS suggests that approximately 10% of all people with melanoma have a family history of the disease and that this population get regular skin exams by a dermatologist and perform self-exams monthly.
United States | American Academy of Family Physicians (AAFP) | 2016 | AAFP agrees with the USPSTF’s recommendations on skin cancer screening and provides no separate recommendations.
United States | American Academy of Dermatology (AAD)^6^ | 2020, Accessed | Provides a language that encourages regular self-exams in asymptomatic persons with no history of skin cancer. Also, the AAD states that persons should seek advice from their health providers on the frequency of self-exam.
Australia and New Zealand | Cancer Council Australia (CCA)^7^; endorsed by the Australasian College of Dermatologists | 2019 | [underlined: General population:] screening is not recommended due to insufficient evidence that screening reduces mortality. However, the CCA states that persons should consult their health provider if they notice any change in their skin.; [underlined: High-risk persons]: CCA encourages total body photography and dermatoscopy every 6 months in persons with a high-risk for skin cancer (defined as having fair skin, light eye color, light or red hair, multiple nevi, compromised immune system, personal/family history of any skin cancer).
Australia and New Zealand | Royal Australian College of General Practitioners (RACGP)^8^ | 2018 | [underlined: General population:] screening is not recommended due to insufficient evidence that screening reduces mortality.; Recommended opportunistic screening in persons with an increased risk for skin cancer (based on family history, skin type, actinic damage, history of KC, and high levels of exposure and episodes of sunburn in childhood).; [underlined: High-risk persons:] RACGP encourages self-exams in persons with a high-risk (i.e., either with a history of melanoma or >5 atypical nevi) for skin cancer every 3 months and clinical examination every 6 months.
Australia and New Zealand | Australian Skin and Skin Cancer Research Center Melanoma Screening Summit^9^ | 2019 | [underlined: General population]: There is currently insufficient evidence to support systematic screening in the general population.; [underlined: High-risk persons]: More research is needed on how risk-based population stratification tools could improve the balance of benefits and harms of opportunistic screening.
Germany | Federal Joint Committee^10^ | 2008 | Nationwide skin cancer screening program: Routine screening is offered to adults aged ≥35 with health insurance every two years.
The Netherlands | Dutch Working Group on Melanoma^11^ | 2013 | General population: Routine screening is not recommended.; [underlined: Increased risk:] Annual exams are recommended for persons with ≥5 atypical nevi or with ≥100 banal nevi.; [underlined: High-risk persons]: In persons with a high-risk due to genetic factors: Screening of the skin once or twice per year by a dermatologist.
United Kingdom | British Association of Dermatologists^12^ | 2010 | [underlined: Increased risk for skin cancer]: Recommended self-exam and monitoring by a health provider.