# Appendix A Literature Search Strategies for Primary Literature

Bridge searches

MEDLINE via Ovid:

Database: Ovid MEDLINE(R) ALL <1946 to January 06, 2022>

Search Strategy:

--------------------------------------------------------------------------------

1. Skin Neoplasms/ (129409)
2. Melanoma/ (90728)
3. Melanoma, Amelanotic/ (652)
4. Nevus/ (6301)
5. Dysplastic Nevus Syndrome/ (1136)
6. Hutchinson's Melanotic Freckle/ (744)
7. Carcinoma, Basal Cell/ (17897)
8. Carcinoma, Squamous Cell/ (135127)
9. Carcinoma, Merkel Cell/ (2824)
10. Neoplasms, Basal Cell/ (647)
11. Neoplasms, Squamous Cell/ (1685)
12. "Neoplasms, Adnexal and Skin Appendage"/ (339)
13. Actinic keratosis/ (2315)
14. Bowen disease/ (1949)
15. Lymphoma, T-Cell, Cutaneous/ (3697)
16. ((skin or derm$ or cutaneous or epithelial or epithelium or epiderm$) adj3 (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or dysplas$)).ti. (52939)
17. melanoma$.ti. (76077)
18. ((naevoid or nevoid) adj3 syndrome$).ti. (49)
19. ((dysplastic or malignant) adj2 (nevus or naevus or nevi or naevi)).ti. (836)
20. Hutchinson$ Melanotic Freckle.ti. (11)
21. lentigo maligna.ti. (558)
22. (basal cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti. (7894)
23. ((basocellular$ or basosquamous) adj carcinoma$).ti. (117)
24. (squamous cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti. (52500)
25. (merkel cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti. (2746)
26. actinic keratosis.ti. (1164)
27. bowen$ disease.ti. (1119)
28. (cutaneous adj2 lymphoma$).ti. (1006)
29. or/1–28 (363896)
30. ((skin or derm$ or cutaneous or epithelial or epithelium or epiderm$) adj3 (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or dysplas$)).ti,ab. (175444)
31. melanoma$.ti,ab. (126484)
32. ((naevoid or nevoid) adj3 syndrome$).ti,ab. (152)
33. ((dysplastic or malignant) adj2 (nevus or naevus or nevi or naevi)).ti,ab. (2138)
34. Hutchinson$ Melanotic Freckle.ti,ab. (35)
35. lentigo maligna.ti,ab. (1188)
36. (basal cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti,ab. (15572)
37. ((basocellular$ or basosquamous) adj carcinoma$).ti,ab. (241)
38. (squamous cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti,ab. (112585)
39. (merkel cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti,ab. (3680)
40. actinic keratosis.ti,ab. (2541)
41. bowen$ disease.ti,ab. (2167)
42. (cutaneous adj2 lymphoma$).ti,ab. (2494)
43. 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 (391209)
44. limit 43 to ("in data review" or in process or "pubmed not medline") (42473)
45. 29 or 44 [skin cancer terms] (385494)
46. Mass screening/ (111499)
47. Early detection of Cancer/ (31666)
48. (screen$ or detect$).ti,ab. (3208953)
49. 46 or 47 or 48 [screening terms] (3240300)
50. Physical Examination/ (42354)
51. Dermoscopy/ (5296)
52. Photography/ (27041)
53. ((skin or body or physical) adj3 (exam$ or inspect$)).ti,ab. (92934)
54. visual$ inspect$.ti,ab. (9509)
55. dermoscop$.ti,ab. (5313)
56. dermatoscop$.ti,ab. (1225)
57. photography.ti,ab. (15973)
58. 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 [exam terms] (180612)
59. 45 and 49 and 58 (2490)
60. screen$.ti. (194784)
61. 45 and 60 (2089)
62. 59 or 61 (4307)
63. limit 62 to (english language and yr="2015 -Current") (1676)
64. remove duplicates from 63 (1673)
65. Biopsy/ (183099)
66. Biopsy, Needle/ (49569)
67. Biopsy, Large-Core Needle/ (2178)
68. Sentinel Lymph Node Biopsy/ (12226)
69. (biopsy$ or biopsies or biopsied).ti,ab. (426788)
70. (excise* or excision$).ti,ab. (183198)
71. Rebiops$.ti,ab. (752)
72. 65 or 66 or 67 or 68 or 69 or 70 or 71 [biopsy] (700929)
73. (harm or harms or harmful or harmed).ti,ab. (137516)
74. (adverse effects or mortality).fs. (2379318)
75. Mortality/ or Morbidity/ (77303)
76. death/ (18760)
77. (death or deaths).ti,ab. (909617)
78. "Drug-Related Side Effects and Adverse Reactions"/ or Long Term Adverse Effects/ (35776)
79. ((adverse or negative or unintended) adj (effect$ or event$ or outcome$ or reaction$)).ti,ab. (484749)
80. complication$.ti,ab. (1005513)
81. side effect$.ti,ab. (271474)
82. safety.ti,ab. (586254)
83. false negative$.ti,ab. (36032)
84. misdiagnos$.ti,ab. (38092)
85. overdiagnos$.ti,ab. (4523)
86. ((unneeded or unnecessary) adj5 (treat$ or therap$ or surg$ or procedure$)).ti,ab. (14620)
87. label$.ti,ab. (565965)
88. psychological effect$.ti,ab. (4699)
89. Cicatrix/ (24030)
90. (cicatrix or scar$).ti,ab. (187490)
91. 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 [harms] (5315254)
92. 45 and 72 and 91 (13066)
93. limit 92 to (english language and yr="2015 -Current") (4063)
94. remove duplicates from 93 (4058)
95. Neoplasm Staging/ (186206)
96. ((detect$ or diagnos$ or biops$) adj5 stage).ti,ab. (45586)
97. ((late$ or distant or advanced or end) adj stage).ti,ab. (137365)
98. ((early or earlier) adj (diagnos$ or detect$ or discovery or findings)).ti,ab. (178249)
99. 95 or 96 or 97 or 98 [staging] (512692)
100. Registries/ (101512)
101. Survival Analysis/ (143501)
102. SEER program/ (9043)
103. Morbidity/ (32372)
104. Mortality/ (48301)
105. Death/ (18760)
106. mo.fs. (621324)
107. (registr$ or register$).ti,ab. (469949)
108. SEER.ti,ab. (9016)
109. "Surveillance epidemiology and end results".ti,ab. (11568)
110. morbidit$.ti,ab. (431528)
111. mortalit$.ti,ab. (868291)
112. (death or deaths).ti,ab. (909617)
113. survival.ti,ab. (1052085)
114. 110 or 111 or 112 or 113 (2531644)
115. limit 114 to ("in data review" or in process or "pubmed not medline") (283788)
116. 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108 or 109 or 115 [registries morbidity] (1479421)
117. 45 and 99 and 116 (12827)
118. limit 117 to (english language and yr="2015 -Current") (4435)
119. remove duplicates from 118 (4430)
120. Dermatologic Surgical Procedures/ (7326)
121. Curettage/ (4588)
122. Dessication/ (7746)
123. Cryosurgery/ (13662)
124. Laser Therapy/ (39419)
125. Mohs Surgery/ (3651)
126. Lymph Node Excision/ (35762)
127. (surger$ or surgical).ti. (664277)
128. curettage.ti,ab. (12149)
129. dessicat$.ti,ab. (289)
130. electrodessicat$.ti,ab. (138)
131. cryosurg$.ti,ab. (4153)
132. laser ablation.ti,ab. (8326)
133. mohs.ti,ab. (3829)
134. metastasectom$.ti,ab. (2544)
135. lymphadenectom$.ti,ab. (18578)
136. ((lymph node$ or lymphoid) adj3 (remov$ or dissect$ or resect$)).ti,ab. (28082)
137. 127 or 128 or 129 or 130 or 131 or 132 or 133 or 134 or 135 or 136 (727329)
138. limit 137 to ("in data review" or in process or "pubmed not medline") (72745)
139. 120 or 121 or 122 or 123 or 124 or 125 or 126 or 138 (182804)
140. 45 and 139 (14973)
141. Skin Neoplasms/su (17958)
142. Melanoma/su (10396)
143. Melanoma, Amelanotic/su (128)
144. Nevus/su (587)
145. Dysplastic Nevus Syndrome/su (95)
146. Hutchinson's Melanotic Freckle/su (248)
147. Carcinoma, Basal Cell/su (5135)
148. Carcinoma, Squamous Cell/su (27490)
149. Carcinoma, Merkel Cell/su (494)
150. Neoplasms, Basal Cell/su (59)
151. Neoplasms, Squamous Cell/su (227)
152. "Neoplasms, Adnexal and Skin Appendage"/su (80)
153. Actinic keratosis/su (73)
154. Bowen disease/su (254)
155. Lymphoma, T-Cell, Cutaneous/su (49)
156. 140 or 141 or 142 or 143 or 144 or 145 or 146 or 147 or 148 or 149 or 150 or 151 or 152 or 153 or 154 or 155 [skin cancer surgery] (55498)
157. Lymphedema/ (9779)
158. Lymph?edema.ti,ab. (10882)
159. Surgical wound infection/ (38685)
160. ((surg$ or postsurg$ or post-surg$) adj2 infect$).ti,ab. (22073)
161. 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 89 or 90 or 157 or 158 or 159 or [harms lymphedema surgery outcomes] (4788906)
162. 156 and 161 (18891)
163. limit 162 to (english language and yr="2015 -Current") (4281)
164. 64 or 94 or 119 or 163 (12204)
165. Animal/ not (Animal/ and Human/) (4905488)
166. 164 not 165 (12092)
167. (oral or tongue or larynx or laryng$ or hypolaryng$ or oropharyng$ or pharynx or pharyng$ or esophag$ or oesophag$ or gastric or ovary or ovaries or ovarian or cervical or cervix or endometrium or endometrial or lung or breast or ocular or vulva$ or anus or anal or mucosal).ti. (1550547)
168. 166 not 167 (7672)

Cochrane Central Register of Controlled Clinical Trials (CENTRAL) via Wiley:

Date Run: 07/01/2022 20:49:50

- #1 (skin or derm* or cutaneous or epithelial or epithelium or epiderm*):ti,ab,kw near/3 (cancer* or neoplasm* or carcinoma* or tumor* or tumour* or malignan* or lesion* or metasta* or dysplas*):ti,ab,kw 9428
- #2 melanoma*:ti,ab,kw 5929
- #3 (naevoid or nevoid):ti,ab,kw near/3 syndrome*:ti,ab,kw 0
- #4 (dysplastic or malignant):ti,ab,kw near/2 (nevus or naevus or nevi or naevi):ti,ab,kw 40
- #5 "Hutchinson's Melanotic Freckle":ti,ab,kw 8
- #6 "lentigo maligna":ti,ab,kw 33
- #7 basal:ti,ab,kw next cell:ti,ab,kw next (carcinoma* or neoplasm* or cancer* or tumor* or tumour* or malignan* or lesion* or metasta* or epithelioma*):ti,ab,kw 1035
- #8 (basocellular* or basosquamous):ti,ab,kw next carcinoma*:ti,ab,kw 6
- #9 squamous:ti,ab,kw next cell:ti,ab,kw next (carcinoma* or neoplasm* or cancer* or tumor* or tumour* or malignan* or lesion* or metasta* or epithelioma*):ti,ab,kw 6777
- #10 merkel:ti,ab,kw next cell:ti,ab,kw next (carcinoma* or neoplasm* or cancer* or tumor* or tumour* or malignan* or lesion* or metasta* or epithelioma*):ti,ab,kw 88
- #11 "actinic keratosis":ti,ab,kw 814
- #12 bowen*:ti,ab,kw next disease:ti,ab,kw 111
- #13 cutaneous:ti,ab,kw near/2 lymphoma*:ti,ab,kw 37
- #14 {or #1-#13} 20514
- #15 screen*:ti,ab,kw 82568
- #16 (skin or body or physical):ti,ab,kw near/3 (exam* or inspect*):ti,ab,kw 18448
- #17 (dermoscop* or dermatoscop*):ti,ab,kw 349
- #18 visual*:ti,ab,kw next inspect*:ti,ab,kw 790
- #19 photography:ti,ab,kw 3866
- #20 {or #15-#19} 100455
- #21 #14 and #20 with Publication Year from 2015 to present, in Trials 935
- #22 (biopsy* or biopsies or biopsied):ti,ab,kw 33249
- #23 (excise* or excision*):ti,ab,kw 7371
- #24 rebiops*:ti,ab,kw 167
- #25 #22 or #23 or #24 39569
- #26 (harm or harms or harmful or harmed):ti,ab,kw 13354
- #27 (death or deaths):ti,ab,kw 80022
- #28 (adverse or negative or unintended):ti,ab,kw next (effect* or event* or outcome* or reaction*):ti,ab,kw 280044
- #29 complication*:ti,ab,kw 198035
- #30 side:ti,ab,kw next effect*:ti,ab,kw 150014
- #31 safety:ti,ab,kw 258866
- #32 false:ti,ab,kw next negative*:ti,ab,kw1607
- #33 misdiagnos*:ti,ab,kw 462
- #34 overdiagnos*:ti,ab,kw 392
- #35 (unneeded or unnecessary):ti,ab,kw near/5 (treat* or therap* or surg* or procedure*):ti,ab,kw 948
- #36 label*:ti,ab,kw 78015
- #37 psychological:ti,ab,kw next effect*:ti,ab,kw 794
- #38 (cicatrix or scar*):ti,ab,kw 13001
- #39 {or #26-#38} 693560
- #40 #14 and #25 and #39 with Publication Year from 2015 to present, in Trials 761
- #41 (detect* or diagnos* or biops*):ti,ab,kw near/5 stage:ti,ab,kw 4134
- #42 (late* or distant or advanced or end):ti,ab,kw next stage:ti,ab,kw 11264
- #43 (early or earlier):ti,ab,kw next (diagnos* or detect* or discovery or findings):ti,ab,kw 6960
- #44 #41 or #42 or #43 21418
- #45 #14 and #44 with Publication Year from 2015 to present, in Trials 557
- #46 (surger* or surgical):ti76330
- #47 curettage:ti,ab,kw 1685
- #48 dessicat*:ti,ab,kw 7
- #49 electrodessicat*:ti,ab,kw 15
- #50 cryosurg*:ti,ab,kw 540
- #51 "laser ablation":ti,ab,kw 600
- #52 mohs:ti,ab,kw 260
- #53 metastasectom*:ti,ab,kw 183
- #54 lymphadenectom*:ti,ab,kw 1782
- #55 ("lymph node" or "lymph nodes" or lymphoid):ti,ab,kw near/3 (remov* or dissect* or resect*):ti,ab,kw 3615
- #56 {or #46-#55} 82689
- #57 (lymphedema or lymphoedema):ti,ab,kw 1519
- #58 (surg* or postsurg* or post-surg*):ti,ab,kw near/2 infect*:ti,ab,kw 7719
- #59 (#26 or #27 or #28 or #29 or #30 or #31 or #38 or #57 or #58) 667482
- #60 #14 and #56 and #59 with Publication Year from 2015 to present, in Trials 498
- #61 #21 or #40 or #45 or #60 2291

Date limit line:

- #62 #21 or #40 or #45 or #60 with Cochrane Library publication date from Jan 2021 to present 357

Embase via Elsevier:

- #1. 'skin cancer'/exp OR 'skin tumor'/de OR 'melanoma'/de OR 'benign skin tumor'/exp OR 'actinic keratosis'/de 329,895
- #2. ((skin OR derm* OR cutaneous OR epithelial OR epithelium OR epiderm*) NEAR/3 (cancer* OR neoplas* OR carcinoma* OR tumo*r* OR malignan* OR lesion* OR metasta* OR dysplas*)):ti,ab 245,169
- #3. melanoma*:ti,ab 179,108
- #4. ((naevoid OR nevoid) NEAR/3 syndrome*):ti,ab 191
- #5. ((dysplastic OR malignant) NEAR/2 (nevus OR naevus OR nevi OR naevi)):ti,ab 2,753
- #6. hutchinson*:ti,ab AND'melanotic freckle’:ti,ab 61
- #7. 'lentigo maligna’:ti,ab 1,715
- #8. (’basal cell’ NEAR/1 (cancer* OR neoplas* OR carcinoma* OR tumo*r* OR malignan* OR lesion* OR metasta* OR epithelioma*)):ti,ab 21,605
- #9. ((basocellular* OR basosquamous) NEAR/1 carcinoma*):ti,ab 375
- #10. (’merkel cell’ NEAR/1 (cancer* OR neoplas* OR carcinoma* OR tumo*r* OR malignan* OR lesion* OR metasta* OR epithelioma*)):ti,ab 5,309
- #11. 'actinic keratosis’:ti,ab 3,695
- #12. 'bowen* disease’:ti,ab 2,797
- #13. (cutaneous NEAR/2 lymphoma*):ti,ab 3,733
- #14. #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 553,819
- #15. 'mass screening'/de OR 'cancer screening'/de OR 'early cancer diagnosis'/de 154,924
- #16. screen*:ti,ab OR detect*:ti,ab 4,178,597
- #17. #15 OR #16 4,217,374
- #18. 'physical examination'/de OR 'skin examination'/exp OR 'photography'/exp 515,079
- #19. ((skin OR body OR physical) NEAR/3 (exam* OR inspect*)):ti,ab 161,831
- #20. 'visual* inspect*':ti,ab 13,775
- #21. dennoscop*:ti,ab 6,929
- #22. dermatoscop*:ti,ab 1,842
- #23. photography:ti,ab 20,361
- #24. #18 OR #19 OR #20 OR #21 OR #22 OR #23 612,334
- #25. #14 AND #17 AND #24 8,084
- #26. screen*:ti 259,234
- #27. #14 AND #26 3,017
- #28. #25 OR #27 10,603
- #29. 'biopsy'/de OR 'skin examination'/exp OR 'large core needle biopsy'/de OR 'sentinel lymph node biopsy'/de 399,688
- #30. biopsy*:ti,ab OR biopsies:ti,ab OR biopsied:ti,ab 694,052
- #31. excise*:ti,ab OR excision*:ti,ab 243,059
- #32. rebiops*:ti,ab 2,910
- #33. #29 OR #30 OR #31 OR #32 1,108,202
- #34. harm:ti,ab OR harms:ti,ab OR harmful:ti,ab OR harmed:ti,ab 176,555
- #35. 'mortality'/de OR 'cancer mortality'/de OR 'surgical mortality'/de OR 'death'/de OR 'morbidity'/de OR 'adverse evenť/exp OR 'side effecť/exp 2,249,034
- #36. death:ti,ab OR deaths:ti,ab 1,307,735
- #37. ((adverse OR negative OR unintended) NEAR/1 (effect* OR event* OR outcome* OR reaction*)):ti,ab 742,638
- #38. complication*:ti,ab 1,490,258
- #39. 'side effect*':ti,ab 402,017
- #40. safety:ti,ab 904,820
- #41. 'false negative*':ti,ab 50,380
- #42. misdiagnos*:ti,ab 55,381
- #43. overdiagnos*:ti,ab 7,917
- #44. ((unneeded OR unnecessary) NEAR/5 (treat* OR therap* OR surg* OR procedure*)):ti,ab 22,509
- #45. label*:ti,ab 720,613
- #46. 'psychological effect*':ti,ab 5,894
- #47. 'scar'/exp 85,856
- #48. cicatrix:ti,ab OR scar*:ti,ab 255,035
- #49. #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48 6,344,805
- #50. #14 AND #33 AND #49 23,410
- #51. ťumor classification'/exp 498,822
- #52. ((detect* OR diagnos* OR biops*) NEAR/5 stage):ti,ab 78,925
- #53. ((late* OR distant OR advanced OR end) NEAR/1 stage):ti,ab 206,326
- #54. ((early OR earlier) NEAR/1 (diagnos* OR detect* OR discovery OR findings)):ti,ab 282,585
- #55. #51 OR #52 OR #53 OR #54 978,055
- #56. 'register'/de OR 'cancer registry'/exp OR 'survival analysis'/de 187,332
- #57. 'mortality'/de OR 'cancer mortality'/de OR 'surgical mortality'/de OR 'death'/de OR 'morbidity'/de 1,384,498
- #58. registr*:ti,ab OR register*:ti,ab 650,353
- #59. seer:ti,ab 17,108
- #60. 'surveillance epidemiology and end results':ti,ab 16,793
- #61. morbidit*:ti,ab 655,879
- #62. mortalit*:ti,ab 1,280,224
- #63. death:ti,ab OR deaths:ti,ab 1,307,735
- #64. survival:ti,ab 1,561,919
- #65. #56 OR #57 OR #58 OR #59 OR #60 OR #61 OR #62 OR #63 OR #64 4,449,378
- #66. #14 AND #55 AND #65 23,560
- #67. 'skin surgery'/de OR 'curettage'/de OR 'desiccation'/de OR 'cryosurgery'/de OR 'low level laser therapy'/de OR 'mohs micrographic surgery'/de OR 'lymph node dissection'/de 147,891
- #68. surger*:ti OR surgical:ti 834,877
- #69. curettage:ti,ab 15,473
- #70. dessicat*:ti,ab 361
- #71. electrodessicat*:ti,ab 231
- #72. cryosurg*:ti,ab 5,275
- #73.'laser ablation':ti,ab 9,484
- #74. mohs:ti,ab 4,701
- #75. metastasectom*:ti,ab 3,920
- #76. lymphadenectom*:ti,ab 29,224
- #77. ((’lymph node*' OR lymphoid) NEAR/3 (remov* OR dissect* OR resect*)):ti,ab 44,056
- #78. #67 OR #68 OR #69 OR #70 OR #71 OR #72 OR #73 OR #74 OR #75 OR #76 OR #77 1,002,439
- #79. #14 AND #78 30,464
- #80. 'skin cancer'/exp/dm_su OR 'skin tumor'/dm_su OR 'melanoma'/dm_su OR 'benign skin tumor'/exp/dm_su OR 'actinic keratosis'/dm_su 35,388
- #81. #79 OR #80 54,550
- #82. 'lymphedema'/de 19,168
- #83. lymph*edema:ti,ab 15,762
- #84. 'surgical infection'/de 56,782
- #85. ((surg* OR postsurg* OR 'post surg*') NEAR/2 infect*):ti,ab 32,076
- #86. #49 OR #82 OR #83 OR #84 OR #85 6,390,209
- #87. #81 AND #86 15,203
- #88. #28 OR #50 OR #66 OR #87 61,359
- #89. #88 NOT (('animal model'/exp OR 'animal experimenť/exp OR 'nonhuman'/de OR 'animal'/exp) NOT 'human'/de) 59,748
- #90. oral:ti OR tongue:ti OR larynx:ti OR laryng*:ti OR hypolaryng*:ti OR oropharyng*:ti OR pharynx:ti OR pharyng*:ti OR esophag*:ti OR oesophag*:ti OR gastric:ti OR ovary:ti OR ovaries:ti OR ovarian:ti OR cervical:ti OR cervix:ti OR endometrium:ti OR endometrial:ti OR lung:ti OR breast:ti OR ocular:ti OR vulva*:ti OR anus:ti OR anal:ti OR mucosal:ti 2,043,498
- #91. #89 NOT #90 48,492
- #92. 'clinical trial'/de OR 'controlled clinical trial'/de OR 'randomized controlled trial'/exp OR 'randomization'/exp OR 'single blind procedure'/de OR 'double blind procedure'/de OR 'crossover procedure'/de OR 'placebo'/de 1,745,764
- #93. 'meta analysis'/exp OR 'meta analysis (topic)'/de 277,275
- #94. 'intermethod comparison'/de OR 'double blind procedure'/de 470,348
- #95. 'clinical trial*':ti,ab OR 'controlled trial*':ti,ab OR random*:ti,ab OR metaanaly*:ti,ab OR 'meta analy*':ti,ab OR trial:ti OR placebo:ti,ab 2,463,628
- #96. compare:ti OR compared:ti OR comparison:ti 576,882
- #97. (evaluated:ab OR evaluate:ab OR evaluating:ab OR assessed:ab OR assess:ab) AND (compare:ab OR compared:ab OR comparing:ab OR comparison:ab) 2,420,992
- #98. (open NEXT/1 label):ti,ab 93,410
- #99. ((double OR single OR doubly OR singly) NEXT/1 (blind OR blinded OR blindly)):ti,ab 253,841
- #100.(parallel NEXT/1 group*):ti,ab 28,650
- #101.crossover:ti,ab OR 'cross over':ti,ab 114,247
- #102.((assign* OR match OR matched OR allocation) NEAR/6 (alternate OR group OR groups OR intervention OR interventions OR patient OR patients OR subject OR subjects OR participant OR participants)):ti,ab 405,885
- #103.assigned:ti,ab OR allocated:ti,ab 435,414
- #104.(controlled NEAR/8 (study OR design OR trial)):ti,ab 404,226
- #105.volunteer:ti,ab OR volunteers:ti,ab 264,587
- #106.#92 OR #93 OR #94 OR #95 OR #96 OR #97 OR #98 OR #99 OR #100 OR #101 OR #102 OR #103 OR #104 OR #105 6,142,879
- #107.'controlled study'/exp 8,776,888
- #108.'longitudinal study'/exp OR 'prospective study'/de OR 'retrospective study'/de 1,998,477
- #109.'cohort analysis'/de OR 'follow up'/de 2,394,342
- #110.'observational study'/de 258,002
- #111.'correlational study'/de 52,279
- #112.'family study'/de 26,087
- #113.'case control*':ti,ab 187,623
- #114.cohort:ti,ab 1,105,924
- #115.1ongitudinal:ti,ab 381,034
- #116.'follow up':ti,ab OR followup:ti,ab 1,751,006
- #117.prospective*:ti,ab 1,210,350
- #118.'comparison group*':ti,ab OR 'control group*':ti,ab 757,393
- #119.observational:ti,ab 339,743
- #120.retrospective*:ti,ab 1,455,587
- #121.database*:ti,ab 798,285
- #122.nonrandomi*:ti,ab 39,615
- #123.population*:ti,ab 2,608,255
- #124.epidemiologic*:ti,ab 345,127
- #125.'cross sectional':ti,ab 558,465
- #126.#107 OR #108 OR #109 OR #110 OR #111 OR #112 OR #113 OR #114 OR #115 OR #116 OR #117 OR #118 OR #119 OR #120 OR #121 OR #122 OR #123 OR #124 OR #125 14,329,834
- #127.#106 OR #126 16,342,576
- #128.#91 AND #127 30,081
- #129.#91 AND #127 AND [english]/lim AND [2015–2022]/py 15,132

Date limit line:

- #130.#91 AND #127 AND [english]/lim AND [2015–2022]/py AND [12–01-202l]/sd 3,570

Original searches

MEDLINE via Ovid:

Database: Ovid MEDLINE(R) and Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Daily and Versions(R) <1946 to January 08, 2021>

Search Strategy:

--------------------------------------------------------------------------------

1. Skin Neoplasms/ (122639)
2. Melanoma/ (85810)
3. Melanoma, Amelanotic/ (611)
4. Nevus/ (6097)
5. Dysplastic Nevus Syndrome/ (1116)
6. Hutchinson's Melanotic Freckle/ (680)
7. Carcinoma, Basal Cell/ (17171)
8. Carcinoma, Squamous Cell/ (130801)
9. Carcinoma, Merkel Cell/ (2599)
10. Neoplasms, Basal Cell/ (622)
11. Neoplasms, Squamous Cell/ (1654)
12. "Neoplasms, Adnexal and Skin Appendage"/ (307)
13. Actinic keratosis/ (2109)
14. Bowen disease/ (1899)
15. Lymphoma, T-Cell, Cutaneous/ (3465)
16. ((skin or derm$ or cutaneous or epithelial or epithelium or epiderm$) adj3 (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or dysplas$)).ti. (50559)
17. melanoma$.ti. (72435)
18. ((naevoid or nevoid) adj3 syndrome$).ti. (49)
19. ((dysplastic or malignant) adj2 (nevus or naevus or nevi or naevi)).ti. (829)
20. Hutchinson$ Melanotic Freckle.ti. (11)
21. lentigo maligna.ti. (538)
22. (basal cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti. (7564)
23. ((basocellular$ or basosquamous) adj carcinoma$).ti. (111)
24. (squamous cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti. (48326)
25. (merkel cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti. (2577)
26. actinic keratosis.ti. (1074)
27. bowen$ disease.ti. (1096)
28. (cutaneous adj2 lymphoma$).ti. (948)
29. or/1–28 (348146)
30. ((skin or derm$ or cutaneous or epithelial or epithelium or epiderm$) adj3 (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or dysplas$)).ti,ab. (167103)
31. melanoma$.ti,ab. (120189)
32. ((naevoid or nevoid) adj3 syndrome$).ti,ab. (148)
33. ((dysplastic or malignant) adj2 (nevus or naevus or nevi or naevi)).ti,ab. (2095)
34. Hutchinson$ Melanotic Freckle.ti,ab. (33)
35. lentigo maligna.ti,ab. (1138)
36. (basal cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti,ab. (14905)
37. ((basocellular$ or basosquamous) adj carcinoma$).ti,ab. (227)
38. (squamous cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti,ab. (105191)
39. (merkel cell adj (cancer$ or neoplas$ or carcinoma$ or tumo?r$ or malignan$ or lesion$ or metasta$ or epithelioma$)).ti,ab. (3438)
40. actinic keratosis.ti,ab. (2382)
41. bowen$ disease.ti,ab. (2112)
42. (cutaneous adj2 lymphoma$).ti,ab. (2353)
43. 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 (370760)
44. limit 43 to ("in data review" or in process or "pubmed not medline") (43213)
45. 29 or 44 [skin cancer terms] (370216)
46. Mass screening/ (105601)
47. Early detection of Cancer/ (26804)
48. (screen$ or detect$).ti,ab. (3009872)
49. 46 or 47 or 48 [screening terms] (3040274)
50. Physical Examination/ (41203)
51. Dermoscopy/ (4707)
52. Photography/ (26210)
53. ((skin or body or physical) adj3 (exam$ or inspect$)).ti,ab. (87690)
54. visual$ inspect$.ti,ab. (8796)
55. dermoscop$.ti,ab. (4728)
56. dermatoscop$.ti,ab. (1128)
57. photography.ti,ab. (15108)
58. 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 [exam terms] (171739)
59. 45 and 49 and 58 (2329)
60. screen$.ti. (182363)
61. 45 and 60 (1990)
62. 59 or 61 (4056)
63. limit 62 to (english language and yr="2015 -Current") (1430)
64. remove duplicates from 63 (1414)
65. Biopsy/ (176527)
66. Biopsy, Needle/ (49302)
67. Biopsy, Large-Core Needle/ (1821)
68. Sentinel Lymph Node Biopsy/ (11353)
69. (biopsy$ or biopsies or biopsied).ti,ab. (406321)
70. (excise* or excision$).ti,ab. (175778)
71. Rebiops$.ti,ab. (711)
72. 65 or 66 or 67 or 68 or 69 or 70 or 71 [biopsy] (671651)
73. (harm or harms or harmful or harmed).ti,ab. (123766)
74. (adverse effects or mortality).fs. (2255171)
75. Mortality/ or Morbidity/ (72919)
76. death/ (17846)
77. (death or deaths).ti,ab. (846009)
78. "Drug-Related Side Effects and Adverse Reactions"/ or Long Term Adverse Effects/ (33489)
79. ((adverse or negative or unintended) adj (effect$ or event$ or outcome$ or reaction$)).ti,ab. (441798)
80. complication$.ti,ab. (938978)
81. side effect$.ti,ab. (255697)
82. safety.ti,ab. (531682)
83. false negative$.ti,ab. (34148)
84. misdiagnos$.ti,ab. (34921)
85. overdiagnos$.ti,ab. (4189)
86. ((unneeded or unnecessary) adj5 (treat$ or therap$ or surg$ or procedure$)).ti,ab. (13635)
87. label$.ti,ab. (542702)
88. psychological effect$.ti,ab. (4193)
89. Cicatrix/ (22736)
90. (cicatrix or scar$).ti,ab. (171218)
91. 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 83 or 84 or 85 or 86 or 87 or 88 or 89 or 90 [harms] (4990117)
92. 45 and 72 and 91 (12442)
93. limit 92 to (english language and yr="2015 -Current") (3444)
94. remove duplicates from 93 (3413)
95. Neoplasm Staging/ (177140)
96. ((detect$ or diagnos$ or biops$) adj5 stage).ti,ab. (41929)
97. ((late$ or distant or advanced or end) adj stage).ti,ab. (128088)
98. ((early or earlier) adj (diagnos$ or detect$ or discovery or findings)).ti,ab. (164256)
99. 95 or 96 or 97 or 98 [staging] (479381)
100. Registries/ (92863)
101. Survival Analysis/ (137979)
102. SEER program/ (8047)
103. Morbidity/ (30677)
104. Mortality/ (45548)
105. Death/ (17846)
106. mo.fs. (591252)
107. (registr$ or register$).ti,ab. (421847)
108. SEER.ti,ab. (7869)
109. "Surveillance epidemiology and end results".ti,ab. (10223)
110. morbidit$.ti,ab. (403380)
111. mortalit$.ti,ab. (797285)
112. (death or deaths).ti,ab. (846009)
113. survival.ti,ab. (979037)
114. 110 or 111 or 112 or 113 (2350010)
115. limit 114 to ("in data review" or in process or "pubmed not medline") (290125)
116. 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108 or 109 or 115 [registries morbidity] (1401438)
117. 45 and 99 and 116 (12258)
118. limit 117 to (english language and yr="2015 -Current") (3864)
119. remove duplicates from 118 (3830)
120. Dermatologic Surgical Procedures/ (7074)
121. Curettage/ (4446)
122. Dessication/ (7297)
123. Cryosurgery/ (13148)
124. Laser Therapy/ (38148)
125. Mohs Surgery/ (3246)
126. Lymph Node Excision/ (33723)
127. (surger$ or surgical).ti. (631566)
128. curettage.ti,ab. (11639)
129. dessicat$.ti,ab. (287)
130. electrodessicat$.ti,ab. (127)
131. cryosurg$.ti,ab. (4106)
132. laser ablation.ti,ab. (7776)
133. mohs.ti,ab. (3519)
134. metastasectom$.ti,ab. (2358)
135. lymphadenectom$.ti,ab. (17730)
136. ((lymph node$ or lymphoid) adj3 (remov$ or dissect$ or resect$)).ti,ab. (26158)
137. 127 or 128 or 129 or 130 or 131 or 132 or 133 or 134 or 135 or 136 (691169)
138. limit 137 to ("in data review" or in process or "pubmed not medline") (74054)
139. 120 or 121 or 122 or 123 or 124 or 125 or 126 or 138 (179096)
140. 45 and 139 (14309)
141. Skin Neoplasms/su (17070)
142. Melanoma/su (10021)
143. Melanoma, Amelanotic/su (125)
144. Nevus/su (576)
145. Dysplastic Nevus Syndrome/su (92)
146. Hutchinson's Melanotic Freckle/su (223)
147. Carcinoma, Basal Cell/su (4921)
148. Carcinoma, Squamous Cell/su (26692)
149. Carcinoma, Merkel Cell/su (465)
150. Neoplasms, Basal Cell/su (58)
151. Neoplasms, Squamous Cell/su (227)
152. "Neoplasms, Adnexal and Skin Appendage"/su (75)
153. Actinic keratosis/su (68)
154. Bowen disease/su (249)
155. Lymphoma, T-Cell, Cutaneous/su (48)
156. 140 or 141 or 142 or 143 or 144 or 145 or 146 or 147 or 148 or 149 or 150 or 151 or 152 or 153 or 154 or 155 [skin cancer surgery] (53576)
157. Lymphedema/ (9233)
158. Lymph?edema.ti,ab. (10159)
159. Surgical wound infection/ (36984)
160. ((surg$ or postsurg$ or post-surg$) adj2 infect$).ti,ab. (20180)
161. 73 or 74 or 75 or 76 or 77 or 78 or 79 or 80 or 81 or 82 or 89 or 90 or 157 or 158 or 159 or [harms lymphedema surgery outcomes] (4484893)
162. 156 and 161 (18243)
163. limit 162 to (english language and yr="2015 -Current") (3643)
164. 64 or 94 or 119 or 163 (10392)
165. Animal/ not (Animal/ and Human/) (4741836)
166. 164 not 165 (10302)
167. (oral or tongue or larynx or laryng$ or hypolaryng$ or oropharyng$ or pharynx or pharyng$ or esophag$ or oesophag$ or gastric or ovary or ovaries or ovarian or cervical or cervix or endometrium or endometrial or lung or breast or ocular or vulva$ or anus or anal or mucosal).ti. (1473595)
168. 166 not 167 (6505)

Cochrane Central Register of Controlled Clinical Trials (CENTRAL) via Wiley:

Date Run: 12/01/2021 22:56:53

- #1 (skin or derm* or cutaneous or epithelial or epithelium or epiderm*):ti,ab,kw near/3 (cancer* or neoplasm* or carcinoma* or tumor* or tumour* or malignan* or lesion* or metasta* or dysplas*):ti,ab,kw 8659
- #2 melanoma*:ti,ab,kw 5471
- #3 (naevoid or nevoid):ti,ab,kw near/3 syndrome*:ti,ab,kw 0
- #4 (dysplastic or malignant):ti,ab,kw near/2 (nevus or naevus or nevi or naevi):ti,ab,kw 38
- #5 "Hutchinson's Melanotic Freckle":ti,ab,kw 8
- #6 "lentigo maligna":ti,ab,kw 28
- #7 basal:ti,ab,kw next cell:ti,ab,kw next (carcinoma* or neoplasm* or cancer* or tumor* or tumour* or malignan* or lesion* or metasta* or epithelioma*):ti,ab,kw 966
- #8 (basocellular* or basosquamous):ti,ab,kw next carcinoma*:ti,ab,kw 5
- #9 squamous:ti,ab,kw next cell:ti,ab,kw next (carcinoma* or neoplasm* or cancer* or tumor* or tumour* or malignan* or lesion* or metasta* or epithelioma*):ti,ab,kw 6265
- #10 merkel:ti,ab,kw next cell:ti,ab,kw next (carcinoma* or neoplasm* or cancer* or tumor* or tumour* or malignan* or lesion* or metasta* or epithelioma*):ti,ab,kw 74
- #11 "actinic keratosis":ti,ab,kw 746
- #12 bowen*:ti,ab,kw next disease:ti,ab,kw 106
- #13 cutaneous:ti,ab,kw near/2 lymphoma*:ti,ab,kw 33
- #14 {or #1-#13} 18926
- #15 screen*:ti,ab,kw 73849
- #16 (skin or body or physical):ti,ab,kw near/3 (exam* or inspect*):ti,ab,kw 16935
- #17 (dermoscop* or dermatoscop*):ti,ab,kw 267
- #18 visual*:ti,ab,kw next inspect*:ti,ab,kw 712
- #19 photography:ti,ab,kw 3469
- #20 {or #15-#19} 90240
- #21 #14 and #20 with Publication Year from 2015 to 2021, in Trials 769
- #22 (biopsy* or biopsies or biopsied):ti,ab,kw 30879
- #23 (excise* or excision*):ti,ab,kw 6815
- #24 rebiops*:ti,ab,kw 158
- #25 #22 or #23 or #24 36717
- #26 (harm or harms or harmful or harmed):ti,ab,kw 12063
- #27 (death or deaths):ti,ab,kw 72613
- #28 (adverse or negative or unintended):ti,ab,kw next (effect* or event* or outcome* or reaction*):ti,ab,kw 259695
- #29 complication*:ti,ab,kw 184994
- #30 side:ti,ab,kw next effect*:ti,ab,kw 141964
- #31 safety:ti,ab,kw 237359
- #32 false:ti,ab,kw next negative*:ti,ab,kw1496
- #33 misdiagnos*:ti,ab,kw 401
- #34 overdiagnos*:ti,ab,kw 367
- #35 (unneeded or unnecessary):ti,ab,kw near/5 (treat* or therap* or surg* or procedure*):ti,ab,kw 865
- #36 label*:ti,ab,kw 69921
- #37 psychological:ti,ab,kw next effect*:ti,ab,kw 718
- #38 (cicatrix or scar*):ti,ab,kw 11624
- #39 {or #26-#38} 642600
- #40 #14 and #25 and #39 with Publication Year from 2015 to 2021, in Trials 648
- #41 (detect* or diagnos* or biops*):ti,ab,kw near/5 stage:ti,ab,kw 3664
- #42 (late* or distant or advanced or end):ti,ab,kw next stage:ti,ab,kw 10187
- #43 (early or earlier):ti,ab,kw next (diagnos* or detect* or discovery or findings):ti,ab,kw 6228
- #44 #41 or #42 or #43 19252
- #45 #14 and #44 with Publication Year from 2015 to 2021, in Trials 468
- #46 (surger* or surgical):ti70496
- #47 curettage:ti,ab,kw 1581
- #48 dessicat*:ti,ab,kw 7
- #49 electrodessicat*:ti,ab,kw 14
- #50 cryosurg*:ti,ab,kw 501
- #51 "laser ablation":ti,ab,kw 565
- #52 mohs:ti,ab,kw 236
- #53 metastasectom*:ti,ab,kw 166
- #54 lymphadenectom*:ti,ab,kw 1665
- #55 ("lymph node" or "lymph nodes" or lymphoid):ti,ab,kw near/3 (remov* or dissect* or resect*):ti,ab,kw 3310
- #56 {or #46-#55} 76395
- #57 (lymphedema or lymphoedema):ti,ab,kw 1383
- #58 (surg* or postsurg* or post-surg*):ti,ab,kw near/2 infect*:ti,ab,kw 7208
- #59 (#26 or #27 or #28 or #29 or #30 or #31 or #38 or #57 or #58) 619181
- #60 #14 and #56 and #59 with Publication Year from 2015 to 2021, in Trials 422
- #61 #21 or #40 or #45 or #60 1924

Embase via Elsevier:

- #1 'skin cancer'/exp OR 'skin tumor'/de OR 'melanoma'/de OR 'benign skin tumor'/exp OR 'actinic keratosis'/de 311543
- #2 ((skin OR derm* OR cutaneous OR epithelial OR epithelium OR epiderm*) NEAR/3 (cancer* OR neoplas* OR carcinoma* OR tumo*r* OR malignan* OR lesion* OR metasta* OR dysplas*)):ti,ab 230750
- #3 melanoma*:ti,ab 168357
- #4 ((naevoid OR nevoid) NEAR/3 syndrome*):ti,ab 184
- #5 ((dysplastic OR malignant) NEAR/2 (nevus OR naevus OR nevi OR naevi)):ti,ab 2679
- #6 hutchinson*:ti,ab AND 'melanotic freckle':ti,ab 59
- #7 'lentigo maligna':ti,ab 1617
- #8 ('basal cell' NEAR/1 (cancer* OR neoplas* OR carcinoma* OR tumo*r* OR malignan* OR lesion* OR metasta* OR epithelioma*)):ti,ab 20348
- #9 ((basocellular* OR basosquamous) NEAR/1 carcinoma*):ti,ab 351
- #10 ('merkel cell' NEAR/1 (cancer* OR neoplas* OR carcinoma* OR tumo*r* OR malignan* OR lesion* OR metasta* OR epithelioma*)):ti,ab 4952
- #11 'actinic keratosis':ti,ab 3427
- #12 'bowen* disease':ti,ab 459
- #13 (cutaneous NEAR/2 lymphoma*):ti,ab 3460
- #14 #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 521590
- #15 'mass screening'/de OR 'cancer screening'/de OR 'early cancer diagnosis'/de 145301
- #16 screen*:ti,ab OR detect*:ti,ab 3915915
- #17 #15 OR #16 3952938
- #18 'physical examination'/de OR 'skin examination'/exp OR 'photography'/exp 482345
- #19 ((skin OR body OR physical) NEAR/3 (exam* OR inspect*)):ti,ab 150389
- #20 'visual* inspect*':ti,ab 12778
- #21 dermoscop*:ti,ab 5809
- #22 dermatoscop*:ti,ab 1604
- #23 photography:ti,ab 19103
- #24 #18 OR #19 OR #20 OR #21 OR #22 OR #23 574221
- #25 #14 AND #17 AND #24 7368
- #26 screen*:ti 242957
- #27 #14 AND #26 2812
- #28 #25 OR #27 9711
- #29 'biopsy'/de OR 'skin examination'/exp OR 'large core needle biopsy'/de OR 'sentinel lymph node biopsy'/de 384845
- #30 biopsy*:ti,ab OR biopsies:ti,ab OR biopsied:ti,ab 651428
- #31 excise*:ti,ab OR excision*:ti,ab 231449
- #32 rebiops*:ti,ab 2750
- #33 #29 OR #30 OR #31 OR #32 1046723
- #34 harm:ti,ab OR harms:ti,ab OR harmful:ti,ab OR harmed:ti,ab 160662
- #35 'mortality'/de OR 'cancer mortality'/de OR 'surgical mortality'/de OR 'death'/de OR 'morbidity'/de OR 'adverse evenť/exp OR 'side effecť/exp 2123561
- #36 death:ti,ab OR deaths:ti,ab 1212813
- #37 ((adverse OR negative OR unintended) NEAR/1 (effect* OR event* OR outcome* OR reaction*)):ti,ab 674739
- #38 complication*:ti,ab 1385663
- #39 'side effect*':ti,ab 377930
- #40 safety:ti,ab 820849
- #41 'false negative*':ti,ab 47860
- #42 misdiagnos*:ti,ab 50580
- #43 overdiagnos*:ti,ab 7413
- #44 ((unneeded OR unnecessary) NEAR/5 (treat* OR therap* OR surg* OR procedure*)):ti,ab 20835
- #45 label*:ti,ab 686568
- #46 'psychological effect*':ti,ab 5318
- #47 'scar'/exp 80154
- #48 cicatrix:ti,ab OR scar*:ti,ab 233525
- #49 #34 OR #35 OR #36 OR #37 OR #38 OR #39 OR #40 OR #41 OR #42 OR #43 OR #44 OR #45 OR #46 OR #47 OR #48 5918605
- #50 #14 AND #33 AND #49 21318
- #51 ťumor classification'/exp 451299
- #52 ((detect* OR diagnos* OR biops*) NEAR/5 stage):ti,ab 71924
- #53 ((late* OR distant OR advanced OR end) NEAR/1 stage):ti,ab 191408
- #54 ((early OR earlier) NEAR/1 (diagnos* OR detect* OR discovery OR findings)):ti,ab 261028
- #55 #51 OR #52 OR #53 OR #54 897182
- #56 'register'/de OR 'cancer registry'/exp OR 'survival analysis'/de 174263
- #57 'mortality'/de OR 'cancer mortality'/de OR 'surgical mortality'/de OR 'death'/de OR 'morbidity'/de 1318853
- #58 registr*:ti,ab OR register*:ti,ab 586613
- #59 seer:ti,ab 15195
- #60 'surveillance epidemiology and end results':ti,ab 14942
- #61 morbidit*:ti,ab 610389
- #62 mortalit*:ti,ab 1172638
- #63 death:ti,ab OR deaths:ti,ab 1213072
- #64 survival:ti,ab 1446387
- #65 #56 OR #57 OR #58 OR #59 OR #60 OR #61 OR #62 OR #63 OR #64 4118283
- #66 #14 AND #55 AND #65 21012
- #67 'skin surgery'/de OR 'curettage'/de OR 'desiccation'/de OR 'cryosurgery'/de OR 'low level laser therapy'/de OR 'mohs micrographic surgery'/de OR 'lymph node dissection'/de 138543
- #68 surger*:ti OR surgical:ti 791912
- #69 curettage:ti,ab 14735
- #70 dessicat*:ti,ab 357
- #71 electrodessicat*:ti,ab 205
- #72 cryosurg*:ti,ab 5187
- #73 'laser ablation':ti,ab 8863
- #74 mohs:ti,ab 4639
- #75 metastasectom*:ti,ab 3647
- #76 lymphadenectom*:ti,ab 27719
- #77 (('lymph node*' OR lymphoid) NEAR/3 (remov* OR dissect* OR resect*)):ti,ab 41167
- #78 #67 OR #68 OR #69 OR #70 OR #71 OR #72 OR #73 OR #74 OR #75 OR #76 OR #77 949269
- #79 #14 AND #78 28544
- #80 'skin cancer'/exp/dm_su OR 'skin tumor'/dm_su OR 'melanoma'/dm_su OR 'benign skin tumor'/exp/dm_su OR 'actinic keratosis'/dm_su 33743
- #81 #79 OR #80 51615
- #82 'lymphedema'/de 17948
- #83 lymph*edema:ti,ab 14626
- #84 'surgical infection'/de 51938
- #85 ((surg* OR postsurg* OR 'post surg*') NEAR/2 infect*):ti,ab 29238
- #86 #49 OR #82 OR #83 OR #84 OR #85 5962061
- #87 #81 AND #86 14163
- #88 #28 OR #50 OR #66 OR #87 55786
- #89 #88 NOT (('animal model'/exp OR 'animal experimenť/exp OR 'nonhuman'/de OR 'animal'/exp) NOT 'human'/de) 54299
- #90 oral:ti OR tongue:ti OR larynx:ti OR laryng*:ti OR hypolaryng*:ti OR oropharyng*:ti OR pharynx:ti OR pharyng*:ti OR esophag*:ti OR oesophag*:ti OR gastric:ti OR ovary:ti OR ovaries:ti OR ovarian:ti OR cervical:ti OR cervix:ti OR endometrium:ti OR endometrial:ti OR lung:ti OR breast:ti OR ocular:ti OR vulva*:ti OR anus:ti OR anal:ti OR mucosal:ti 1937404
- #91 #89 NOT #90 43991
- #92 'clinical trial'/de OR 'controlled clinical trial'/de OR 'randomized controlled trial'/exp OR 'randomization'/exp OR 'single blind procedure'/de OR 'double blind procedure'/de OR 'crossover procedure'/de OR 'placebo'/de 1658355
- #93 'meta analysis'/exp OR 'meta analysis (topic)'/de 244255
- #94 'intermethod comparison'/de OR 'double blind procedure'/de 447271
- #95 'clinical trial*':ti,ab OR 'controlled trial*':ti,ab OR random*:ti,ab OR metaanaly*:ti,ab OR 'meta analy*':ti,ab OR trial:ti OR placebo:ti,ab 2279186
- #96 compare:ti OR compared:ti OR comparison:ti 549307
- #97 (evaluated:ab OR evaluate:ab OR evaluating:ab OR assessed:ab OR assess:ab) AND (compare:ab OR compared:ab OR comparing:ab OR comparison:ab) 2225824
- #98 (open NEXT/1 label):ti,ab 83963
- #99 ((double OR single OR doubly OR singly) NEXT/1 (blind OR blinded OR blindly)):ti,ab 241386
- #100 (parallel NEXT/1 group*):ti,ab 26720
- #101 crossover:ti,ab OR 'cross over':ti,ab 108903
- #102 ((assign* OR match OR matched OR allocation) NEAR/6 (alternate OR group OR groups OR intervention OR interventions OR patient OR patients OR subject OR subjects OR participant OR participants)):ti,ab 380281
- #103 assigned:ti,ab OR allocated:ti,ab 405667
- #104 (controlled NEAR/8 (study OR design OR trial)):ti,ab 374271
- #105 volunteer:ti,ab OR volunteers:ti,ab 254381
- #106 #92 OR #93 OR #94 OR #95 OR #96 OR #97 OR #98 OR #99 OR #100 OR #101 OR #102 OR #103 OR #104 OR #105 5739562
- #107 'controlled study'/exp 8088576
- #108 'longitudinal study'/exp OR 'prospective study'/de OR 'retrospective study'/de 1746197
- #109 'cohort analysis'/de OR 'follow up'/de 2140477
- #110 'observational study'/de 218946
- #111 'correlational study'/de 46791
- #112 'family study'/de 25940
- #113 'case control*':ti,ab 167936
- #114 cohort:ti,ab 977729
- #115 longitudinal:ti,ab 347885
- #116 'follow up':ti,ab OR followup:ti,ab 1620158
- #117 prospective*:ti,ab 1120812
- #118 'comparison group*':ti,ab OR 'control group*':ti,ab 707155
- #119 observational:ti,ab 297638
- #120 retrospective*:ti,ab 1306243
- #121 database*:ti,ab 705193
- #122 nonrandomi*:ti,ab 36131
- #123 population*:ti,ab 2419527
- #124 epidemiologic*:ti,ab 326244
- #125 'cross sectional':ti,ab 494182
- #126 #107 OR #108 OR #109 OR #110 OR #111 OR #112 OR #113 OR #114 OR #115 OR #116 OR #117 OR #118 OR #119 OR #120 OR #121 OR #122 OR #123 OR #124 OR #125 13289912
- #127 #106 OR #126 15226253
- #128 #91 AND #127 26927
- #129 #91 AND #127 AND [english]/lim AND [2015-2021]/py 11982

Appendix A Figure 1 Literature Flow Diagram

Abbreviation: KQ = Key question.

This figure is a flow chart that summarizes the search and selection of articles. There were 20,286 citations identified through literature databases. An additional 34 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 20,320 unique citations were screened at the title/abstract stage. The full-text of 522 citations were examined for inclusion for one or more of the four Key Questions.

Appendix A Table 1 Inclusion and Exclusion Criteria

| Include | Exclude
Population | KQs 1–3: Asymptomatic adolescents and adults age 15 years and older with or without a family history of melanoma; KQ4: Adolescents and adults age 15 years and older diagnosed with skin cancer | Individuals younger than age 15 years; KQs 1–3: Individuals under surveillance for skin cancer (e.g. previous skin cancer; genetic syndromes associated with increased skin cancer risk; conditions associated with suppressed immune system); KQ4: Overlapping population with already included study (contains duplicative data)
Settings | Primary care-relevant settings; In-person or virtual settings; Countries categorized as “Very High” on the 2019 Human Development Index (as defined by the United Nations)^1^ | KQ1, KQ2: Conducted exclusively in specialty care settings (for example, dermatology, plastic surgery)
Screening tests | Total or partial visual skin examination conducted by a clinician with or without tools to aid examination (for example but not limited to, dermatoscopy; whole body photography) | KQ1: Lesion-directed diagnostic skin examination (e.g. in response to patient concern); Skin self-exam or behavioral counseling by clinician for self-exam
Comparison | KQ1: No visual skin examination; KQ2: Usual care (e.g. lesion-directed examination); KQ4: Stage or thickness at detection (precancerous lesions or skin cancer)
Outcomes | KQ1, KQ4: Morbidity or mortality associated with skin cancer, including quality of life; skin cancer mortality; or all-cause mortality; KQ2: Stage or lesion thickness at detection of skin cancer or precancerous lesion.; KQ3: Any persistent harm (beyond 30 days) from screening, biopsy, or excision; including psychosocial harms and procedure-related adverse events | KQ1, KQ2, KQ4: Non-skin location, Merkel cell carcinoma; Risk reduction behaviors (e.g., skin self-exam, sun protective behaviors) or measures of doctor-patient relationship quality; Outcomes not stratified by skin cancer type (melanoma vs. non-melanoma skin cancers); KQ4:; - - Reports relative survival data only (no mortality data); - - Reports risk as a continuous estimate only (e.g., single HR / risk estimate for association); - - Reports results in graphical format only
Study design | All KQs: Fair- and good-quality studies; KQ1, KQ2, KQ4: Randomized, controlled trials; controlled clinical trials; nonrandomized studies with a contemporaneous control; KQ3: Randomized, controlled trials; controlled clinical trials; large screening registry or database nonrandomized studies; cohort studies; and systematically selected case series; Note: KQ4 studies must use AJCC (any version) or SEER staging criteria | All KQs: Poor-quality studies; KQ1, KQ2: Decision analyses; KQ3: Case studies; KQ4:; - - Studies taking place at single site or institution; - - Studies reporting only Breslow depth, thickness, T-stages, or Clark levels; - - Studies comparing grouped stages (e.g., I+II vs. III+IV) or sub-stages (e.g., Ia vs. Ib vs. Ic vs. Id); - - Studies limited to a single body part (e.g., lip, outer ear) or cancer sub-type (e.g., acral melanoma)
Publication type | Original, peer-reviewed research | Not original research (e.g., editorials, opinion pieces, narrative reviews); Not peer-reviewed research (e.g., conference abstracts)

Abbreviations: AJCC = American Joint Committee on Cancer; KQ = Key question; HR = Hazard ratio; SEER = Surveillance, Epidemiology, and End Results Program

Appendix A Table 2 Quality Assessment Criteria

Study Design | Quality criteria
Nonrandomized studies (e.g., prospective cohort studies), adapted from the Newcastle-Ottawa Scale (NOS)^2^ | Bias arising in randomization process or due to confounding; - Balance in baseline characteristics; - No baseline confounding; - No time-varying confounding; Bias in selecting participants into the study; - No evidence of biased selection of sample; - Start of followup and start of intervention coincide; Bias due to departures form intended interventions; - Participant intervention status is clearly and explicitly defined and measured; - Classification of intervention status is unaffected by knowledge of the outcome or risk of the outcome; Bias in classifying interventions; - Fidelity to intervention protocol; - Participants were analyzed as originally allocated; Bias from missing data; - Outcome data are reasonably complete and comparable between groups; - Confounding variables that are controlled for in analysis are reasonably complete; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported
Randomized clinical trials, adapted from U.S. Preventive Services Task Force Manual ^3^ | Bias arising in the randomization process or due to confounding; - Valid random assignment/random sequence generation method used; - Allocation concealed; - Balance in baseline characteristics; Bias in selecting participants into the study; - CCT only: No evidence of biased selection of sample; Bias due to departures from intended interventions; - Fidelity to the intervention protocol; - Low risk of contamination between groups; - Participants were analyzed as originally allocated; Bias from missing data; - No, or minimal, post-randomization exclusions; - Outcome data are reasonably complete and comparable between groups; - Reasons for missing data are similar across groups; - Missing data are unlikely to bias results; Bias in measurement of outcomes; - Blinding of outcome assessors; - Outcomes are measured using consistent and appropriate procedures and instruments across treatment groups; - No evidence of biased use of inferential statistics; Bias in reporting results selectively; - No evidence that the measures, analyses, or subgroup analyses are selectively reported